# Discussion

The biological effects of vitamins and minerals have sparked enormous scientific enthusiasm in examining their potential as agents for preventing a variety of chronic diseases and conditions. Over the past four decades, there have been more than 355,000 peer-reviewed articles addressing one or more of the nutrients that often are included in multivitamin/mineral supplements. The evidence accumulated to date primarily concerns vitamin/mineral supplement use in relation to the prevention of cancer, cardiovascular disease, and bone health, and less frequently, eye disease and cognitive function. In this context, the nutrients that have been studied the most include multivitamins, β-carotene, vitamin E, folic acid/vitamin B6/vitamin B12, calcium, vitamin D, and to a lesser extent, selenium.

In 2003, the United States Preventive Services Task Force released a report concluding that the evidence is insufficient to recommend for or against the use of supplements of vitamins A, C, or E; multivitamins with folic acid; or antioxidant combinations for the prevention of cancer or cardiovascular disease. The Task Force also concluded that β-carotene supplementation provides no benefit in the prevention of cancer or cardiovascular disease in middle-aged and older adults.^160^ In addition to providing an update on the available evidence, this evidence report goes beyond the scope of the United States Preventive Services Task Force review to have included systematic reviews and original studies on the efficacy of multivitamin/mineral supplement use in the prevention of chronic diseases and conditions, in addition to cancer and cardiovascular disease, in the general adult population, and on the safety of multivitamin/mineral supplements, vitamin A, vitamin D with or without calcium, vitamin E, folic acid, β-carotene, selenium, and iron supplementation in the general population of adults and children.

## Summary of the Key Findings

Results from this systematic review indicate a relative paucity of data that specifically address the efficacy of multivitamin/mineral supplement use in the prevention of chronic disease in the general population of the United States. The data were on the efficacy of designed combinations of vitamins and minerals; none of the trials used the one-a-day multivitamins (of approximately 100% of the RDAs) prevailing on the market. The Linxian trial suggests that supplementation with combined β-carotene, vitamin E and selenium supplements at doses 1 to 2 times the RDA for 5 years had 13 percent to 21 percent reductions in gastric cancer incidence, gastric cancer mortality, and total cancer mortality in a nutritionally deprived Chinese population. The reduction in cancer mortality was stronger in women than in men, and in persons of age 55 or younger. There were no significant effects on total cancer incidence and cerebrovascular mortality. The SU.VI.MAX study in a French population documented a 31 percent reduction in overall cancer risk by use of 5 antioxidants (vitamin C, vitamin E, β-carotene, selenium, and zinc) for 8 years in men but not in women, and a 12 percent reduction in prostate cancer risk, particularly a 48 percent risk reduction in those with normal prostate specific antigen levels at baseline. There was no significant effect of the combined antioxidants on ischemic cardiovascular disease incidence. In this trial, men had lower serum levels of vitamin C and β-carotene than women at baseline. Multivitamin/mineral supplement use for 3 to 6 years had no significant benefits in preventing cataract in 3 trials in the United States (with one trial also in United Kindom) and the Linxian trial. High-dose zinc combined with antioxidants had beneficial effects on age-related macular degeneration only in those with intermediate age-related macular degeneration in one or both eyes, or those with advanced age-related macular degeneration in one eye.

Overall, total mortality data pointed to either no increased risk or lower risk in the groups with multivitamin/mineral supplement use. Total mortality was 9 percent lower among those who received β-carotene, selenium, and vitamin E in the Linxian trial; there was no sex- or age-difference in the relative risks. In the AREDS study, total mortality was 6 percent higher in the group receiving antioxidants compared to the group receiving no antioxidants, but the increase was not statistically significant. Among the participants at high risk for age-related macular degeneration, total mortality was 13 percent to 20 percent lower in the groups receiving zinc alone or zinc combined with antioxidants.^64,^ ^75^ In the SU.VI.MAX study, a sex-difference was documented for the relative risk of total mortality among those receiving antioxidants and zinc compared to those receiving placebo. In the REACT, total mortality rate was not calculated. Nine deaths occurred in the antioxidant group, whereas 3 deaths occurred in the placebo group. The deaths in the antioxidant group were caused by esophagitis, sudden death, aneurysm, pulmonary fibrosis, cancer, and coronary thrombosis.

Daily supplementation with β-carotene of 20 mg, 30 mg or 50 mg was not protective against malignancies, cardiovascular disease outcomes, diabetes mellitus, cataract or age-related maculopathy. Supplementation with β-carotene with or without vitamin A increased the incidence of lung cancer in persons with asbestos exposure or in cigarette smokers, and was associated with increased mortality in some trials. To date, there has been no randomized controlled trial that assessed the efficacy of vitamin A alone in preventing chronic disease. Studies in selected populations (nutritionally inadequate, asbestos exposure, or smokers) showed no benefit of combinations of vitamin A and zinc or vitamin A and β-carotene for the prevention of stroke mortality, esophageal or gastric cancer incidence, or cardiovascular or all-cause mortality.

Vitamin E supplements (synthetic α-tocopherol 50 mg or 300 IU per day, or natural source, 600 IU per day) have been studied for primary prevention of cancer, cardiovascular disease, cataract, and age-related eye disease. The evidence predominantly comes from the ATBC and WHS studies.^68,^ ^87,^ ^90,^ ^96,^ ^98^–^100,^ ^107^ There was a lack of effects of vitamin E in the prevention of these diseases, except for a 32 percent reduction in prostate cancer incidence, a 41 percent reduction in the prostate cancer mortality, and a 22 percent reduction in colorectal cancer in heavy smokers in the ATBC, and decreased cardiovascular deaths (primarily sudden death) in the WHS participants, particularly in those aged 65 years or older. The findings on hemorrhagic stroke were conflicting between the ATBC trial and the WHS; the former found a higher risk with use of low-dose α-tocopherol supplements but the latter found a lower risk with use at a high dose.

Two previous systematic reviews reported that supplementation with folic acid at daily doses of 0.75 mg or 30 mg, alone or in combination with vitamin B12 and/or vitamin B6 for 5–12 weeks, had no significant effects on cognitive function in 5 small randomized controlled trials. Combined vitamin B2 and niacin supplement use for 5 years had no significant effects on cerebrovascular mortality, total mortality, total cancer incidence, and esophageal or gastric dysplasia/cancer incidence and esophageal or gastric cancer mortality in a poorly nourished population in China.

In a study in persons with a history of non-melanoma skin cancer, supplementation with selenium of 200 mcg per day had no effect on cardiovascular outcomes, but had protective effects on total mortality and incidence of lung, colorectal, and prostate cancers. Another study in China found a significantly reduced risk for liver cancer in those who used selenium supplements of 200 mcg/day for two years.

Due to the substantial amount of efficacy data on calcium/vitamin D and osteoporosis, we reviewed systematic review articles supplemented with data from recent randomized controlled trials and data from randomized controlled trials meeting our inclusion criteria that were not included in previous systematic reviews. The previous reviews reported that supplementation with calcium has short-term (particularly within one year) benefit on retaining bone mineral density in postmenopausal women, and a possible effect in preventing vertebral fractures. The reviews also indicated that combined vitamin D_3_ (700–800 IU/day) and calcium (1000 mg/day) may reduce the risk of hip and other non-vertebral fractures in populations with low levels of vitamin D and/or calcium. Recent published data from the WHI trial were consistent with these systematic reviews in showing a 1.06 percent higher hip bone density (p<.02) and a 12 percent non-significant lower risk for hip fracture in postmenopausal women after receiving calcium carbonate (500 mg twice a day) and vitamin D_3_ (200 IU twice a day) for an average of 7 years as compared to women receiving a placebo. In this trial, participants were allowed to have self-selected use of multivitamin supplement as well as calcium and vitamin D supplements up to 1000 mg and 600 IU per day, respectively, and thus had a baseline average daily intake of 1150 mg calcium and 365 IU vitamin D. Hence, the WHI participants had higher intake of calcium than the general population (761 mg per day). The WHI trial found no benefit of calcium and vitamin D supplementation in preventing colorectal cancer incidence.

For evidence on the safety of multivitamin/mineral supplements when used for the purpose of preventing chronic disease, we identified 10 studies using multivitamin/mineral preparations and 24 studies using single nutrients for primary prevention of chronic disease. Doses were usually 2 to 10 times the RDA. Overall, we found no consistent pattern of increased adverse effects in the active group compared with the placebo group, with the exception of changes in skin color, which was common in studies in which beta-carotene was part of the multivitamin preparation.

Supplementation with β-carotene with or without vitamin A also increased the incidence of lung cancer in persons with asbestos exposure or in heavy smokers, and was associated with increased mortality. Vitamin A supplementation may moderately increase serum triglyceride levels. Calcium supplementation increased the risk of kidney stones. Vitamin E supplementation was associated with an increased incidence of epistaxis but was not associated with an increased risk of more serious bleeding events, such as hemorrhagic stroke. Iron supplementation was found to reduce weight gain in iron-sufficient, non-anemic children in a small randomized controlled trial. But more recent trials have not fully clarified this issue, because they targeted deficient populations and/or included other micronutrients in the intervention formulation.

## Efficacy of Multivitamin/mineral Supplements

Between the Linxian trial and the SU.VI.MAX trial, the types of vitamin/mineral supplements overlapped and the doses were similar. The efficacy was somewhat different, but had similar implications.^64,^ ^68^–^70,^ ^111,^ ^161,^ ^162^ While the multivitamin/mineral supplements used in the Linxian trial reduced cancer mortality by 21 percent in women and by 7 percent in men, the efficacy of the multivitamin/mineral supplementation in the SU.VI.MAX in reducing cancer incidence was only evident in men. This sex-dependent efficacy may be accounted for by the different nutritional status of the study populations, i.e., generally poor nutritional status in the Linxian population and the suboptimal antioxidant status in men compared with women in the SU.VI.MAX.^69^ These findings also corroborated observational studies that suggest benefits of fruits and vegetables on cancer prevention. However, they did not suggest that supplementation with multivitamins and minerals can replace a balanced, healthful diet to achieve an optimal health state because these studies were not designed to address that question. In view of the inadequate nutritional intake in the Linxian population and the “French paradox,” the generalizability of the findings from the SU.VI.MAX and Linxian trials to the United States population is uncertain.

For cataract prevention, AREDS was the largest trial with findings internally consistent in showing no benefits of multivitamin/mineral supplement use. While the REACT found a deceleration in cataract progression in the United States study site, similar benefits were not seen in the United Kingdom study site. For the prevention of age-related macular degeneration, the AREDS study found benefits of high-dose (10 times RDA) zinc alone or in combination with antioxidants in persons with intermediate age-related macular degeneration in one or both eyes, or persons with advanced age-related macular degeneration in one eye. The MONMD study was conducted in persons with advanced dry age-related macular degeneration. The study suffered from missing data and unclear data analysis and presentation, but the authors concluded that the antioxidant supplements used in the study stabilized but did not improve dry age-related macular degeneration. It appears that benefits of multivitamin/mineral supplements in the prevention/management of age-related macular degeneration were limited to persons with moderate or advanced age-related macular degeneration. However, such inference was based on findings from two trials (n=3,580) with one that was very small (n=71).

With multivitamin/mineral supplements in wide use by the general public in the United States, particularly middle-aged or older individuals, it would be difficult now to recruit trial participants for the conduct of large-scale randomized placebo-controlled trials to determine the efficacy of multivitamin supplementation in chronic disease prevention. In the AREDS, 55 percent of study participants had used some vitamins/minerals before enrollment, and consequently, the study investigators provided a free brand name multivitamin to 66 percent of the study participants. Because many nutrients share common mechanisms of action, self-selected supplement use may attenuate the net efficacy, if any, of the nutritional supplements under investigation. This conjecture is supported by the findings that 40 percent of the WHS participants had multivitamin/mineral supplement use in addition to study supplements, and when limited to non-multivitamin supplement users, the relative risk of major cardiovascular disease was 0.88 (95% CI 0.75–1.03), in contrast to a relative risk of 1.02 (95% CI 0.84–1.25) among multivitamin supplement users.^87^ We have found that very few studies reported participants' self-selected supplement use, and most studies allowed use of supplements that were not under investigation. This limitation was rarely addressed in the literature.

## Efficacy of β-carotene

Much research interest has been devoted to elucidating how β-carotene may increase lung cancer risk in high-risk individuals. “Antioxidants” have been assumed to exert in vivo anti-oxidative effects, based on in vitro observations. In fact, the oxidative propensity of a purported “antioxidant” depends at least on the concentrations, the redox potential of the molecule, and the biological environment the molecule is in (e.g., the oxygen tension and the existence of other oxidants/antioxidants). For example, carotenoids may inhibit or enhance apoptosis depending on their concentration, concerted action of other oxidants/antioxidants, cell type, and redox status.^163^ At low oxygen tension, β-carotene may act as an antioxidant, while at high oxygen tension, it may behave as a pro-oxidant,^164^ although a pro-oxidant effect was not corroborated by an in vitro experiment on human bronchial epithelial cells.^165^ While β-carotene has a pivotal role in preventing vitamin A deficiency, the general lack of benefits from β-carotene supplementation and its potential harms in increasing lung cancer risk among high-risk individuals argue against supplementation with β-carotene alone for chronic disease prevention in the general population.

## Efficacy of Vitamin E

In addition to β-carotene, vitamin E is the most extensively studied single nutrient as a chemopreventive agent. Several systematic review articles on vitamin E were identified in our literature search.^114,^ ^166^–^169^ However, in the majority of the previous reviews, primary prevention trials were not separated from secondary prevention trials,^166,^ ^114,^ ^168^ and when aggregate efficacy was calculated, the efficacy of a single nutrient in one intervention arm was not separated from the efficacy of multiple nutrients in one intervention arm.^166,^ ^114,^ ^168^ A systematic review can give misleading results for the efficacy of a single nutrient by including data from trials of multiple nutrients in an intervention arm (which is a multivitamin/mineral intervention). This argument is based on the rationale that several nutrients share common mechanisms of action, that nutrient-nutrient interaction may exist, and that the efficacy of an individual nutrient cannot be determined in a trial that includes multiple nutrients in an intervention arm. This argument is also substantiated by a systematic review in which the aggregate effect of vitamin E alone on cardiovascular death, fatal myocardial infarction, non-fatal myocardial infarction was consistently in the protective direction (RR 0.96, 0.97, and 0.72, respectively), but the RR was 1.03, 1.02, and 0.99 respectively when efficacy was calculated for vitamin E in combination with other nutrient(s).^114^

The general lack of benefits of vitamin E in the primary and secondary prevention of cancer, cardiovascular disease, cataract, and age-related macular degeneration was unexpected in view of the substantial evidence from experiments, animal studies and epidemiologic studies that showed great promise of vitamin E. Natural vitamin E has eight forms, α-, β-, γ-, and δ-tocopherols and α-, β-, γ-, δ-tocotrienols. Supplements of RRR-α-tocopherol, that is not naturally occurring, but derived from methylating γ-tocopherol in vegetable oil, are often commercially labeled as “natural source” vitamin E (as used in the WHS^87^).^96^ It has been shown that high intake of α-tocopherol may enhance the metabolism of other forms of vitamin E.^170^–^171^ Because γ-tocopherol is the predominant (70%) vitamin E in the typical American diet,^172^ and because γ-tocopherol and its metabolite may have biological effects,^173,^ ^174^ it has been hypothesized that reductions in circulating γ-tocopherol levels by α-tocopherol supplementation may compromise the efficacy of α-tocopherol, if any.^175^ In the present review, we found that many trials that used vitamin E did not report the chemical forms. Presumably, all trials used some esters of α-tocopherol because α-tocopherol was the center of research attention in the past, and γ-tocopherol or mixed tocopherols were only available on the market in recent years.

Based on data from the PPP and WHS, neither synthetic α-tocopherol of 300 IU per day for a short term, 3.6 years, nor natural source α-tocopherol of 600 IU every other day for a long-term, 10 years, had beneficial effects in the primary prevention of cardiovascular outcomes.^87,^ ^112^ One intriguing finding from the WHS was the significantly lower risk of cardiovascular death (primarily sudden death), which might have been due to chance alone.^87^

Prompted by the findings from the ATBC trial and the NCP trial on the reduced risk for prostate cancer,^101,^ ^133^ the National Cancer Institute has launched the Selenium and Vitamin E Cancer Prevention Trial (SELECT) to test for the efficacy of daily use of α-tocopherol supplements in the primary prevention of prostate cancer in 32,400 men. The SELECT trial uses synthetic α-tocopherol of a high dose, 400 IU, and will be closed out in 2013.^176^

## Vitamin/mineral Supplement Use and Total Mortality

The implications of the impact of vitamin/mineral supplement use on total mortality are uncertain. Total mortality is relevant to the context of chronic disease prevention because it may provide a clue to potential harms and can be considered as a reference outcome in risk/benefit analysis. However, because two of the causality criteria cannot be applied to death outcome (i.e., response to re-challenge and response to discontinuation of use), the risk for death should be considered based on plausible biological mechanisms and the evidence on the effects of the nutrients on specific disorders. With this rationale along with the consideration on the great heterogeneity in the study design (i.e., factorial design vs. parallel-arm design), doses of supplements, duration of supplement use, and characteristics of study participants, we did not attempt to calculate an aggregate estimate for total mortality for the trials that reported such data. Instead, we examined the causes of death that might have accounted for the difference in total mortality between randomized groups.

The 9 percent reduced risk of total mortality by multivitamins/minerals in the Linxian trial was likely to be driven by the reduction in stomach cancer mortality. Similarly, reduced total mortality in men in the SU.VI.MAX may reflect the 31 percent reduction in cancer incidence.

The higher total mortality by β-carotene supplementation during the conduct of ATBC trial was primarily due to lung cancer and cardiovascular disease, whereas the higher total mortality in the first 4 years of post-trial follow up was primarily due to a wide spectrum of cardiovascular diseases.^103^ How β-carotene increased the risk of cardiovascular mortality remains unclear.

A contentious issue regarding vitamin E supplementation is its impact on total mortality. The issue was set off by a recent meta-analysis from which an excess of 39 deaths per 10,000 persons was reported (95% CI 3 to 74 per 10,000) for trials using vitamin E at doses greater than or equal to 400 IU per day.^168^ In contrast, mortality was reduced (risk difference was -16 per 10,000 (-40 to 10 per 10,000) for trials using lower doses (less than 400 IU per day).^168^ This meta-analysis had the shortcoming in combining 9 primary prevention trials and 10 secondary prevention trials, and combining data from 9 trials using vitamin E alone and data from 10 trials using vitamin E combined with other nutrients, including β-carotene which has been linked with an increased risk for total mortality. Furthermore, most trials that used high doses were secondary prevention trials in persons with various types of diseases and medication use.

In the present review on vitamin E supplement use for primary prevention, the ATBC and the WHS participants comprised 87 percent of the study populations. In the ATBC trial, a 2 percent increased risk of total mortality was observed at the end of the supplementation period, but a 4 percent risk “reduction” was observed in the next 3 years, followed by a 5 percent increase for the next 3 years and 0 percent for the next 2 years.^103^ The overall relative risk of total mortality during the 8 years of post-trial follow up was 1.01 (95% CI 0.96 to 1.05) and there was no difference in the relative risk of mortality throughout the post-trial follow up period.^103^ These findings suggest no late effects of α-tocopherol supplementation on risk of death in heavy smokers. In the WHS,^87^ the authors reported that “the main causes of death, apart from cardiovascular and cancer deaths, were pulmonary diseases (32 vitamin E, 22 placebo) and violent deaths, excluding suicide (9 vs. 6). None of these causes of deaths was significantly related to vitamin E.” The relative risk of cardiovascular death and cancer death in the WHS was 0.76 (95% CI 0.59–9.98) and 1.12 (95% CI 0.95–1.32), respectively.^87^ The VECAT documented 31 deaths (20 in vitamin E; 11 in placebo), and the authors reported that “no consistent or unusual patterns were identified among the specific causes of death recorded.”^113^ In view of these data along with consideration of biological plausibility, we find no convincing evidence to suggest vitamin E supplement use increases risk of death per se.

## Timing and Duration of Supplement Use

Timing and duration of supplement use is an important determinant of the efficacy. However, these issues have rarely been addressed in the literature and little is known about the optimal time to start and stop supplementation. For the reasons of feasibility and resource constraints, most randomized controlled trials have had a follow up period of approximately 5 years, and some followed for only 2 years, while a chronic disease may take 10 to 20 years to develop.

In the ATBC and CARET studies, lung cancer risk was increased by β-carotene alone or by combined β-carotene and retinol over 5 to 10 years of supplementation among heavy smokers and persons regularly exposed to asbestos, suggesting that the supplementation regimens might have accelerated the progression of carcinogenesis in these high-risk groups.

The CARET study reported a late effect of β-carotene supplementation on lung cancer.^94^ The ATBC trial observed a late effect on colorectal cancer, but not lung cancer.^103^ These post-trial follow up data may provide some clues to how likely the link between β-carotene supplementation and increased lung cancer incidence was causal, and how the effects may vary with carcinogenesis processes, but the data may also be simply due to chance alone or be subject to confounding by trial participants' changes in supplement use after the closeout of the trial.

An intriguing finding from the WHS study was that a significantly lower risk of major cardiovascular events was limited to women aged 65 or older who received vitamin E supplements for 10 years (RR 0.74).^87^ This finding is not congruent with the oxidative hypothesis stating that oxidative damage occurs early in the atherosclerosis process,^177^ nor with the data that showed that early atherosclerotic lesions occurred in adolescents.^178,^ ^179^ In the Linxian trial with 5 years of follow up, benefits of α-tocopherol, selenium and β-carotene on cancer mortality, cardiovascular mortality and total mortality were more evident in those aged less than 55 years.^67^ The SU.VI.MAX trial found a protective effect of antioxidants on prostate cancer incidence among men who had normal prostate specific antigen levels, but not in men who had elevated prostate specific antigen levels after 8 years of follow up.^70^ The benefit on prostate cancer by β-carotene supplement use in the ATBC trial was limited to clinical prostate cancer but not for latent cancer.^101^ If cancer development takes more than 10 years to develop, these data would seem to have provided paradoxical information on whether antioxidant supplements should be used earlier or later in the life span, let alone whether different chemopreventive agents may act differently along the carcinogenesis process. Additional data from subgroup analyses from trial enrollment to diagnosis with adjustment for potential confounding variables such as age in other completed or on-going trials are needed before a clear picture can be seen.

## Doses of Vitamin/mineral Supplements

The RDA is the average daily dietary intake level sufficient to meet the nutrient requirement of nearly all (97 to 98 percent) apparently healthy individuals in a particular age and gender group. There is a wide range of doses of vitamins and minerals formulated into over-the-counter supplements. The “one-a-day” type of multivitamins/mineral supplements may contain nutrients of 100% to 300% of the RDAs for adults. The doses of B vitamins in other multivitamin preparations are high; usually 1667% of the RDAs, and up to 6000% of the RDAs. For vitamin E, commonly used doses in individual vitamin E or multivitamin supplements are 100, 200, 400, and 800 IU which, if of natural form, correspond to 333%, 667%, 1332% and 2640% of the RDA for vitamin E. For vitamin C, commonly used doses in individual vitamin C supplements or multivitamin supplements are 250 mg, 500 mg, and 1000 mg, which correspond to approximately 417%, 833%, and 1667% of the RDA for vitamin C.

In this review, only two trials of multivitamin/minerals supplements reported data on cancer and cardiovascular outcomes and the benefits on these outcomes were implicated in those who had inadequate nutrient intake. The active supplements (combined vitamin E, selenium, and β-carotene; combined vitamin E, selenium, β-carotene, vitamin C and zinc) in these two trials were of doses around 100%-200% of the RDAs. Hence, the efficacy of lower or higher doses of the nutrients was not known. With respect to prevention of age-related macular degeneration, the AREDS study used a high dose of vitamin E (400 IU) and zinc (2 times the UL), and the benefit on preventing the progression to advanced age-related macular degeneration appeared to have come primarily from the groups receiving zinc. In this study, of nearly 100 comparisons, a few adverse effects occurred more often in participants receiving zinc as compared to participants receiving no zinc, including more difficulties in swallowing the pill (17.8% vs. 15.3%), more hospitalizations due to genitourinary problems (7.5% vs. 4.9%), more “adverse circulatory experiences” (0.9% vs. 0.3%) and more anemic individuals (13.2% vs. 10.2%).

In the WHI study, participants were allowed to have self-selected use of multivitamin supplements, as well as calcium and vitamin D supplements up to 1000 mg and 600 IU per day, respectively. Hence, the WHI participants had a baseline average daily intake of 1150 mg calcium and 365 IU vitamin D. If women randomized to the calcium supplementation group also used their own calcium supplements and multivitamin supplements that contained calcium, a daily total intake could have approached the UL, 2500 mg, and led to a higher risk for adverse effects such as kidney stone formation.

## Safety Consideration

As noted previously, the potential adverse effects of multivitamin or single-nutrient supplements have not been systematically studied in well-controlled trials. Because of the uncertainties regarding design (exposure, doses, etc.) and the ethical constraints, such studies may never be carried out. Our assessment of the safety of supplements, therefore, must rely on the safety monitoring during randomized controlled trials and on case reports and other observational data.

Since the ULs were defined based on limited data or extrapolations, and generally were based on one single indicator of adverse effects, it is not surprising that several trials reported no adverse effects after consumption of doses above the UL. These studies may have used indicators other than those used to define the UL for that nutrient, or may have had only slight increases in an adverse effect that was not significantly different from the placebo group. A few adverse effects, because they appear with certain consistency in different trials, may be interpreted as common responses in the general population. For example, yellowing of the skin with sustained consumption of β-carotene at daily doses of 8 mg or higher has been described in most studies using this nutrient. Similarly, increases in serum triglycerides with vitamin A supplementation have been reported in several studies. Minor bleeding, particularly epistaxis, also appears to be a relatively common effect of vitamin E supplementation. But as noted above, there is no evidence that this vitamin results in an increased risk of more serious bleeding events, such as hemorrhagic stroke.

A general conclusion, with the caveats mentioned regarding the limited data available, is that consumption of multivitamin supplements for prolonged periods (1 to 8 years) appears to be safe. We found no reports of major, life-threatening adverse effects, and no evidence of increased mortality in groups consuming multivitamin supplements. A similar general conclusion can be reached for single-nutrient supplements. However, the late effects of β-carotene on cardiovascular death in heavy smokers deserve further investigation for the underlying mechanisms. In addition, some studies confirmed the adverse effects used to define the UL, as for example, gastrointestinal symptoms and/or diarrhea with vitamin C. While the UL for this nutrient was set at 2 g per day, some studies have reported these symptoms with doses of 750 mg per day. It is recognized that the ULs represent a probability of an adverse event in the general population, and that that probability (and therefore the UL threshold) may vary across subgroups and in different circumstances.

## Limitations

An enormous volume of literature exists on the effects of multivitamin/mineral supplements when seeking to include the literature on all of the single nutrients that are often included in multivitamin supplements. To find the most relevant literature on our questions, we had to design a search strategy that sacrificed some degree of sensitivity in order to have reasonable specificity. Thus, it is possible that the search strategy missed some studies that have potentially relevant data. We tried to minimize this problem by performing hand searching of the references in key articles and reviews, and by asking our peer reviewers to identify any important studies that were missing in the draft report. Clinical experts may question the efficiency of our systematic approach to searching the massive volume of literature on multivitamin/mineral supplements, but we were concerned about the risk of bias in selecting articles for inclusion in the review if we had relied only on experts for identifying eligible studies.

In addition, for our review of evidence on the efficacy of multivitamin/mineral supplements in preventing chronic disease, we focused on randomized controlled trials as the strongest source of evidence. We also focused on primary prevention studies because they are the ones most relevant to use of multivitamins in the general population of healthy adults. Although we focused on randomized controlled trials only for efficacy data, we included observational studies in our consideration of the safety of multivitamins/mineral supplements.

Many of the studies had important methodologic limitations. One particularly important limitation is that study groups often were permitted to use vitamin/mineral supplements other than the assigned study interventions. Such leeway would have attenuated the observed efficacy of study supplements. In addition, most studies did not provide information on trial participants' characteristics, such as medication use, that may have modified the effects of the nutrients of interest.

There is marked heterogeneity of the literature on our key questions, with differences in study design (e.g., some of the trials used a factorial design), targeted study population (with different cultural/lifestyle and genetic backgrounds), chemical forms and doses of supplements, and specific outcome measures. This degree of heterogeneity makes it difficult to synthesize results across studies, and generally makes it inappropriate to perform quantitative synthesis (i.e., meta-analysis). The differences in study populations are particularly problematic because few studies have examined the efficacy of multivitamin/mineral supplements in the general United States population, making it difficult to determine whether the results of studies in other countries such as China and France can be applied to the United States population.

There has been inconsistent reporting on the potential adverse effects of the nutrients of interest. A significant proportion of data in the literature concerning adverse events came from case reports that are subject to serious methodological limitations. As a result, the overall strength of the evidence on adverse effects is weak. In addition, the implications of data from case reports are uncertain. In a previous systematic review of case reports of adverse effects of drugs, it was found that 83 percent of suspected adverse reactions were not further evaluated in confirmatory studies, and adverse effect alerts were not systematically incorporated into published drug reference information.^140^

## Conclusions

Limited evidence accumulated to date suggests potential benefits of multivitamin/mineral supplements in the primary prevention of cancer in individuals with poor nutritional status or suboptimal antioxidant intake. However, the heterogeneity in the study populations upon which this evidence is based limits generalization to the United States population. The evidence also indicates that multivitamin/mineral supplement use does not have significant effects in the primary prevention of cardiovascular disease and cataract, but may confer benefits to slow the progression of age-related macular degeneration among persons at high risk for developing advanced stages of the disease.

We also conclude that regular supplementation with a single nutrient or a mixture of nutrients for years has no significant benefits in the primary prevention of cancer, cardiovascular disease, cataract, age-related macular degeneration or cognitive decline. A few exceptions, that were reported in a single or a few trials, included a decreased incidence of prostate cancer with use of synthetic α-tocopherol (50 mg per day) in smokers, a decreased progression of age-related macular degeneration with high doses of zinc alone or zinc in combination with antioxidants in persons at high risk for developing advanced stages of the disease, and a decreased incidence of cancer with use of selenium (200 mcg per day). Supplementation with calcium has short-term (particularly within one year) benefit on retaining bone mineral density in postmenopausal women, and a possible effect in preventing vertebral fractures. Combined vitamin D_3_ (700–800 IU/day) and calcium (1000 mg/day) may reduce the risk of hip and other non-vertebral fractures in individuals with low levels of intake. Supplementation with β-carotene increased lung cancer risk in persons with asbestos exposure or cigarette smoking.

The overall quality and quantity of the literature on the safety of multivitamin/mineral supplements is limited. Available data suggest multivitamin/mineral supplement use for 1 to 8 years is safe. Among the adverse effects reported in randomized controlled trials, a prominent one is yellowing of the skin among β-carotene supplementation. Vitamin A supplementation may moderately increase serum triglyceride levels. Calcium supplementation may increase the risk of kidney stones. Vitamin E supplementation was associated with an increased incidence of epistaxis but was not associated with an increased risk of more serious bleeding events.

## Future Research

In vitro studies and animal models have helped us to understand the function of nutrients under a controlled environment. However, these types of studies often have over-simplified the sophistication of the human body. There is a gap in our knowledge of how specific nutrients work in vivo to prevent disease. Future research should be directed toward filling the gap by developing valid in vivo biomarkers and applying them in the settings of randomized controlled trials to examine how nutrients influence the body's physiological function and pathological processes, and how nutrients work in concert to do so. Identifying an optimal dose in dose-response studies is critical to guide the design of future large-scale randomized controlled trials when the conduct of the trials is considered worthwhile.

Nutritional research has adopted a reductionist approach that emphasizes the role of individual nutrients in physiologic function or disease process. In view of the complex pathological processes of chronic diseases, the idea of using a single nutrient or a few nutrients to modify disease risk carries considerable optimism. The design and conduct of several large-scale randomized controlled trials on antioxidants was derived from epidemiological data that showed a lower risk of chronic disease (predominantly cancer and cardiovascular disease) in those who had higher circulating levels or dietary intake of some micronutrients. Because of residual confounding and measurement errors in dietary assessment, dietary data from observational studies can be better examined by patterns of food consumption with a multivariate approach, rather than by ranking of specific nutrient intake with a univariate approach.

We have found that many studies did not report study participants' self-selected supplement use before and during the trial participation, and allowed self-selected supplement use during the trial. Similarly, there was a lack of information on other variables that might have modified the effects of study supplements. Collective study findings also may not apply to every individual. Additional research should be done, particularly in existing randomized controlled trials, to examine how efficacy may vary by age, time since trial enrollment to diagnosis, self-selected supplement use, dietary patterns, disease history, medication use, and/or genetic polymorphisms.

With many food products being fortified with several nutrients, Americans' dietary intake of certain nutrients may well be above the RDAs. Hence, it is important to study the level of intake among consumers and assess how nutrient fortification may influence the public's health. An adverse event reporting system needs to be in place to facilitate this type of research.

For policy making, research should be conducted to estimate the cost-effectiveness and the risk/benefit profile of multivitamin/mineral supplement use or more generally, dietary supplement use, in the general population. Such research should also consider subpopulations for which these parameters may differ.

## Implications

The results of this systematic review have important implications for clinical practice and public health policy. When people ask about the need for multivitamin/mineral supplements, clinical practitioners should be aware that while multivitamin/mineral supplements are unlikely to have serious adverse effects, it remains unclear whether multivitamin/mineral supplementation is efficacious in preventing cancer, cardiovascular disease, or other major chronic diseases and conditions in the general United States adult population. Clinical practitioners may need to take into consideration other factors, such as nutritional status, when making recommendations about the need for multivitamin/mineral supplements. Forpublic health policy makers, our conclusion isthat evidence is insufficient to universally recommend or discourage routine use of multivitamin/mineral supplementsby adults in the general United States populationfor primary prevention of chronic disease