# Methods

The NIH Office of Medical Applications of Research (OMAR) requested an evidence report to review and synthesize the evidence on multivitamin/mineral supplements and prevention of chronic disease. Our Evidence-based Practice Center established a team and a work plan to develop the evidence report. The project consisted of recruiting technical experts, formulating and refining the specific questions, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence and submitting the report for peer review.

## Recruitment of Technical Experts and Peer Reviewers

At the beginning of the project, we recruited a panel of internal and external technical experts to give input on key steps including the selection and refinement of the questions to be examined. The panel included two internal technical experts from the Johns Hopkins University who have strong expertise in various aspects of the efficacy and/or safety of multivitamins/minerals and evidence-based medicine, and external experts who have strong expertise in nutritional research (see Appendix A ^a^). In addition to this panel of technical experts, we recruited a few additional experts to serve as peer reviewers of the evidence report, as described further in the section on Peer Review.

a Appendixes cited in this report are provided electronically at: http://www.ahrq.gov/clinic/tp/multivittp.htm

## Key Questions

We worked with the technical experts and representatives of OMAR and the Agency for Healthcare Research and Quality (AHRQ) to develop the Key Questions that are presented in the Specific Aims section of Chapter 1 (Introduction). We expanded the preliminary questions to include functionally related nutrient pairs, tuberculosis, hepatitis C, and pulmonary disease, and limited the questions involving efficacy to randomized controlled trials. The Key Questions focus on the efficacy of multivitamins/minerals (and specific single nutrients and functionally related pairs) in the prevention of chronic diseases and conditions as well as the safety of multivitamin/minerals and specific nutrients.

## Literature Search Methods

Searching the literature included the steps of identifying reference sources, formulating a search strategy for each source, and executing and documenting each search. Additionally, we searched for medical subject heading (MeSH) terms that were relevant to the specific nutrients and diseases specified in Key Question 1 to help develop the search strategy. We used a systematic approach for searching the literature to minimize the risk of bias in selecting articles for inclusion in the review. In this systematic approach, we had to be very specific about defining the eligibility criteria for inclusion in the review. The systematic approach was intended to help identify gaps in the published literature. We used a systematic approach for extracting data from the studies to minimize the risk of bias in how we extracted data from eligible studies. By creating standardized forms for data extraction, we sought to maximize consistency in identifying all pertinent data available for synthesis.

### Sources

Our comprehensive search plan included electronic and hand searching. Beginning in August of 2005 we ran searches of the following databases: MEDLINE^®^, EMBASE,^®^ and the Cochrane database including Cochrane Reviews and The Cochrane Central Register of Controlled Trials (CENTRAL). These searches were updated to include all articles published up until November 1, 2005. The FDA Adverse Event Reporting System (AERS) was researched. AERS covers drug adverse events and does not include reports on supplements. A similar reporting system exists for reporting adverse events associated with supplements; the Center for Food Safety and Applied Nutrition (CFSAN). CFSAN does not have a searchable database.

Hand searching for possibly relevant citations took several forms. Our experts identified 15 journals that were thought to be most likely to contain relevant studies (see Appendix B ^a^). We scanned the table of contents of each issue of these journals for relevant citations from January 2005 through February 2006. For the second form of hand searching, reviewers received eligible articles and flagged references of interest for the team to compare to the existing database. We used SRS^®^ 3.0 (TrialStat! Corporation, Ottawa, Ontario, Canada), a Web-based software package developed for systematic review data management, to track the article flagging.

### Search terms and strategies

Search strategies, specific to each database, were designed to enable the team to focus available resources on articles most likely to be relevant to the Key Questions, given that an enormous body of literature exists on vitamins and minerals. Initially, we developed a core strategy for MEDLINE, accessed via PubMed, based on an analysis of the MeSH terms and text words of key articles identified a priori. The PubMed strategy formed the basis for the strategies developed for the other electronic databases (see Appendix C ^a^).

### Organization and tracking of literature search

The results of the searches were downloaded and imported into ProCite^®^ version 5 (ISI ResearchSoft, Carlsbad, CA). From ProCite, the articles were uploaded to SRS 3.0. We used the duplication check feature in SRS 3.0. This feature allowed us to scan for exact article duplicates, author/title duplicates, and title duplicates. Additionally, this database was used to store citations in portable document format (PDF) and to track the search results at title review, abstract review, article inclusion/exclusion, and data abstraction levels (Figure 2). A list of excluded articles is presented in Appendix D ^a^

Figure 2. Summary of literature search and review process (number of articles )

## Title Review

After the electronic databases were searched, citations were downloaded into ProCite, and uploaded to the SRS 3.0 tracking system. The study team scanned all titles. Two independent reviewers conducted title scans in a parallel fashion. For a title to be eliminated at this level, both reviewers had to indicate that it was ineligible. If the two reviewers did not agree on the eligibility of an article, it was automatically promoted to the next level (see Appendix E ^a^, Title Review Form). The title review phase was designed to capture as many studies as possible reporting on the efficacy of single nutrients, related nutrient pairs, and multivitamins/minerals in the primary prevention of chronic diseases and conditions as well as the safety of multivitamins/minerals and a specified set of nutrients. All titles that were thought to address the above efficacy and or safety issues were promoted to the abstract review phase.

## Abstract Review

### Inclusion and exclusion criteria

The abstract review phase was designed to identify studies reporting on the efficacy of single nutrients, related nutrient pairs, and multivitamins/minerals in the primary prevention of chronic diseases and conditions as well as the safety of multivitamins/minerals and a specified set of nutrients. Investigators determined whether studies involving efficacy were randomized controlled trials and applied to primary prevention as previously defined in the Specific Aims section of Chapter 1. Investigators were instructed that articles relating to safety did not need to be randomized controlled trials. This review was primarily interested in safety studies on multivitamin/mineral supplements as well as a defined set of single nutrients for which reasonable concerns exist regarding potential adverse effects in the doses used. All articles with abstracts meeting these criteria were kept for further review. Abstracts were reviewed independently by two investigators, and were excluded if both investigators agreed that the article met one of the following exclusion criteria: (1) not written in English; (2) contained no human data; (3) included only pregnant women; (4) only infants; (5) only subjects of age less than or equal to 18 years (if a study included only subjects of age less than or equal to 18 years, we included it only if it presented data on the safety of a vitamin/mineral supplement) (6) included only patients with particular chronic diseases; (7) included only patients receiving treatment for chronic disease or included only patients in long-term care facilities; (8) only studied clinical nutritional deficiency; (9) contained no useful information applying to the Key Questions; (10) did not address the use of supplements; (11) did not address the use of supplements separately from dietary intake; (12) did not cover the defined disease endpoints or; (13) was an editorial, commentary, or letter. Additionally, an article could be excluded if it applied to Key Question 1 and/or 3 but was not a randomized controlled trial or a systematic review and did not address safety issues. (see Appendix E, Abstract Review Form). Differences in opinions regarding abstract inclusion or exclusion were resolved through consensus adjudication. At this level of inclusion/exclusion, the reviewers were also asked to identify which nutrient(s) each article addressed as well as the Key Questions the article might apply to if the article was eligible.

## Article Inclusion/Exclusion

Because of the broad array of potentially eligible articles obtained at the abstract review phase, full articles initially selected for review underwent another independent parallel review by investigators to determine if they should be included for full data abstraction. At this phase of review, investigators determined which of the Key Questions each article addressed, and what type of protocol was used in the study (see Appendix E, Article Inclusion/Exclusion Form). If articles were still deemed to have applicable information, they were included in the final article review. Differences in opinions regarding article inclusion or exclusion were resolved through consensus adjudication.

## Article Review/Data Abstraction

The purpose of the article review was to confirm the relevance of each article to the research questions, to determine methodological characteristics pertaining to study quality, and to collect evidence that addressed the research questions. Articles eligible for full review could address one or more of the Key Questions. If reviewers determined that an article addressed both efficacy and safety, multiple data abstraction forms were used. We used a systematic approach for extracting data from the studies to minimize the risk of bias in how we extracted data from eligible studies. By creating standardized forms for data extraction, we sought to maximize consistency in identifying all pertinent data available for synthesis.

Each article underwent double review by study investigators for full data abstraction and assessment of study quality. For all data abstracted from studies, we used a sequential review process. In this process, the primary reviewers completed all data abstraction forms. The second reviewer confirmed the first reviewer's data abstraction forms for completeness and accuracy. Reviewer pairs were formed to include personnel with both clinical and methodological expertise. A third reviewer re-reviewed a random sample of articles marked as “ineligible” by the first two reviewers to ensure consistency in the classification of the articles. Reviewers were not masked to the articles' authors, institution, or journal. In most instances, data were directly abstracted from the article. If possible, relevant data were also abstracted from figures. Differences in opinion were resolved through consensus adjudication. For assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms. (see Appendix E, Data Abstraction Review Forms)

For all articles containing original data, reviewers extracted information on general study characteristics such as study design, study period and follow up, study participants, sample size, and prior supplement use (see Appendix E, Data Abstraction Review Forms). Data abstracted to the “Arm” forms (see Appendix E, Data Abstraction Review Forms) included: placebo or intervention; nutrients studied; chemical form; dose; units; frequency of use; timing of use; and duration of use.

For studies addressing efficacy (Key Question 1 and/or 3), an outcomes form for efficacy (see Appendix E, Data Abstraction Review Forms) was filled out to obtain the information on study outcomes and adverse effects, and the results from subgroup analyses. Additionally, a specific study quality form was filled out (quality forms were filled out independently) to assess: representativeness of the study population; bias and confounding; description of study supplements/supplementation; adherence and completeness of follow up; statistical analysis; and conflict of interest (see Appendix E, Data Abstraction Review Forms).

Reviewers used an outcomes form to abstract data from articles addressing safety (Key Questions 2 and/or 4) on adverse effects/events and criteria for causality (see Appendix E, Data Abstraction Review Forms).

We also abstracted data from systematic reviews that specifically applied to our Key Questions. This included systematic reviews of calcium and/or vitamin D only, and reviews of studies other than calcium and/or vitamin D only (see Appendix E, Data Abstraction Review Forms).

All information from the article review process was entered into the TrialStat database by the individual completing the review. Reviewers entered comments into the system whenever applicable. The TrialStat database was used to maintain and clean the data, as well as to create detailed evidence tables and summary tables (see Appendix F and Summary Tables).

### Data abstracted to assess the efficacy of multivitamin/mineral supplements and single nutrients (and related pairs of nutrients) in the primary prevention of chronic diseases/conditions (Key Questions 1 and 3)

Articles were reviewed to obtain information on (1) study characteristics, (2) study participants, (3) study supplements, and (4) study results. Specific abstracted data on study characteristics were: study name and abbreviation (if available), types of study design, study period, chronological follow up period, median/mean follow up duration, eligibility criteria for trial enrollment, sample size, study site, and recruitment setting. The inclusion of the item on recruitment setting was intended to capture the source population from which the study population was established. Specific abstracted data on participants' characteristics were: age, sex, race, smoking, alcohol, and body mass index (BMI). These factors were considered by the team members to be important confounding variables. Other characteristics reported in the article were also abstracted. Specific abstracted data on study supplements were: control (placebo, no dietary supplements or no standard care, standard care, nutritional/dietary education) and intervention arms (list of nutrients). The chemical form, total dose per ingestion, dose unit, and frequency, timing and duration of use of study supplements were abstracted. For clinical endpoints, data abstracted were: outcome measures, number of events, person years, incidence rates, and estimates of efficacy (relative risk, odds ratio, hazard ratio) along with the corresponding 95% confidence intervals. For biomarker endpoints such as bone mineral density, central and dispersion statistics of the biomarker measurements were abstracted.

### Data abstracted to assess the safety of multivitamins/minerals and single nutrients (selenium, iron, β-carotene, vitamin A, vitamin E, folic acid, and calcium (with or without vitamin D)) (Key Questions 2 and 4)

Articles with safety data were reviewed to obtain information on (1) study characteristics, (2) study participants, (3) randomized groups, and (4) study results. Specific abstracted data on study characteristics, study participants and study supplements were the same as those for Key Questions 1 and 3. Specific abstracted data on study results were: the types of adverse effects/events, whether the adverse effects/events occurred, numbers of adverse events, and estimates of associations along with the corresponding 95% confidence intervals. For biomarker endpoints, central and dispersion statistics of the biomarker measurements were abstracted. Plausibility of causality was considered using the following criteria: temporal relationship, lack of alternative causes, dose-response, relationship, evidence of increased circulating levels of the nutrient under investigation, and response to re-challenge.

### Data abstracted from previous systematic reviews on vitamin D and calcium

Several systematic reviews have been published to address the efficacy of vitamin D and/or calcium in the prevention of bone loss, osteoporosis and fractures. The most recent review article was published in 2005. In addition, the University of Ottawa Evidence-based Practice Center will soon release a systematic review that focuses on vitamin D, including the effect of supplemental doses of vitamin D on bone density and fracture and fall risk. Since the studies on vitamin D and/or calcium have been reviewed so recently, we reviewed the available systematic reviews on this subject. Data from systematic review articles were abstracted regarding: (1) the aim of the review, (2) exclusion criteria, (3) search strategies (databases, search terms), (4) range of publication dates of reviewed articles, (5) number of trials in the review, (6) total numbers of trial participants in vitamin D and/or calcium group and in the placebo groups, (7) range of follow up periods, (8) range of proportions of participants lost to follow up, (9) trial participants' characteristics (age, women, race/ethnicity groups), (10) inclusion of primary prevention trials alone or a mixture of primary and secondary prevention trials, (11) chemical forms of vitamin D and calcium, and (12) aggregate results of bone mineral density/content.

### Data abstracted from previous systematic reviews on nutrients other than vitamin D and calcium

We also abstracted the following data from published systematic reviews on nutrients other than vitamin D and calcium: (1) the aim of the review, (2) exclusion criteria, (3) search strategies (databases, search terms), (4) range of publication dates of reviewed articles, (5) number of trials in the review, (6) total numbers of trial participants in vitamin/mineral group and in the placebo groups, (7) range of follow up periods, (8) range of proportions of participants lost to follow up, (9) trial participants' characteristics (age, women, race/ethnicity groups), (10) inclusion of primary prevention trials alone or a mixture of primary and secondary prevention trials, (11) chemical forms of nutrients included in the review, and (12) aggregate estimates of efficacy along with the corresponding 95% confidence intervals and p-values. Efforts were made to abstract data from primary prevention trials included in systematic reviews that reviewed evidence from both primary and secondary prevention trials.

## Quality Assessment

Article quality was assessed differently for different types of studies: efficacy studies (randomized controlled trials only); safety studies; and systematic reviews. The dual, independent review of article quality judged articles on several aspects of each study type's external and internal validity. Quality assessment of studies addressing efficacy included: (1) the representativeness of the study population (description of the study population and where it was drawn, and how well the participants' characteristics were described); (2) bias and confounding (whether this was controlled for in the study design and reported on in the study); (3) description of supplements/supplementation; (4) description of adherence to study protocols and follow up (flow of patients through the study over time, loss to follow up, and participant withdrawal); (5) statistical analysis; and (6) conflict of interest.

Quality assessment of studies addressing safety considered: (1) temporal relationships between timing of supplement use and adverse events (how this was reported); (2) dose-response relationship; (3) whether adverse effects disappeared after supplement use ceased; (4) serum levels of supplements; (5) whether an alternative cause for the adverse event was investigated: and (6) whether the adverse event re-occurred if the supplement was used again.

The quality of each systematic review was assessed using a different set of criteria: (1) whether the question being addressed by the review was clearly stated; (2) comprehensiveness of search methods used and described in the report; (3) whether inclusion/exclusion criteria were clearly defined and appropriate; (4) whether analyses were conducted to measure variability in efficacy; (5) whether study quality was assessed and done appropriately (using validated instruments); (6) whether differences in how outcomes were reported and analyzed across studies were taken into consideration; (7) whether the study methodology was reproducible; and (8) whether conclusions were supported by the data presented.

For each study, we assigned a rating of high, medium or low quality for each domain of study quality based on whether the score for that domain was designated High (80–100%), Medium (50–79%), or Low (0–49%) quality.

## Data Synthesis

For each Key Question, we created a set of detailed evidence tables containing all information extracted from eligible studies. The investigators reviewed the tables and eliminated items that were rarely reported. Investigators used the resulting versions of the evidence tables to prepare the text of the report and selected summary tables.

## Data Entry and Quality Control

Initial data were abstracted by investigators and entered directly into Web-based data collection forms using; SRS^®^ 3.0 (TrialStat! Corporation, Ottawa, Ontario, Canada). After a second reviewer reviewed data, adjudicated data were re-entered into Web-based data collection forms by the second reviewer. Second reviewers were generally more experienced members of the research team, and one of their main priorities was to check the quality and consistency of the first reviewers' answers. In addition to the second reviewers checking the consistency and accuracy of the first reviewers, a senior investigator examined all reviews to identify problems with the data abstraction. If problems were recognized in a reviewer's data abstraction, the problems were discussed at a meeting with the reviewers. In addition, research assistants used a system of random data checks to assure data abstraction accuracy.

## Grading of the Evidence

At the completion of our review, we graded the quantity, quality and consistency of the best available evidence addressing Key Questions 1 and 3 by adapting an evidence grading scheme recommended by the GRADE Working Group.^63^ We applied evidence grades to bodies of evidence on each type of nutrient for each major type of outcome. We considered the strength of the study designs with randomized controlled trials considered best, followed by non-randomized controlled trials, observational studies, and case reports. We considered at least two randomized controlled trials reporting on a specific outcome to constitute a body of evidence pertaining to that outcome. If an outcome was evaluated by at least two randomized controlled trials as well as observational studies and case reports, our evidence grade was based only on the randomized controlled trials evaluating that outcome. If an outcome was evaluated by one or no randomized controlled trials, our evidence grade was based on the single randomized controlled trial in addition to the best available non-randomized controlled trial or the best available observational studies (cohort studies considered best, followed by cross-sectional studies and studies with pre-post observational design). We reported the number of studies within the category of best available evidence to assess the quantity of evidence. We also assessed the quality and consistency of the best available evidence, including assessment of limitations to individual study quality (using individual quality scores), certainty regarding the directness of the observed effects in studies, precision and strength of findings, and availability (or lack thereof) of data to answer the Key Question. We classified evidence bodies pertaining to each Key Question into four basic categories: (1) “high” grade (indicating confidence that further research is very unlikely to change our confidence in the estimated effect in the abstracted literature); (2) “moderate” grade (indicating that further research is likely to have an important impact on our confidence in the estimates of effects and may change the estimates in the abstracted literature); (3) “low” grade (indicating further research is very likely to have an important impact on confidence in the estimates of effects and is likely to change the estimates in the abstracted literature); and 4) “very low” grade (indicating any estimate of effect is very uncertain).

## Peer Review

Throughout the project, feedback was sought from the technical experts through ad hoc and formal requests for guidance. A draft of the completed report was sent to the technical experts and peer reviewers, as well as to the representatives of the NIH and AHRQ. In response to the comments of the technical experts and peer reviewers, revisions were made to the evidence report, and a summary of the comments and their disposition has been submitted to AHRQ.