# Introduction

## Purpose

Multivitamin/mineral supplements are the most commonly used nutritional supplements in the United States.^1^ Scientific evidence on the efficacy and safety of supplement use will serve as the basis for us to identify knowledge gaps and inform the general public's practice and future research. This report synthesizes the published literature on the efficacy and the safety of multivitamin/mineral supplements in the prevention of chronic disease for the general population of adults, and on the efficacy and the safety of certain commonly-used single vitamin or mineral supplements in the general population of adults and children. The content of this report will be used by the National Institutes of Health (NIH) in preparing a State-of-the-Science Statement for health care providers and the general public.

## Specific Aims

The specific aims of this review are to synthesize evidence in the literature for addressing the following Key Questions:

1 What is the efficacy determined in randomized controlled trials of multivitamin/mineral supplements (defined as 3 or more vitamins and/or minerals without herbs, hormones, or drugs), each at a dose less than the tolerable upper intake level (UL) determined by the Food and Nutrition Board, in the general adult population^*^ for prevention^†^ against the development of one or more of the following chronic diseases or conditions^‡^?
  * General population is defined as community-dwelling individuals who do not have special nutritional need such as those who are institutionalized, hospitalized, pregnant or clinically deficient in nutrients."
  † This review focused on primary prevention using the following definition as a guide. Primary prevention denotes an action taken to prevent the development of a disease in a person who is well and does not have the disease in question.^185^ Using this definition, we included studies of supplements that were used in patients with risk factors for disease (e.g., type 2 diabetes mellitus or hypertension) to prevent one or more of the listed chronic diseases or conditions (e.g., cardiovascular disease). We also included studies of supplements that were used in patients with selected precursors of disease (e.g., polyps) to prevent a malignant disorder (e.g., colon cancer). We did not include studies of supplements that were used in patients with carcinoma-in-situ or similar malignant conditions.
  a Oncologic: breast cancer, colorectal cancer, lung cancer, prostate cancer, gastric cancer, or any other malignancy (including colorectal polyps)
  b Cardiovascular: myocardial infarction, stroke
  c Endocrine: type 2 diabetes mellitus
  d Neurologic: Parkinson's disease, cognitive decline, memory loss, dementia
  e Age-related sensory loss: cataracts, macular degeneration, hearing loss
  f Musculoskeletal: osteoporosis, osteopenia, rheumatoid arthritis, osteoarthritis
  g Gastroenterologic: non-alcoholic steatorrheic hepatitis, non-alcoholic fatty-liver disease
  h Renal: chronic renal insufficiency, chronic nephrolithiasis
  i Infectious: HIV infection, hepatitis C, tuberculosis
  j Pulmonary: chronic obstructive pulmonary disease
2 What is known about the safety of use of multivitamin/mineral supplements (as defined in question 1) in the general population of adults and children, based primarily on data from randomized controlled trials and observational studies?
3 What is the efficacy determined in randomized controlled trials of supplementation with the single nutrients or functionally related nutrient pairs listed below, each at a dose less than the UL determined by the Food and Nutrition Board, in the general adult population for prevention against the development of one or more of the chronic diseases or conditions listed above for question 1?
  a calcium
  b folic acid
  c vitamin B6
  d vitamin B12
  e vitamin D
  f vitamin E
  g vitamin C
  h vitamin A
  i iron
  j zinc
  k magnesium
  l vitamin B1
  m vitamin B2
  n niacin
  o calcium/vitamin D
  p calcium/magnesium
  q folic acid/vitamin B12
  r folic acid/vitamin B6
4 What is known about the safety of use of the following single nutrients in the general population of adults and children, based primarily on data from randomized controlled trials and observational studies?
  a calcium (with or without vitamin D)
  b folic acid
  c vitamin D
  d vitamin E
  e vitamin A
  f iron
  g selenium
  h β-carotene

## Use of Multivitamin/mineral Supplements in the United States

Multivitamins are the most commonly used dietary supplements in the United States.^1^ Multivitamin/mineral pills typically include at least 10 vitamins, and 10 minerals. They generally contain 100 percent of the Recommended Daily Allowance (RDA) for those micronutrients for which there are recommendations, except for calcium and certain other minerals, which are too bulky to include more than a fraction of the RDA. Recently, variation in the formulation of multivitamin/mineral supplements has occurred. Many of these supplements contain two to six times the RDA. Often, formulations of B vitamins are 10 to 20 times the RDA. According to the National Health and Nutrition Examination Survey (NHANES) 1999-2000, 35 percent of adults reported use of multivitamin/mineral supplements in the month prior to the survey.^1^ Commercials have widely promoted dietary supplements. In 2005, 20.3 billion dollars were spent on purchases of dietary supplements in the United States.^2^ Many individuals use vitamins/minerals supplements for prophylactic or disease-mitigating purposes. Whether long-term use is efficacious and safe warrants rigorous scientific evaluation.

## Chronic Disease

Chronic disease is estimated to account for 35 million deaths worldwide.^3^ Cardiovascular disease and cancer comprise a major proportion of chronic diseases in both developed and developing countries.^4^ Other than cardiovascular disease and cancer, obesity-related diseases such as type 2 diabetes, end-stage renal disease, osteoarthritis and non-alcoholic steatorrheic hepatitis are also becoming significant public health problems.^5,^ ^6^ The prevalence and incidence of these diseases may rapidly increase in the near future in the United States because the prevalence of obesity has increased from 23 percent to 30 percent during the 1990s.^7^ At the same time, the population is gradually aging, and age-related degenerative diseases/conditions claim enormous health and economic tolls. Age-related cataract is the leading cause of blindness, accounting for about 42 percent of all blindness globally.^8^ Approximately one in five people over age 65 live with age-related macular degeneration, and adults with advanced macular degeneration have a markedly reduced quality of life and need for assistance with activities of daily living.^9^ The incidence of dementia also increases exponentially with age.^10^ Alzheimer disease accounts for more than half of dementia cases.^11^

## Common Pathologic Mechanisms of Chronic Diseases

The etiology of most chronic diseases is multifaceted. However, many chronic diseases share common risk factors and underlying pathologic mechanisms. Cigarette smoking/tobacco use, sedentary lifestyle, unhealthy (high calorie, low fruit/vegetable intake) diet, and obesity are well established as major risk factors of several chronic diseases. Cigarette smoke is a rich source of oxidants (free radicals and reactive oxygen, nitrogen and chlorine species), whereas a diet low in fruits and vegetables contains a low amount of antioxidants. Substantial evidence from in vitro experiments, animal models and epidemiological observational studies suggests that oxidative stress, a result of an imbalance between oxidative and reductive potential in favor of the former, may play an important role in the initiation, promotion, and progression of cardiovascular disease (in particular, ischemic heart disease and stroke), cancer, and several degenerative diseases/conditions, such as age-related cataract, age-related macular degeneration and cognitive decline.^12^–^19^ Oxidative damage to lipids by free radicals initiates and propagates chain reactions that may be intercepted by antioxidants or otherwise lead to development of atherosclerosis and mutagenesis.^12,^ ^20^ Oxidative damage to DNA causes formation of DNA adducts, double strand breaks, single strand breaks, aberrations and instability of chromosomes, and genomic instability, all of which may result in mutagenesis and carcinogenesis.^21^ Oxidative damage to proteins may affect enzyme expression and impair critical cellular signaling, leading to alterations in cell function.^22^

It is well known that sedentary lifestyle, excessive caloric intake, and lack of physical activities lead to obesity, and obese individuals have higher levels of inflammation, a key process of host responses to infections and an important risk factor of cardiovascular disease and many cancers and chronic conditions.^23,^ ^24^ Inflammatory responses can induce the generation of free radicals and reactive species that cause oxidative stress and further exacerbate disease processes.^25^

In addition to oxidative damage and inflammation, one-carbon metabolism has been implicated to be important in several chronic diseases, particularly cardiovascular disease, renal failure, neurological dysfunction, and cancer. An important step in one-carbon metabolism is the synthesis/metabolism of methionine. Methionine is a precursor of S-adenosylmethionine (SAM), a universal methyl donor to DNA, RNA, protein, phospholipids, neurotransmitters and hormones. Hypermethylation in the promoter regions of tumor suppressor genes and chromosome aberrations due to global hypomethylation may lead to oncogenesis.^26,^ ^27^ In methionine synthesis, an intermediate molecule is homocysteine, which has been found to be associated with increased risk of coronary artery disease, stroke, peripheral vascular disease, cognitive impairment, dementia, depression, osteoporotic fractures, and functional decline.^28^

Other pathways by which chronic disease develops may or may not be modifiable by vitamins/minerals. Examples of these factors include but are not limited to genetic susceptibility, growth factors, and capacity of detoxification.

## Possible Mechanisms of Action of Vitamins and Minerals in Chronic Disease Prevention

Multivitamin/mineral supplements often contain vitamin A, β-carotene, vitamin B1 (thiamine), vitamin B2 (riboflavin), vitamin B6 (pyridoxine), vitamin B12 (cyanocobalamin), vitamin C, vitamin D, vitamin E, folic acid, niacin, calcium, iron, zinc, magnesium, and selenium. These nutrients have numerous biological effects and have garnered considerable research interest in their potential as chemo-preventive agents for the prevention of chronic disease.

As described previously, a common process of chronic disease is oxidative damage by free radicals or reactive species. Multiple systems work in concert to protect the human body from oxidative damage. Endogenous enzymatic antioxidants, such as copper- and zinc-, or manganese-containing superoxide dismutase, selenium-dependent glutathione peroxidase, and catalase, can catalyze radical- and peroxide-quenching reactions. Nonenzymatic antioxidants include but are not limited to vitamin C, vitamin E, bilirubin, urate, flavanoids, and certain carotenoids (e.g., β-carotene and lycopene). In addition, metal-binding proteins can quench iron and copper ions which, if free, can catalyze oxidative reactions.^29^

Folate, vitamin B6, and vitamin B12 influence methylation by supplying methyl groups and are essential for nucleotide synthesis, DNA synthesis, and DNA repair.^30^ Folate and B vitamins maintain normal brain function through the methylation of neurotransmitters, phospholipids and myelin.^31^ They are also essential in homocysteine metabolism because irreversible transsulfuration and the re-methylation of homocysteine rely on coenzymes derived from vitamin B6, vitamin B12, and folate. A previous meta-analysis indicated that daily supplementation with folic acid of 0.5–5 mg and vitamin B12 of approximately 0.5 mg would reduce blood homocysteine concentrations by up to one-third, whereas vitamin B6 did not have a significant additional effect.^32^ However, whether a reduction in homocysteine leads to decreased risk for clinical outcomes awaits evidence from randomized controlled trials.

In addition to anti-oxidation and regulation of methylation, vitamins and minerals may have inhibitory effects on inflammation (γ-tocopherol, zinc, and vitamin A) and angiogenesis (α-tocopherol, vitamin A, vitamin C, vitamin D). Some may also regulate cell differentiation, proliferation, and apoptosis (vitamin A, α-tocopherol, vitamin D, calcium) and enhance immunity (vitamin A, zinc, vitamin E, vitamin C, calcium).^33^–^40^ Vitamin C may be useful in the prevention or management of osteoarthritis through collagen synthesis,^41^ and vitamin D may prevent the progression of osteoarthritis by impairing bone's response to the pathophysiological process of the disease.^42^ Magnesium and calcium are important in regulating blood pressure.^43,^ ^44^ Calcium may also have beneficial effects on cholesterol levels and body weight, and may shield the contact of carcinogen with bowel mucosa by forming insoluble chemical complexes with bile acid and fat.^45,^ ^46^ Several meta-analyses have addressed the effects of calcium and/or vitamin D supplementation on bone density, osteoporosis, fractures, and falls.^47^–^52^ The evidence has led the Food and Drug Administration (FDA) to authorize health claims in the labeling of calcium supplements for the benefits in osteoporosis prevention. The 2004 United States Surgeon General's Report on Bone Health and Osteoporosis has clearly stated the importance of calcium and vitamin D in maintaining healthy bones and preventing osteoporosis.^53^ However, intake of vitamin D and calcium from food source has been generally inadequate in American adults; only 4 percent of individuals of age greater than 51 years meet the Adequate Intake level of vitamin D,^54^ and the average calcium intake in American adults was estimated to be 761mg per day, below the Recommended Dietary Allowance for adults (1,000–1,200 mg).^55^

## Factors that Affect the Efficacy and Safety of Vitamin/mineral Supplement Use in Chronic Disease Prevention

Perturbation of metabolism and other physiologic function often occurs in persons with established chronic disease. Accordingly, evaluation of the efficacy and safety of multivitamin/mineral supplement use should be made separately for primary versus secondary prevention. In addition to individuals' health status, several factors may affect the efficacy and the safety of vitamin and/or mineral supplement use in chronic disease prevention, such as individuals' nutritional status, bioavailability of nutrients, nutrient-nutrient interaction, chemical forms and doses of supplements, timing and duration of supplement use, among others.

Age, sex, race, genetic susceptibility, geographic location, smoking, diet, physical activity, obesity, and sunlight exposure are important factors because they affect individuals' baseline nutritional levels and may modify the efficacy and safety of supplement use. Geographical location is also relevant because dietary intake of selenium depends on the selenium content of the soil where plants are grown or animals are raised. In addition, ecological studies have linked areas with increased selenium levels to lower rates of lung, colorectal, bladder, esophageal, pancreas, breast, ovarian, and cervical cancers.^56^

After a nutrient is ingested, its biological effects are heavily determined by the bioavailability, i.e., the absorbable fraction that affects the biological effects of the nutrient by modulating the amount of the nutrient entering the body. Key factors determining the bioavailability of a micronutrient are the chemical form in which the nutrient is presented to the intestinal absorptive surface, the presence of other competing chemicals the concentration of food constituents (such as phytates and other chelating agents) that bind to the nutrient and make it unavailable for absorption, intestinal transit time, and enzyme activity. For example, synthetic vitamin E has approximately 50 percent the bioavailability of natural vitamin E, and use of α-tocopherol can reduce the bioavailability of other forms of vitamin E,^57^ after competing for the uptake into very low-density lipoproteins (VLDL) by α-tocopherol transfer protein in the liver. Hence, factors influencing the bioavailability of a nutrient are important to consider when assessing the effects of multiple micronutrient preparations.

One nutrient may affect the absorption, transport, tissue uptake, function and metabolism of other nutrients. Accordingly, the concurrent ingestion of several nutrients may result in synergistic, antagonistic, or threshold effects as compared to a single nutrient. Hence, the efficacy of a single nutrient vs. multiple nutrients should be considered separately unless no interactive or threshold effects can be found. Examples of nutrient-nutrient interactions include vitamin B12 and selenium modification of host's responses to inadequate dietary intake of folic acid. An excessive intake of folic acid may obscure vitamin B12 deficiency.^58^ Zinc regulates the absorption, transport and utilization of vitamin A.^59^ Calcium and vitamin D are inter-related metabolically in bone and intestine.

The chemical form of a nutrient may also determine its effects. For example, rather than an antioxidant effect, α-tocopheryl succinate has anti-proliferative effects in in vitro settings. Doses of supplements and duration of use are directly relevant to the efficacy, particularly for lipid soluble vitamins that can be accumulated in the tissue for a long-term.

## The Tolerable Upper Intake Levels of Daily Nutrient Intake

The United States Food and Nutrition Board established tolerable ULs for several nutrients. By definition, a UL is the highest level of daily nutrient intake that is likely to pose no risk of adverse health effects to almost all individuals in the general population.^60^ A UL is determined by the following steps: (1) hazard identification based on in vitro experiments, animal studies, and/or human studies, (2) dose-response assessment to identify the no-observed-adverse-effect level (NOAEL) or lowest-observed-adverse- effect level (LOAEL), which is then weighed with an uncertainty factor (UF) to derive the UL. In the case where toxicity data are unavailable from children, an extrapolation from the ULs determined for adults is made based on body weight difference. The strength of the evidence for determining a UF varies and therefore the choice of a UF has leeway of subjectivity. The UL of vitamin E for adults is determined primarily based upon its hemorrhagic effects in rats.^60^ The UL of iron, zinc, and selenium was determined based on gastrointestinal symptoms, reduced copper status, and hair and nail brittleness and loss, respectively.^60^ Since the time when ULs were determined, several large-scale randomized controlled trials of vitamin/mineral supplementation have been completed. An update on the data regarding adverse effects will help to evaluate the appropriateness of ULs.

## Federal Regulation of Vitamin/mineral Supplements

The United States FDA regulates dietary supplements under the Dietary Supplement Health and Education Act (DSHEA) of 1994 which states that supplements containing ingredients marketed prior to the enactment of DSHEA are not subject to pre-market burden on proof of safety. Many vitamins and minerals, such as vitamin A, vitamin B, vitamin C, vitamin D, vitamin E, calcium, and magnesium, with established nutritional function, fall into this category and have been grandfathered as Generally Recognized As Safe (GRAS).^61,^ ^62^ However, the determination of GRAS was primarily based on experts' opinions or a history of safe use before January 01, 1958 when the Food Additives Amendment to Food, Drug, and Cosmetic Act was enacted. A lack of high-quality data before 1958 is conceivable when an adverse event reporting system was not in place.

## Conceptual Framework

Figure 1 demonstrates the conceptual framework used to guide this systematic review, focusing on primary prevention of chronic disease. Chronic disease endpoints are the outcomes of interest. A biomarker endpoint is considered if the biomarker is a marker of disease progression or the biomarker is reported as an adverse effect of supplement use. Bone mineral density, cognitive function, and fasting glucose were considered as biomarker endpoints for efficacy in this review. The framework acknowledges that vitamin and mineral supplements have many biologic effects that could help to prevent chronic disease outcomes. The framework also acknowledges potential adverse effects of vitamin and mineral supplements.

Figure 1. Conceptual framework for the prevention of chronic diseases and conditions with vitamin/mineral supplements (circled numbers represent the key questions addressed in this systematic review)