# Appendix G: List of Acronyms

AERS | Adverse Event Reporting System
AHRQ | Agency for Healthcare Research and Quality
AMD | Age-related macular degeneration
AREDS | Age-Related Eye Disease Study
ATBC | Alpha-Tocopherol Beta-Carotene Cancer Prevention
BCC | Basal cell carcinomas
BMD | Bone mineral density
BMI | Body mass index
CARET | Beta-Carotene and Retinol Efficacy Trial
CENTRAL | The Cochrane Central Register of Controlled Trials
CFSAN | Center for Food Safety and Applied Nutrition
CI | Confidence interval
DRI | Dietary reference intake
DSHEA | Dietary Supplement Health and Education Act
EPC | Evidence-based Practice Center
FDA | Food and Drug Administration
GRAS | Generally Recognized As Safe
HR | Hazard ratio
IPO | Percentage pixel opaque
LOAEL | Lowest-observed-adverse- effect level
LOCS II | Lens Opacities Classification System
MeSH | Medical Subject Heading
MONMD | Multi-center Ophthalmic and Nutritional Eye-Related Macular Degeneration Study
NCSP | Nambour Skin Cancer Prevention Trial
NHANES | National Health and Nutrition Examination Survey
NIH | National Institutes of Health
NOAEL | No-observed-adverse-effect level
NPC | Nutritional Prevention of Cancer
OMAR | Office of Medical Applications of Research
OR | Odds ratio
PDF | Portable document format
PHS | Physician's Health Study
PPP | Primary Prevention Project
RDA | Recommended daily allowance
RE | Retinol equivalent
REACT | Roche European American Cataract Trial
RR | Relative risk
SAM | S-adenosylmethionine
SCC | Squamous cell carcinoma
SCP | Skin Cancer Prevention Study
SELECT | Selenium and Vitamin E Cancer Prevention Trial
SU.VI.MAX | Supplementation en Vitamines et Mineraux Antioxydants
UF | Uncertainty factor
UL | Tolerable upper level intake
VECAT | Vitamin E, Cataract, and Age-Related Maculopathy Trial
VLDL | Very low density lipoprotiens
WHI | Women's Health Initiative study
WHS | Women's Health Study