# Appendix F: Evidence Tables

Evidence Table 1a. Characteristics of the studies on the efficacy of multivitamins in preventing chronic disease

Study name | Nutrient(s) | Study design | Study period | Exclusion criteria | Total sample size enrolled | Mean/ median follow-up time | Study site | Recruitment setting
Linxian General Population Trial ^64,66^ | Groups of placebo, AB, AC, AD, BC, BD, CD, ABCD where | RCT; Factorial design | 1986-1991 | Not 40–69; history of stomach or esophageal cancer; debilitating disease; does not live in one of 4 communes in Linxian | 29584 | 5.25 years (total) | Linxian province, China | Community
| A: Retinol palmitate 10000 IU + Zinc oxide 45 mg,
| B: Riboflavin 5.2 mg + Niacin 40 mg,
| C: Ascorbic acid 180 mg + Molybdenum Yeast complex 30 μg,
| D: Beta-carotene 15 mg + Selenium yeast 50 μg + alpha-tocopherol 60 mg
Wang, 1994^68^ | | | | Not 40–69; history of cancer; did not live in one of two villages in Rencun commune; did not complete 1st (1987) and end-of-trial (2nd 1991) cytology exam. | 391 (in 1991)
Linxian cataract Study ^65^ | Groups of placebo, AB, AC, AD, BC, BD, CD, ABCD where | RCT; Factorial design | 1985-1991 | Not 40–69; cancer; did not live in Linxian province. | 5390 | 6 years (total) | Linxian province, China | Community
| A: Retinol palmitate 10000 IU + Zinc oxide 45 mg,
| B: Riboflavin 5.2 mg + Niacin 40 mg,
| C: Ascorbic acid 180 mg + Molybdenum Yeast complex 30 μg,
| D: Beta-carotene 15 mg + Selenium yeast 50 μg + alpha-tocopherol 60 mg
SU.VI.MAX ^69,70^ | Vitamin C+ vitamin E+ beta carotene+ selenium+ zinc. | RCT; placebo controlled | 1994-2002 ^69^ | Disease was expected to hinder participation or threaten 5-year survival; participant was taking any supplement offered in this study; participant had extreme beliefs or behavior regarding diet. | 12741 | 8 years (total), 7.5 years (median). | France | Community
| | | 1994-1995 ^70^ | Not 45–60 years old; female; cancer; not free of “severe health problems”; any use study supplements. | 5141 (males) | 8.9 years (median) | France | Community
REACT ^72^ | Beta-carotene + vitamin C+ vitamin E. | RCT; placebo controlled | 1990-1995 | History of iritis or amblyopia; glaucoma or elevated intraocular pressure; ocular corticosteroid use or glaucoma therapy; participation in other anti-cataract trial within last year; regular use of antioxidants. | 297 | 3 years (total), 2.8 years (mean). | Boston, USA; Oxford and Bradford, UK. | Clinical: outpatient eye clinic
ARED ^73,75^ | Beta-carotene+ vitamin C+ vitamin E. | RCT; placebo controlled | 1992-2001 | History of cancer with a poor 7-year prognosis; major cardiovascular or cerebrovascular event within the last year; hemachromatosis; persons bilaterally aphakic or pseudophakic were ineligible for AMD Category 1. | 4596 ^75^ | 9 years (total), 6.3 years (mean). | USA (multiple centers) | Clinical and community
| | | | | 3509 ^73^
ARMD ^74^ | Beta-carotene; vitamin E; vitamin C; citrus bioflavenoid complex; quercitin; rutin; zinc; selenium; taurine; N-acetyl cysteine; glutathione; vitamin B2; chromium. | RCT; Placebo controlled | NR | Did not have a one-time decrease of visual acuity not attributable to cataract, amblyopia, systemic or ophthalmic disease; eye findings not consistent with loss of macular reflex; former prisoner of war; chronic alcoholic with tobacco/nutritional amblyopia or gastrointestinal absorption disorder. | 71 | 3 years (total) | USA (multiple centers) | Clinical
MONMD ^71^ | Beta-carotene; vitamin E; vitamin C; citrus bioflavenoid complex; quercitin; rutin; zinc; selenium; taurine; N-acetyl cysteine; glutathione; vitamin B2; chromium. | RCT; Placebo controlled | NR | Did not have a one-time decrease of visual acuity not attributable to cataract, amblyopia, systemic or ophthalmic disease; eye findings not consistent with loss of macular reflex; former prisoner of war; chronic alcoholic with tobacco/nutritional amblyopia or gastrointestinal absorption disorder; prior use vitamins >1 year. | 84 | 3 years (total) | USA (multiple centers) | Clinical

SU.VI.MAX. (SUppléments en VItamines et Minéraux AntioXydants); REACT (Roche European American Cataract Trial); AREDS (Age-Related Eye Disease Study); ARMD (Age-Related Macular Degeneration).

Evidence Table 1b. Characteristics of the intervention in the studies of the efficacy of multivitamins/minerals in the prevention of chronic disease

Study name | Intervention | Chemical form | Dose/Frequency of use | Timing of use | Duration of use
Linxiana General Population study ^66^ | Placebo | | | NS | 5 years
| Vitamin A | Retinol palmitate | 10000 IU/NS
| Zinc | Zinc oxide | 45 mg/NS
| Vitamin B2 | Riboflavin | 5.2 mg/NS
| Niacin | Niacin | 40 mg/NS
| Vitamin C | Ascorbic acid | 180 mg/NS
| Molybdenum | Yeast complex | 30 μg/NS
| Beta-carotene | NS | 15 mg/NS
| Selenium | Selenium yeast | 50 μg/NS
| Vitamin E | alpha-tocopherol | 60 mg/NS
Linxian General Population Study ^64^ | Placebo | | NS | NS | 5.25 years
| Vitamin A + zinc | Retinol palmitate, zinc oxide | 5000 IU/daily, 22.5 mg/daily
| Riboflavin + niacin | Riboflavin, niacin | 3.2 mg/1x/day, 40 mg/1x/day
| Vitamin C + molybdenum | Ascorbic acid, molybdenum | 120 mg/1x/day, 30 mcg/1x/day
| Vitamin E + selenium + beta-carotene | d-alpha-tocopherol, selenium yeast, beta-carotene | 30 mg/1x/day, 50 mcg/1x/day, 15 mg/1x/day
Linxian General Population Study^68^ | Placebo 1 | | | NS | 5.25 years
| Vitamin A | Retinol palmitate | 5000 IU/daily
| Zinc | Zinc oxide | 22.5 mg/daily
| Vitamin B2 | Riboflavin | 3.2 mg/1x/day
| Niacin | Niacin | 40 mg/1x/day
| Vitamin C | Ascorbic acid | 120 mg/1x/day
| Other Chemical | Molybendum | 30 mcg/1x/day
| Vitamin E | d-alpha-tocopherol | 30 mg/1x/day
| Selenuim | Selenium yeast | 50 mcg/1x/day
| Other Chemical | beta-carotene | 15 mg/1x/day
Linxian Cataract Study ^65^ | Placebo | | NS | NS | 6 years
| Calcium | Dibasic calcium phosphate | 324 mg/NS
| Folic Acid | Folic aci | 800 mcg/NS
| Vitamin B6 | Pyridoxine hydrochloride | 6 mg/NS
| Vitamin B12 | Cyanocobalamin | 18 mcg/NS
| Vitamin D | NS | 800 IU/NS
| Vitamin E | 2-ambo-alpha-tocopherol | 60 IU/NS
| Vitamin C | Ascorbic acid | 180 mg/NS
| Vitamin A | Acetate | 10000 IU/NS
| Iron | Ferrous fumarate | 54 mg/NS
| Zinc | Zinc sulfate | 45 mg/NS
| Magnesium | Magnesium oxide | 200 mg/NS
| Vitamin B1 | Thiamine mononitrate | 5 mg/NS
| Vitamin B2 | Riboflavin | 5.2 mg/NS
| Niacin | Niacinamide | 40 mg/NS
| Selenuim | Sodium selenate | 50 mcg/NS
| Beta-carotene | beta-carotene | 15 mg/1x/day
| Biotin | Biotin | 90 mcg/1x/day
| Calcium | Pantothenic acid/calcium pantothenate | 20 mg/1x/day
| Phosphorus and calcium | Phophorous/dibasic calcium phosphate | 250 mg/1x/day
| Iodine | Iodine/potassium iodide | 300 mg/1x/day
| Copper | Cupric oxide | 6 mg/1x/day
| Potassium | Potassium chloride | 15.4 mg/1x/day
| Chloride | Potassium chloride | 14 mg/1x/day
| Chromium | Chromium chloride | 30 mcg/1x/day
| Molybendum | Sodium molybdate | 30 mcg/1x/day
| Manganese | Manganese sulfate | 15 mg/1x/day
SU.VI.MAX ^69^ | Placebo | | NS | NS | 7.5 years
| Vitamin E | NS | 30 mg/1x/day
| Vitamin C | Ascorbic acid | 120 mg/1x/day
| Vitamin A | beta-carotene | 6 mg/1x/day
| Zinc | Zinc gluconate | 20 mg/1x/day
| Selenuim | Selenium yeast | 100 mcg/1x/day
SU.VI.MAX ^70^ | Placebo | | NS | NS | 8 years
| Vitamin E | a-tocopherol | 30 mg/1x/day
| Vitamin C | NS | 120 mg/1x/day
| Vitamin A | beta-carotene | 6 mg/1x/day
| Zinc | NS | 20 mg/1x/day
| Selenuim | Selenium yeast | 100 mcg/1x/day
REACT ^72^ | Placebo | | | With meals | 3 years
| Vitamin E | all rac-alpha-tocopherol acetate | 200 mg/3x/day
| Vitamin C | Ascorbic acid | 250 mg/3x/day
| Vitamin A | beta-carotene | 6 mg/3x/day
ARED ^75^ | Placebo | | NS | NS | 6.3 years
| Vitamin E | dl-alpha-tocopherol acetate | 200 IU/2x/day/ (2 tablets in the morning, 2 in the evening) | With meals
| Vitamin C | Ascorbic acid | 250 mg/2x/day (2 tablets in the morning, 2 in the evening)
| Vitamin A | beta-carotene | 7.5 mg/2x/day (2 tablets in the morning, 2 in the evening)
| Zinc | Zinc oxide | 40 mg/2x/day (2 tablets in the morning, 2 in the evening)
| Copper | Cupric copper | 2 mg/2x/day (2 tablets in the morning, 2 in the evening)
| Combination above supplements
ARED ^73^ | Placebo | | NS | NS | 6.3 years
| Vitamin E | dl-alpha-tocopherol acetate | 200 IU/2x/day (2 tablets in the morning, 2 in the evening) | With meals
| Vitamin C | Ascorbic acid | 250 mg/2x/day (2 tablets in the morning, 2 in the evening)
| Vitamin A | beta-carotene | 7.5 mg/2x/day (2 tablets in the morning, 2 in the evening)
| Zinc | Zinc oxide | 40 mg/2x/day (2 tablets in the morning, 2 n the evening)
MONMD ^74^ | Placebo | Starch | NS | NS | 18 months
| Vitamin E | NS | 200 IU/1x/day
| Vitamin C | NS | 750 IU/1x/day
| Vitamin A | beta-carotene | 20000 IU/1x/day
| Zinc | Zinc picolinate | 12.5 mg/1x/day
| Selenuim | Unspecified | 60 mcg/1x/day

SU.VI.MAX. (SUppléments en VItamines et Minéraux AntioXydants); REACT (Roche European American Cataract Trial); AREDS (Age-Related Eye Disease Study); ARMD (Age-Related Macular Degeneration); NS = Not specified; mg = milligram; mcg = microgram; IU = international unit

Evidence Table 1c. Characteristics of participants in studies of the efficacies of multivitamins

Study name | Mean age (SD), and/or range | Women, n (%); Ethnicity, n (%) | Smokers, n (%) | Alcohol consumption, n (%) | Mean BMI in kg/m2 | Prior supplement use, type (%)
Linxian General Population Study ^66^ | Median (female) 51; median (male): 53; range: 44–60. | 16271 (55); ethnicity NR | Current (female): 3254 (20); current (male): 8929 (67) | Current (female): (10); current (male): (40). | Median BMI (female): 21.9; median BMI (male): 21.6. | NR
Linxian General Population Study ^64^ | <50: 12425 (42%); 50–59: 10354 (35%); ≥60: 6804 (23%). | 16271 (55); ethnicity NR | Never: 20709 (70); ever smoked for >6 months: 8875 (30). | Never: 22780 (77); any use in past 12 months: 6804 (23). | NR | NR
Wang, 1994 | 53 | 196 (50); ethnicity NR | Current: 141 (36.0). | Current: 145 (37.0). | NR | NR
Linxian Cataract Study ^65^ | 57.5 | 2872 (53.3); ethnicity NR | Ever smoked for >6 months: 1748 (32.4). | NR | NR | NR
SU.VI.MAX ^69^ | Women: 46.6 (6.6); men: 51.3 (4.7). | 7713; ethnicity NR | Never (women, placebo): (54.8); never (women, intervention): (54.6); never (men, placebo): (34.5); never (men, intervention): (33.7); former (women, placebo): (29.1); former (women, intervention) (28.9); former (men, placebo): (50.2); former (men, intervention): (50.9); current (women, placebo): (16.1); current (women, intervention): (16.5); current (men, placebo): (15.3); current (men, intervention): (15.4). | NR | Placebo (women): 22.9 (3.0); intervention (women): 22.8 (0.5); placebo (men): 25.2 (3.0); intervention (men): 25.2 (3.0). | NR
SU.VI.MAX ^70^ | 51.3 (4.6) | 0 (0) ; ethnicity NR | Current: 4818 (15.4) | NR | BMI≥27 (placebo): 25.23%; BMI≥27 (supplement): 25.21%. | NR
REACT ^72^ | UK: 67.55 (8.47); US: 64.2 (8.49). | UK: 33 (47.1); US 52 (59.2); ethnicity NR | Never (UK): 13 (18.8); never (US): 15 (17.1). | NR | NR | NR
ARED ^75^ | Median: 56 | 2551 (56); Caucasian, 4412 (96); Latino 185 (4) | Former: 2184 (48); current: 345 (7.5). | NR | NR | Multivitamins or a supplement containing a study compound: 2528 (55); Centrum: 1548 (66).
ARED ^73^ | Median: 69 | 2021 (56); Caucasian, 3483 (96); Latino 153 (3) | Former: 1751 (49); current: 298 (8.0). | NR | NR | Multivitamin or supplement containing a study compound: 2047 (57); Centrum: 2418 (67).
MONMD ^71^ | 68.6–72.4 | 5 (6) | NR | 0.69–1.00 ounce/day | NR | No one used >1 year at entry

SU.VI.MAX. (SUppléments en VItamines et Minéraux AntioXydants); REACT (Roche European American Cataract Trial); AREDS (Age-Related Eye Disease Study); ARMD (Age-Related Macular Degeneration); BMI = Body mass index; NR (not recorded); UK = United Kingdom; US = United States

Evidence Table 1d. Results of studies of the efficacy of multivitamins/minerals in preventing chronic disease

Study name | Disease endpoint | Study supplement * | Total Number in study (active/ inactive) | Number of disease events (active/ inactive) | Incidence or prevalence of disease endpoint (active/ inactive) | Unadjusted estimates (95% CI) | P-value | Comment
Cancer
Linxian General Population Study ^64^ | Total cancer incidence | Retinol + zinc | Total 29, 584 | Total 1298 | | RR 1.00 (0.89–1.11)
| | Riboflavin + niacin | | | | RR 0.95 (0.85–1.06)
| | Vitamin C + molybdenum | | | | RR 1.06 (0.95–1.18)
| | Beta-carotene +selenium+alpha-tocopherol | | | | RR 0.93 (0.83–1.03)
| Gastric cancer incidence | Retinol + zinc | | Total 539 | | RR 0.96 (0.81–1.14)
| | Riboflavin + niacin | | | | RR 1.04 (0.88–1.23)
| | Vitamin C + molybdenum | | | | RR 1.10 (0.92–1.30)
| | Beta-carotene +selenium+alpha-tocopherol | | | | RR 0.84 (0.71–1.00)
| Esophageal cancer incidence | Retinol + zinc | | Total 640 | | RR 1.07 (0.92–1.25)
| | Riboflavin + niacin | | | | RR 0.86 (0.74–1.01)
| | Vitamin C + molybdenum | | | | RR 1.06 (0.91–1.24)
| | Beta-carotene +selenium+ alpha-tocopherol | | | | RR 1.02 (0.87–1.19)
| Esophageal/cardia incidence | Retinol + zinc | | Total 1075 | | RR 1.05 (0.93–1.19)
| | Riboflavin + niacin | | | | RR 0.94 (0.83–1.06)
| | Vitamin C + molybdenum | | | | RR 1.06 (0.94–1.20)
| | Beta-carotene +selenium+ alpha-tocopherol | | | | RR 0.94 (0.84–1.06)
| Total cancer death | Retinol + zinc | | Total 792 | | RR 0.97 (0.85–1.12)
| | Riboflavin + niacin | | | | RR 0.98 (0.85–1.13)
| | Vitamin C + molybdenum | | | | RR 1.06 (0.92–1.21)
| | Beta-carotene +selenium+ alpha-tocopherol | | | | RR 0.87 (0.75–1.00)
| Stomach cancer death | Retinol + zinc | | Total 331 | | RR 1.03 (0.83–1.28)
| | Riboflavin + niacin | | | | RR 1.00 (0.81–1.24)
| | Vitamin C + molybdenum | | | | RR 1.09 (0.88–1.36)
| | Beta-carotene+selenium+ alpha-tocopherol | | | | RR 0.79 (0.64–0.99)
| Esophageal cancer death | Retinol + zinc | | Total 360 | | RR 0.93 (0.76–1.15)
| | Riboflavin + niacin | | | | RR 0.90 (0.73–1.11)
| | Vitamin C + molybdenum | | | | RR 1.05 (0.85–1.29)
| | Beta-carotene+selenium+ alpha-tocopherol | | | | RR 0.96 (0.78–1.18)
| Esophageal/gastric cardia death | Retinol + zinc | | Total 613 | | RR 1.04 (0.89–1.22)
| | Riboflavin + niacin | | | | RR 0.95 (0.81–1.11)
| | Vitamin C + molybdenum | | | | RR 1.06 (0.90–1.24)
| | Beta-carotene+selenium+ alpha-tocopherol | | | | RR 0.90 (0.77–1.05)
Linxian General Population Study^68^ | Esophageal and gastric cancer and dyaplasia | Retinol + zinc | 197/194 | 28/32 | | OR 0.83 (0.47–1.46) | | Adjusted for age, gender, smoking, and alcohol use
| | Riboflavin + niacin | 194/197 | 34/26 | | OR 1.39 (0.79–2.44)
| | Ascorbic acid + molybdenum | 206/185 | 37/23 | | OR 1.61 (0.91–2.86)
| | Beta-carotene + selenium + alpha-tocopherol | 177/214 | 25/35 | | OR 0.83 (0.47–1.46)
| Esophageal and gastric cancer | Retinol + zinc | 197/194 | 13/18 | | OR 0.61 (0.29–1.31)
| | Riboflavin + niacin | 194/197 | 18/13 | | OR 1.46 (0.68–3.11)
| | Ascorbic acid + molybdenum | 206/185 | 21/10 | | OR 1.99 (0.90–4.41)
| | Beta-carotene + selenium + alpha-tocopherol | 177/214 | 12/19 | | OR 0.79 (0.36–1.69)
SU.VI.MAX ^70^ | Prostate cancer | Vitamin C + vitamin E + beta-carotene + selenium + zinc | 2522/2512 | 49/54 | | 0.88 (0.60–1.29) | 0.73
| | | 2293/2270 | 18/33 | | 0.52 (0.29–0.92) | 0.009 | In men with initial PSA<3.0 μg/L
| | | 149/143 | 31/19 | | 1.54 (0.87–2.72) | 0.43 | In men with initial PSA≥3.0 μg/L
SU.VI.MAX ^69^ | Cancer | Vitamin C + vitamin E + beta-carotene + selenium + zinc | 6364/6377 | 267/295 | | RR 0.90 (0.76–1.06) | 0.19
| | | 3844/3869 women only | 179/171 | | RR 1.04 (0.85–1.29) | 0.53
| | | 2520/2508 men only | 88/124 | | RR 0.69 (0.53–0.91) | 0.008
Cardiovascular Disease
Linxian General Population Study ^66^ | Stroke deaths | Retinol + zinc + riboflavin + niacin | Total 29,584 | 66/77 | 3.5/4.1 per 1000 | RR 0.85 (0.61–1.18)
| | Retinol + zinc + vitamin C + molybdenum | | 71/77 | 3.8/4.1 per 1000 | RR 0.91 (0.66–1.27)
| | Retinol + zinc + beta-carotene +selenium+ alpha-tocopherol | | 55/77 | 2.9/4.1 per 1000 | RR 0.71 (0.50–1.00)
| | Riboflavin + niacin + vitamin C + molybdenum | | 60/77 | 3.2/4.1 per 1000 | RR 0.78 (0.55–1.09)
| | Riboflavin + niacin + beta-carotene + selenium + alpha-tocopherol | | 58/77 | 3.1/4.1 per 1000 | RR 0.75 (0.53–1.05)
| | Vitamin C + molybdenum + beta-carotene + selenium+ alpha-tocopherol | | 67/77 | 3.6/4.1 per 1000 | RR 0.86 (0.62–1.20)
| | retinol + zinc + riboflavin + niacin + vitamin C + molybdenum + beta-carotene + selenium + alpha-tocopherol | | 69/77 | 3.7/4.1 per 1000 | RR 0.88 (0.64–1.22)
| | Retinol + zinc | | | | RR 0.99 (0.84–1.18)
| | Riboflavin + niacin | | | | RR 0.94 (0.79–1.11)
| | Vitamin C + molybdenum | | | | RR 1.04 (0.88–1.24)
| | Beta-carotene + selenium + alpha-tocopherol vs. placebo | | | | RR 0.91 (0.76–1.07)
SU.VI.MAX ^69^ | Ischemic cardiovascular disease | Vitamin C + vitamin E + beta-carotene + selenium + zinc | 6364/6377 | 134/137 | | RR 0.97 (0.77–1.20) | 0.8
Eye Disease
Linxian Cataract Study ^65^ | Prevalence of nuclear cataracts | Retinol + zinc | 1628/ 1621 | | 0.120/ 0.151 | OR 0.77 (0.58–1.02)
| | Riboflavin + niacin | 1623/ 1626 | | 0.107/ 0.169 | OR 0.59 (0.45–0.79) | | OR 0.99 (0.62–1.59) in those aged 55–64, OR 0.45(0.31–0.64) in those aged 65–74
| | Vitamin C + molybdenum | 1654/ 1595 | | 0.121/ 0.150 | OR 0.78 (0.59–1.04)
| | Beta-carotene + selenium + alpha-tocopherol | 1617/ 1632 | | 0.146/ 0.125 | OR 1.19 (0.90–1.59)
| Prevalence of cortical cataracts | Retinol + zinc | 1628/ 1621 | | 0.342/ 0.325 | OR 1.08 (0.92–1.27)
| | Riboflavin + niacin | 1623/ 1626 | | 0.342/ 0.325 | OR 1.08 (0.92–1.27)
| | Vitamin C + molybdenum | 1654/ 1595 | | 0.325/ 0.342 | OR 0.92 (0.79–1.09)
| | Beta-carotene + selenium + alpha-tocopherol | 1617/ 1632 | | 0.330/ 0.338 | OR 0.96 (0.82–1.13)
| Prevalence of posterior subcapsular cataracts | Retinol + zinc | 1628/ 1621 | | 0.008/ 0.013 | OR 0.59 (0.31–1.14)
| | Riboflavin + niacin | 1623/ 1626 | | 0.016/ 0.006 | OR 2.64 (1.31–5.35)
| | Vitamin C + molybdenum | 1654/ 1595 | | 0.011/ 0.009 | OR 1.25 (0.65–2.38)
| | Beta-carotene + selenium + alpha-tocopherol | 1617/1632 | | 0.013/ 0.008 | OR 1.56 (0.81–3.00)
REACT ^72^ | Anterior % pixel opaque^†^ | Beta-carotene + vitamin C + vitamin E | 81/77 | Not applicable | | Mean ± 95% CI Placebo: baseline 5.0 ± 1.4, last 8.3 ± 2.2, mean change from baseline: 3.3 ± 1.4; supplement: baseline 5.7± 1.6, last 7.3± 2.0 mean change from baseline: 1.7± 1.0; Difference from placebo: -1.6 | 0.05 | Unfavorable changes in secondary outcomes were smaller in the active supplement group, but none was significantly different from placebo group.
AREDS ^73^ cataract | Total lens event | Vitamin C + vitamin E + beta-carotene | 2286/2310 | 756/785 (in 5 years) | | OR 0.97 (0.84–1.11) | 0.55 | Adjustments for several potential confounders did not materially alter results
| Cataract surgery | Vitamin C + vitamin E + beta-carotene | 2286/2310 | 675 in total | | OR 0.94 (0.77–1.14) | 0.41
| Severe lens event | Vitamin C + vitamin E + beta-carotene | 2286/2310 | 991 in total | | OR 0.92 (0.76–1.12) | 0.27
| Nuclear event | Vitamin C + vitamin E + beta-carotene | 4331 | 1674 in total | | OR 0.98 (0.84–1.14) | 0.71 | Analysis of antioxidants only vs. placebo yielded similar results
| | Antioxidants only (vitamin C + vitamin E+ beta-carotene) | 2715 | 1027 in total | | OR 1.00 (0.82–1.22) | 0.97
| Cortical event | Vitamin C + vitamin E + beta-carotene | 4329 | 1058 in total | | OR 0.99 (0.82–1.19) | 0.84
| | Antioxidants only (vitamin C + vitamin E+ beta-carotene) | 2715 | 625 in total | | OR 0.91 (0.71–1.15) | 0.29
| Posterior subcapsular event | Vitamin C + vitamin E + beta-carotene | 4329 | 888 in total | | OR 0.94 (0.78–1.14) | 0.39
| | Antioxidants only (vitamin C + vitamin E+ beta-carotene) | 2715 | 535 in total | | OR 0.91 (0.70–1.17) | 0.33
| Lens event in eyes without opacities | Vitamin C + vitamin E + beta-carotene | 823 | NR | | OR 0.85 (0.55–1.33) | NR | Among those with no or minimal opacity in at least one eye at enrollment
| Loss of visual acuity score of 15 letters or more | Antioxidants only (vitamin C + vitamin E+ beta-carotene) | 537/580 | Total 172 | | OR 1.03 (0.63–1.66) | 0.89 | Among those without age-related macular degeneration at enrollment
AREDS ^75^ age-related macular degene-ration | Progression to advanced AMD (among participants in AMD categories 2,3,4) | Antioxidants vs. no antioxidants | Total 3609 | Total803 | | OR 0.87(0.70–1.09) | 0.12 | Analysis adjusted for sex, age, race, and category, and smoking status at enrollment did not materially alter size or direction of estimates
| | Zinc vs. no zinc | | | | OR 0.82 (0.66–1.03) | 0.02
| | Antioxidants | | | | OR 0.80 (0.59–1.09) | 0.07
| | Zinc | | | | OR 0.75 (0.55–1.03) | 0.02
| | Antioxidants + zinc | | | | OR 0.72 (0.52–0.98) | 0.007
| Loss of visual acuity score of >=15 letters from baseline (among participants in AMD categories 2,3,4) | Antioxidants vs. no antioxidants | Total 3597 | Total 1197 | | OR 0.90 (0.74–1.09) | 0.14
| | Zinc vs. no zinc | | | | OR 0.88 (0.73–1.07) | 0.09
| | Antioxidants | | | | OR 0.88 (0.67–1.15) | 0.22
| | Zinc | | | | OR 0.87 (0.66–1.13) | 0.17
| | Antioxidants + zinc | | | | OR 0.79 (0.60–1.04) | 0.03
| Progression to advanced AMD (among participants in AMD categories 3,4) | Antioxidants vs. no antioxidants | Total 2556 | Total 775 | | OR 0.83 (0.66–1.06) | 0.05
| | Zinc vs. no zinc | | | | OR 0.79 (0.69–0.99) | 0.009
| | Antioxidants | | | | OR 0.76 (0.55–1.05) | 0.03
| | Zinc | | | | OR 0.71 (0.52–0.99) | 0.008
| | Antioxidants + zinc | | | | OR 0.66 (0.47–0.91) | 0.001
| Loss of visual acuity score of >=15 letters from baseline (among participants in AMD categories 3,4) | Antioxidants vs. no antioxidants | Total 2549 | Total 1022 | | OR 0.86 (0.70–1.07) | 0.07
| | Zinc vs. no zinc | | | | OR 0.84 (0.68–1.04) | 0.04
| | Antioxidants | | | | OR 0.85 (0.63–1.14) | 0.16
| | Zinc | | | | OR 0.83 (0.62–1.11) | 0.10
| | Antioxidants + zinc | | | | OR 0.73 (0.54–0.99) | 0.008
MONMD ^74^ | Macular degeneration | Beta-carotene + vitamin E+vitamin C+ citrus bioflavenoid complex+ quercitin+ rutin+ zinc+ selenium+ taurine+ N-acetyl cysteine+ glutathione+ vitamin B2+ chromium | 39/32 | Not applicable | | | | Acuity of left eyes, dist VA (logMAR): from 0.17 to 0.19 (active arm), from 0.26 to 0.35 (placebo arm); difference from placebo=-0.7(p=0.03)
| | | | | | | | Acuity of left eyes, near VA (M print): from 0.77 M to 0.89 M (active arm), from 1.29 M to 2.03 M (placebo arm); difference from placebo=-.62(p=0.07)

* comparisons were made between groups receiving the combination of the listed nutrients and the groups receiving combinations of placebo/nutrients other than the nutrients listed, unless otherwise specified.

† primary endpoint

‡ secondary endpoint

SU.VI.MAX. (SUppléments en VItamines et Minéraux AntioXydants); MONMD = Multicenter ophthalmic and nutritional age-related macular degeneration study; REACT (Roche European American Cataract Trial); AREDS (Age-Related Eye Disease Study); OR = odds ratio; RR = relative risk; 95% CI = 95 confidence interval; PSA = prostate-specific antigen; py = person-years; AMD = age-related macular degeneration.

Evidence Table 1e. Total mortality in studies multivitamins/minerals used to prevent chronic disease

Study name | Disease endpoint | Study supplement* | Total Number in study (active/ inactive) | Number of disease events (active/ inactive) | Incidence or prevalence of disease endpoint (active/ inactive) | Unadjusted estimates (95% CI) | P-value | Comment
Linxian General Population Study ^66^ | Total mortality | Retinol + zinc + riboflavin + niacin | 29,584 (total) | 265/280 | 14.1/15.0 per 1000 py | RR 0.94 (0.79–1.11) | NR
| | Retinol + zinc + vitamin C + molybdenum | | 296/280 | 15.8/15.0 per 1000 py | RR 1.05 (0.89–1.24)
| | Retinol + zinc + beta-carotene +selenium+ alpha-tocopherol | | 250/280 | 13.3/15.0 per 1000 py | RR 0.89 (0.75–1.05)
| | Riboflavin + niacin + vitamin C + molybdenum | | 268/280 | 14.3/15.0 per 1000 py | RR 0.95 (0.81–1.13)
| | Riboflavin + niacin + beta-carotene +selenium+ alpha-tocopherol | | 263/280 | 14.0/15.0 per 1000 py | RR 0.93 (0.79–1.11)
| | Vitamin C + molybdenum + beta-carotene + selenium+ alpha-tocopherol | | 249/280 | 13.2/15.0 per 1000 py | RR 0.88 (0.74–1.05)
| | Retinol + zinc + riboflavin + niacin + vitamin C + molybdenum + beta-carotene + selenium + alpha-tocopherol | | 256/280 | 13.6/15.0 per 1000 py | RR 0.91 (0.76–1.07)
| | Retinol + zinc | | NR | NR | RR 1.00 (0.92–1.09)
| | Riboflavin + niacin | | | | RR 0.98 (0.90–1.06)
| | Vitamin C + molybdenum | | | | RR 1.01 (0.92–1.10)
| | Beta-carotene +selenium+ alpha-tocopherol | | | | RR 0.91 (0.84–0.99)
Linxian General Population Study ^71^ | Total mortality In men | Retinol + zinc | NR | NR | NR | 1.03 | NR | Confidence intervals not reported;
| | Riboflavin + niacin | | | | 0.96
| | Vitamin C + molybdenum | | | | 0.93 | | Age and sex difference are not statistically significant
| | Beta-carotene +selenium+ alpha-tocopherol | | | | 0.93
| Total mortality In women | Retinol + zinc | | | | 0.97
| | Riboflavin + niacin | | | | 0.99
| | Vitamin C + molybdenum | | | | 1.12
| | Beta-carotene +selenium+ alpha-tocopherol | | | | 0.89
| Total mortality In those aged <55 years | Retinol + zinc | | | | 0.96
| | Riboflavin + niacin | | | | 1.02
| | Vitamin C + molybdenum | | | | 0.90
| | Beta-carotene +selenium+ alpha-tocopherol | | | | 0.87 | <.05
| Total mortality In those aged ≥55 years | Retinol + zinc | | | | 1.02 | NR
| | Riboflavin + niacin | | | | 0.96
| | Vitamin C + molybdenum | | | | 1.05
| | Beta-carotene +selenium+ alpha-tocopherol | | | | 0.93
SU.VI.MAX ^69^ | Total mortality | Vitamin C + vitamin E + beta-carotene + zinc +selenium vs. placebo | 6364/6377 | 76/98 | NR | RR 0.77 (0.57–1.00) | .09
AREDS ^73^ cataract study | Total mortality | Vitamin C + vitamin E + beta-carotene | 2370/2387 | 251/240 | | RR 1.06 (0.84–1.33) | .53
| | vitamin C + vitamin E+ beta-carotene only vs. placebo | 2965 | 313 | | RR 1.05 (0.78–1.40) | .68
AREDS ^75^ age-related macular degene-ration | | Vitamin C + vitamin E + beta-carotene | 1833/1807 | 216/194 | | RR 1.10 (0.85–1.42) | .35
| | Zinc vs. no zinc | 1792/1848 | 178/232 | | RR 0.79 (0.61–1.02) | .02
| | Vitamin C + vitamin E + beta-carotene vs. placebo | 945/903 | 125/107 | | RR 1.12 (0.80–1.57) | .39
| | Zinc vs. placebo | 904/903 | 87/107 | | RR 0.81 (0.56–1.17) | .14
| | Vitamin C + vitamin E + beta-carotene + zinc vs. placebo | 888/903 | 91/107 | | RR 0.87 (0.60–1.25) | .32
REACT ^72^ | | Beta-carotene + vitamin C + vitamin E vs. placebo | 81/77 | 9/3 | | NR | NR

* comparisons were made between groups receiving the combination of the listed nutrients and the groups receiving combinations of placebo/nutrients other than the nutrients listed, unless otherwise specified.

CI = confidence interval; SU.VI.MAX. = SUppléments en VItamines et Minéraux AntioXydants; RR = relative risk; AREDS = Age-Related Eye Disease Study; REACT = Roche European American Cataract Trial; NR = not reported.

Evidence Table 2a. Characteristics of the interventions in studies of the safety of multivitamin supplements

Author, year | Study design | Control arm (duration of use) | INTERVENTION ARMS
| | | Nutrient/supplement | Chemical form(s) | Dose/frequency of use | Timing of use | Duration of use
Chylack, 2002^72^ | RCT | Placebocorn oil (3 years) | Multivitamin (beta-carotene, vitamin C, vitamin E) | All-rac alpha-tocopherol acetate; ascorbic acid; beta-carotene | 200 mg; 250 mg; 6 mg | 3x per day (with meals) | 3 years
ARED, 2001a, b^73,75^ | RCT | Placebo (6.3 years) | Multivitamin (vitamin E, vitamin C, vitamin A, zinc, copper) | Dl-alpha-tocopherol acetate; ascorbic acid; beta-carotene; zinc oxide; cuprix oxide | 200 IU; 250 mg; 7.5 mg; 40 mg; 1 mg | 2 pills in the morning, 2 in the evening, with meals | 6.3 years
| | | Multivitamin (vitamin E, vitamin C, vitamin A) | Dl-alpha-tocopherol acetate; ascorbic acid; beta-carotene | 200 IU; 250 mg; 7.5 mg
| | | Zinc, copper | Zinc oxide; cupric oxide | 40 mg; 1 mg
Richer, 1996^74^ | RCT | Placebo (starch), (18 months) | Multivitamin (Vitamin E, Vitamin C, Vitamin A, Zinc, Vitamin B2, Selenuim, citrus bioflavonoid complex; quercitin (bioflavonoid); biberry extract (bioflavonoid); rutin (bioflavonoid); taurine; n-acetyl cysteine; l-glutathione; chromium) | NS; NS; betacarotene; Zinc picolinate; NS; NS; NS; NS; NS; NS; NS;taurine; n-acetyl cysteine; l-glutathione | 200 IU; 750 IU; 20000 IU; 12.5 mg; 25 mg; 60 mcg; 125 mg; 50 mg; 5 mg; 50 mg; 100 mg; 100 mg; 100mg; 5 mg | 2x per day | 18 months
Xuan, 1991^78^ | RCT | | Vitamin A; beta-carotene; vitamin E; selenium | Retinol; beta-carotene; d-alpha-tocopherol; selenium yeast | 25,000 IU, 30 mg; 50 mg; 800 IU; 400 mcg | 1x per day | 6 months
Ohtake^79^ | Case report | | Multivitamin (Calcium, Vitamin D, Vitamin C), laxatives and aspirin | Calcium lactate; NS; ascorbic acid | 1000 mg; 250 IU; 6000 mg | 1x per day | 10 years
Grouhi, 2000^80^ | Case report | | Multivitamin (Calcium, Vitamin E, Vitamin C, niacin, selenium), echinacia; barley green; licorice root; Chinese herbs; B complex | NS; NS; NS; niacin; NS | 100 mg; 800 IU; 300 mg; 240 mg (niacin comes from multivitamin (40mg), B-complex (40mg) and anti-nausea drug(150mg)); 200 mcg | NS | NS
Gulati, 1999^81^ | Case report | | Multivitamin/minerals (Vitamin E Vitamin C Vitamin A Zinc Vitamin B2 Selenuim + copper) | Vitamin E acetate; NS; vitamin A acetate; NS; NS; selenium dioxide monohydrate; copper sulfate | NS | 1x per day | NS

Evidence Table 2b. Results of studies with information on clinical adverse effects of multivitamin supplements in the prevention of chronic diseases

Author, year | Nutrient | Adverse effect | Adverse effects in supplement group, n (%) | Adverse effects in inactive group, n (%) | Point estimate in active group, indicate what type | Statistical significance (p-value) | Comment
Chylack, 2002^72^ | Vitamins A, C, E | Intercurrent illness | 107 | 84 | NR | NS
| | Deaths/serious events | 9 deaths (2 from coronary thrombosis, lead from renal cell cancer, throat cancer, carcinomatosis, esophagitis, sudden death, aneurysm, pulmonary fibrosis) | 3 deaths (coronary thrombosis, bile duct cancer, lung cancer) | | 0.07 for deaths
| | Skin yellowing | 6 | NR
ARED, 2001a^73^ | Antioxidants | Hospitalizations (due to mild to moderate symptoms) | 173 (7.3%) | 221(9.3%) | NR | 0.01
| | Primary adverse effect (caused by skin, subcutaneous tissue problems) | 56 (2.4%) | 21(.9%) | | <0.001
| | Change in skin color | 203 (8.6%) | 146 (6.1%) | | <0.001
| | Chest pain | 467 (19.8%) | 541 (22.8%) | | 0.01
| | Mortality | 251 | 240 | 1.06 (0.84–1.33) | 0.53 | Similar results for analysis of antioxidants only vs. placebo
ARED, 2001b^75^ | Antioxidants | Yellow skin | 151 (8.3%) in antioxidant arm | 106 (6.0%) in non antioxidant arms | NR | 0.008
| | Hospitalizations due to infections | 29 (1.6%) in antioxidant arms | 15 (0.8%) in non antioxidant arns | NR | 0.04
| | Mortality | NR | NR | 1.10 (0.85–1.42) | 0.35 | Similar results when comparing antioxidants vs. placebo.
| | Skin and subcutaneous tissue conditions | 41 (2.2%) | 18 (1.0)% | NR | 0.003
| Zinc | Anemia | 236 (13.2%) in zinc arms | 187 (10.2%) in non zinc arms | NR | 0.004
| | Genitourinary hospitalizations (eg, unspecified urinary tract infection, prostatic hyperplasia in men, stress incontinence in women) | 134 (7.5%) in zinc arms | 90 (4.9%) in non zinc arms | | 0.001
| | Hospitalizations for mild/moderate symptoms (e.g. chest pain, fever) | 173 (9.7%) in zinc arms | 143 (7.8%) in non zinc arms | | 0.04
| | Circulatory adverse experience | 16 (0.9%) | 5 (0.3%)
Richer, 1996^74^ | Beta-carotene; vitamin E; vitamin C; bioflavonoid; zinc picolinate; selenium; taurine; n-acetyl cysteine; l-glutathione; vitamin B2; chromium | Diffuse whole body maculopapular rash | 1 | NR | NR | 0.06 for interation between time and caPsule within Patients
| | Transient diarrhea | NR | | | | In the article, Appendix 3 showed changes in several labs, and none of which were significant,Appendix 4 showed the mean scores for diarrhea, constipation, nausea/vomiting, and dyspeptic symptoms, none of which differed between the arms.
| | Diarrhea, constipation, nausea/vomiting, dyspeptic symptoms
Xuan, 1991^78^ | Vitamin E, selenium | See comments | See comments | See comments | NR | | Symptoms (muscle cramps, diarrhea, decreased appetite, runny nose, joint pain, lip chapping, yellowing, broken nails, hair loss, tingling headache, lethargy) were generally improved by the intervantion.
| | Stroke | 1 (vitamin E + selenium) | 1 (placebo)
Ohtake, 2005^79^ | Ascorbic acid; calcium lactate; vitamin D, laxatives; laxatives | Severe proximal tubular dysfunction, calcified lesion, hypokalemic nephropathy | 1 | 0 | NR | | Case took ascorbic acid of 6000 mg/day, vitamin D, calcium lactate and laxatives; hypokalemic nephropathy probably was due to long-term use of laxatives, but the calcified lesion probably was due to massive oxalate load after excessive ingestion of vitamin C.
Grouhi, 2000^80^ | Niacin | Pseudoallergic toxic reaction | 1 | NA | NA
Gulati, 1999^81^ | Vitamin A acetate; vitamin E acetate; vitamin C; vitamin B2; copper sulfate; zinc sulfate; selenium dioxide monohydrate | Fixed drug eruption | 1 | 0 | NA

NR = Not reported; NS = Not significant; NA = Not applicable

Evidence Table 2c. Results of Studies with information on lipid profiles associated with the use of multivitamin supplements

Author, year | Nutrient | Adverse effect | Adverse effects in supplement group, n (%) | Adverse effects in inactive group, n (%) | Change in active group (indicate mean (95% CI)), mean (SD), mean (SE), median or other measurements | Change in inactive group (indicate mean (95% CI)), mean (SD), mean (SE), median or other measurements | Statistical significance (p-value) | Comment
Sacco, 2003^181^ | Vitamin E | Lipid profiles: Cholesterol (mM), LDL (mM), HDL (mM), triglycerides (mM) | NA | NA | Mean (SD) pre/post: Cholesterol 4.97 (1.09)/4.73 (0.87); LDL 3.44 (0.88)/3.06 (0.96l); HDL 1.44 (0.42)/1.23 (0.37); TG 0.84 (0.15)/0.92 (0.28) | Mean (SD) pre/post: Cholesterol 4.68 (0.84)/4.60 (0.80); LDL 2.40 (0.53)/2.84 (0.79) HDL 1.01 (0.3)/1.22 (0.48) TG 1.44 (0.99)/1.18 (0.55) | | All values not significantly different from the mean level of the 50 volunteers
| Vitamin C | | | | Mean (SD) pre/post: Cholesterol 5.23 (0.97)/5.30 (1.00); LDL 2.82 (0.65)/3.17(0.72); HDL 1.58 (0.41)/1.50 (0.79); TG 1.31 (1.00)/1.33 (0.79) | Mean (SD) pre/post: Cholesterol 4.68 (0.84)/4.60 (0.80); LDL: 2.40 (0.53)/2.84 (0.79); HDL: 1.01 (0.3)/1.22 (0.48); TG: 1.44 (0.99)/1.18 (0.55)
| Beta-Carotene | | | | Mean (SD) pre/post: Cholestrol 4.83 (0.65)/4.87 (0.55); LDL 2.88 (0.24)/3.14 (0.52); HDL 1.28 (0.21)/1.12 (0.22); TG 1.01 (0.41)/1.29 (0.96) | Mean (SD) pre/post: Cholesterol 4.68(0.84)/4.60 (0.80); LDL 2.40 (0.53)/2.84 (0.79); HDL 1.01 (0.30)/1.22 (0.48); TG 1.44 (0.99)/1.18 (0.55)
| Combined | | | | Mean (SD) pre/post: Cholestrol 5.04 (1.32)/4.98 (1.27); LDL 2.97 (1.75)/3.19 (0.34); HDL 1.39 (0.34)/1.30 (0.37); TG 1.06 (0.75)/1.08 (0.89) | Mean (SD) pre/post: Cholesterol 4.68 (0.84)/4.60 (0.80); LDL 2.40 (0.53)/2.84 (0.79); HDL 1.01 (0.30)/1.22 (0.48); TG 1.44 (0.99)/1.18 (0.55)

NA = Not applicable; NR = Not Reported; LDL = low-density lipoprotein; HDL = high-density lipoprotein; SD = Standard Deviation; SE = Standard Error.

Evidence Table 2d. Assessment of the likelihood that reported adverse effect were caused by use of a multivitamin/mineral supplement

Author, year | Nutrient | Adverse effect | Temporal relationship | Dose-response relationship | Adverse effects disappeared after discontinuation of supplementation | Evidence of supplement use | Lack of alternative cause | Recurrence after reuse of supplement
Chylack, 2002^72^ | Vitamins A, C, E | Intercurrent illness | Yes | NR | NR | Yes | NR | NR
| | Deaths/serious events
| | Skin yellowing
ARED, 2001a^73^ | Antioxidants | Hospitalizations (due to mild to moderate symptoms) | Yes | NR | NR | Yes | NR | NR
| | Primary adverse effect (caused by skin, subcutaneous tissue problems)
| | Change in skin color
| | Chest pain
ARED, 2001b^75^ | Antioxidants | Yellow skin | Yes | NR | NR | Yes | NR | NR
| | Hospitalizations due to infections
| | Skin and subcutaneous tissue conditions
| Zinc | Anemia | Yes | NR | NR | Yes | NR | NR
| | Genitourinary hospitalizations
| | Hospitalizations for mild/moderate symptoms (e.g. chest pain, fever)
| | Circulatory adverse experience
Richer, 1996^74^ | Beta-carotene; vitamin E; vitamin C; bioflavonoid; zinc picolinate; selenium; taurine; n-acetyl cysteine; l-glutathione; vitamin B2;chromium | Diffuse whole body maculopapular rash | Yes | NR | NR | Yes | No | NR
| | Transient diarrhea | Yes | NR | NR | Yes | Yes | NR
| | Cholesterol | No | NR | NR | Yes | NR | NR
| | Diarrhea, constipation, nausea/vomiting, dyspeptic symptom | Yes | NR | NR | Yes | NR | NR
Xuan, 1991^78^ | Vitamin E, selenium | Stroke | Yes | NR | NR | Yes | NR | NR
Ohtake, 2005^79^ | Ascorbic acid; calcium lactate; vitamin D, laxatives; laxatives | Severe proximal tubular dysfunction, calcified lesion, hypokalemic nephropathy | NR | No | Yes | NR | NR | NR
Grouhi, 2000^80^ | Niacin | Pseudoallergic toxic reaction | NR | Yes | NR | Yes | Yes | NR
Gulati, 1999^81^ | Vitamin A acetate; vitamin E acetate; vitamin C; vitamin B2; copper sulfate; zinc sulfate; selenium dioxide monohydrate | Fixed drug eruption | NR | NR | NR | No | NR | NR

NR = Not reported

Evidence Table 3a. Characteristics of the studies on the efficacy of vitamin A and/or beta-carotene (singly or paired) in preventing chronic disease

Author, year | Study design | Study period | Exclusion criteria | Total sample size enrolled | Mean/ median follow-up time | Study site | Recruitment setting
ATBC
ATBC, 1994^97^ | RCT; Factorial design | 1985-1988 | Not 50–69; female; any cancer except non-melanoma skin; chronic renal insufficiency; liver cirrhosis; chronic alcoholism; medical condition limiting participation; severe angina; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses | 29133 | 6.1 years (median) | Finland | Community
Albanes, 1996^98^ | | 1985-1993 | Not 50–69; female; any previous or current cancer; symptomatic CV disease, CHD or major ischemic change in their ECG; atrophic gastritits at baseline or after 3-yr follow-up; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; not smoking 5 or more cigarettes/day at entry; anti-coagulant use | 1344 | 5–8 years (total), 3.9 years (median, Helsinki), 5.8 years (median, outside Helsinki)
Rautalahti, 1999^99^ | | 1985-1993 | Not 50–69; female; cancer; serious diseases; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; nonsmokers) | 29133 | 5–8 years (total), 6.1 years (media
Varis, 1998^90^ | | 1985-1993 | Not 50–69; female; any previous or current cancer; symptomatic CV disease, CHD or major ischemic change in their ECG; atrophic gastritits at baseline or after 3-yr follow-up; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; not smoking 5 or more cigarettes/day at entry; anti-coagulant use | 1344 | 5–8 years (total), 3.9 years (median, Helsinki), 5.8 years (median, outside Helsinki)
Rapola, 1996^106^ | | 1985-1993 | MI; any history of CHD at baseline and same criteria as general ATBC trial | 22265 | 4.7 years (median)
Leppala, 2000 ^107^ | | 1985-1993 | Not 50–69; female; cancer; serious diseases; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; not smoking 5 or more cigarettes/day at entry; anti-coagulant use | 28519 | 6.0 years (median)
Teikari, 1997^109^ | | 1985-1993 | Not 50–69; female; cancer; serious diseases; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; nonsmokers) | 1828 | 6.6 years (median)
CARET
Omenn, 1996a^105^ | RCT; Placebo controlled | 1985-1993 | Asbestos arm: not 45–74 years old in pilot period or 45–69 yrs in vanguard; smoking arm: not 50–69 yrs, male; any history of cancer except non-melanoma skin cancer in past 5 years; NASH; NAFLD; asbestos arm: no chest X-ray evidence of asbestos interstitial lung disease or not greater than or equal to 5 years high risk trade, SGOT or alkaline phosphate greater than 2.5x and 1.5x 95th percentile of normal, respectively, history of liver disease in past 12 months, any beta-carotene supplementation; smoking arm: < 20 pack-year smoking history, current or quit in past 6 years; smoking arm: premenopausal; asbestos arm: < 15 years since first occupational exposure. | 1845 | 8 years (total) | Seattle, Washington; Portland, Oregon; San Francisco, CA; Baltimore, MD; New Haven Conn; Irvine, CA. | Clinical and community
Omenn, 1996b^93^ | | 1985-1995 | | 18314 | 4 years (mean), 3.7 years (median). | | Asbestos arm: recruited from physicians' clinics, worker's compensation programs, labor unions, lawyers, Navy Medical Asbestos Surveillance Program, union. Smoking arm: Insurance and AARP mailing lists.
Gooodman, 2004^94^ | RCT ( Post-intervention follow up) | 1985-1996 | | 17140 | 5.9 years (total) | | Clinical and community
NCSP
Green, 1999^84^ | RCT; Factorial design | 1992-1996 | Skin cancer | 809 | 4.5 years (total) | Australia | Community
SCP
Greenberg, 1996^85^ | RCT; Parallel arms | 1983-1993 | 85 years old or greater; any cancer other than nonmelanoma skin cancer diagnosed during the prior 5 years; debilitating cardiovascular conditions; known genetic predisposition to cancer; had not had at least one biopsy proved basal cell or squamous cell skin cancer treated after January 1, 1980; medical conditions that would limit participation in the study. | 1720 | 8.2 years (median) | USA | Clinical
PHS
Cook, 2000^104^ | RCT; Factorial design | 1982-1995 | Female; cancer; MI; stroke; current use of vitamin A supplements; taking aspirin. | 22071 | 12.9 years (mean) | USA | Physician rosters
Frieling, 2000^86^
Liu, 1999^108^ | | | Female; cancer; MI; stroke; type II diabetes | 21468 | 12.9 years (mean) | | Physician rosters
Hennikens, 1996^95^ | | | Female; cancer except nonmelanoma skin cancer; MI; stroke; transient cerebral ischema | 22071 | 12 years (mean) | | Physician rosters
WHS
Lee, 1999^96^ | RCT; Factorial design | 1993-1996 | Male; cancer; MI; stroke; serious illness that might preclude participation; participants in the Nurses Health Study; taking supplements of vitamin A, E, or beta-carotene more than once per week; taking aspirin or aspirin containing medications and not willing to forego use; NSAID more than once a week and not willing to forego use; taking anticoagulants; taking corticosteroids. | 39876 | 4.1 years (median) | USA (nation-wide) | Health professionals
Linxian General Population Study
Mark, 1998^66^ | RCT; factorial design | 1986-1991 | Not 40–46 years old; history of cancer; history of debilitating diseases. | 29584 | 5 years (total) | Linxian province, China | Community
Blot, 1993^64^ | | | Not 40–69; stomach or esophageal; debilitating disease; does not live in one of 4 communes in Linxian | | 5.25 years (total)

ATBC = Alpha-tocopherol Bata-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; NSCP = Nambour Skin Cancer Prevention Trial; SCP = Skin Cancer Prevention Study; PHS = Physicians Health Study; WHS = Womens Health Study.

Evidence Table 3b. Characteristics of the intervention in the studies of the efficacy of vitamin A and/or beta-carotene in the prevention of chronic disease

Author, year | Control arm | Intervention | Chemical form | Dose/Frequency of use | Timing of use | Duration of use
ATBC
ATBC, 1994^97^ | Placebo | Vitamin E; beta-carotene | dl-alpha-tocopherol acetate; beta-carotene | 50 mg/1x/day; 20 mg/1x/day | NS | 6.1 years median
Albanes, 1996^98^ | | | | | | 5.1 years; 3.9 years (Helsinki) and 5.4 years (outside)
Rautalahti, 1999^99^ | | | | | | 6.1 years
Varis, 1998^90^ | | | | | | 5.1 years; 3.9 years (Helsinki) and 5.4 years (outside)
Rapola, 1996^106^ | | | | | | 4.7 years median
Leppala, 2000 ^107^ | | | | | | 6 years median
Teikari, 1997^109^ | | | | | | 5.1 years; 3.9 years (Helsinki) and 5.4 years (outside)
CARET
Omenn, 1996a^105^ | Placebo | Vitamin A | Retinol in pilot phase (1985-1988) then retinyl palmitate in Vanguard (1988-1996) | 25000 IU/1x/day | NS | Max 8 years
Omenn, 1996b^93^ | | Vitamin A | Retinyl palmitate | 25000 IU/1x/day | | 10 years; Until endpoint (NS)
Gooodman, 2004^94^ | | Vitamin A; beta-carotene | | 25000 IU/1x/day; 30 mg/1x/day | | 10 years;Until endpoint (NS)
NSCP
Green, 1999^84^ | Placebo | Beta-carotene | Beta-carotene | 30 mg/1x/day | With meals | 4.5 years
SCP
Greenberg, 1996^85^ | Placebo | Beta-carotene | Beta-carotene | 50 mg/1x/day | NS | 4.3 years
PHS
Cook, 2000^104^ | Placebo | Beta-carotene | Beta-carotene | 50 mg/every other day | NS | 12.9 years (mean)
Frieling, 2000^86^ | | | | | | 12.9 years (mean)
Liu, 1999^108^ | | | | | | 12 years
Hennikens, 1996^95^ | | | | | | 12 years (mean)
WHS
Lee, 1999^96^ | Placebo | Beta-carotene | Beta-carotene | 50 mg/every other day | NS | 2.1 years
Linxian General Population Study
Mark, 1998^66^ | Placebo | Vitamin A; zinc | Retinol palmitate; zinc oxide | 10,000 IU/NS; 45 mg/NS | NS | 5 years
| | Vitamin B2; niacin | Riboflavin; niacin | 5.2 mg/NS; 40 mg/NS
| | Vitamin C; molybdenum | Ascorbic acid; yeast complex | 180 mg/NS; 30 μg/NS
Blot, 1993^64^ | Placebo | Vitamin A; zinc | Retinol palmitate; zinc oxide | 5000 IU/daily; 22.5 mg/daily | NS | 5.25 years
| | Vitamin B2; niacin | Riboflavin; niacin | 3.2 mg/1x/day; 40 mg/1x/day
| | Vitamin C; molybdenum | Ascorbic acid; yeast complex | 12 mg/NS; 30 μg/NS

ATBC = Alpha-tocopherol Bata-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; NSCP = Nambour Skin Cancer Prevention Trial; SCP = Skin Cancer Prevention Study; PHS = Physicians Health Study; WHS = Women Health Study; NS = Not specified; mg = milligram; mcg = microgram; IU = international unit; μg

Evidence Table 3c. Characteristics of participants in studies of the efficacies of Vitamin A and/or beta-carotene (singly or in nutrient pairs)

Author, year | Mean age (SD), and/or range | Women, n (%); Ethnicity, n (%) | Smokers, n (%) | Alcohol consumption, n (%) | Mean BMI in kg/m2 | Prior supplement use, type (%)
ATBC
ATBC, 1994^97^ | Median: 57; range: 50–69. | 0 (0); ethnicity NR | Current: 29133 (100) | Mean intake (grams/day): 11.0. | 26.0 | NA
Albanes, 1996^98^ | Median: 57; range: 50–69. | | Current: 29133 (100) | Mean intake (grams/day): 11.0. | 26.0
Rautalahti, 1999^99^ | 57.7 | | Current: (100.0) | Mean intake (grams/day): 18.0. | 26.3
Varis, 1998^90^ | 58.8 | | Current: 1344 (100) | Mean intake (grams/day): 8.9. | NR
Rapola, 1996^106^ | Median: 56.9 | | Current: 22269 (100) | NR | 26.0
Leppala, 2000 ^107^ | Mean: 57.7 | | Current: 28519 (100) | Mean intake (grams/day): 18.0. | 26.3
Teikari, 1997^109^ | 64.8 | | Current: 1828 (100) | Mean intake (grams/day): 12.5. | 25.5
CARET
Omenn, 1996a^105^ | NR | Gender, NR; ethnicity NR | NR | NR | NR | NR
Omenn, 1996b^93^ | 58 | 6289 (34.3); Caucasian, 17067 (93.2); African-American, 530 (2.9); Latino 275 (1.5) | Never: 132 (0.7); former: 7174 (39.2); current: 11008 (60.1). | Never: 6121 (33.4).
Gooodman, 2004^94^ | 62 | 6007 (35); Caucasian, 15988 (93.3) | Never: 116 (0.7); former: 8988 (52.4); current: 8036 (46.9). | NR
NSCP
Green, 1999^84^ | 48.8 | 913 (56.3); ethnicity NR | NR | NR | NR | NR
SCP
Greenberg, 1996^85^ | 63.2 | 532 (31); ethnicity NR | Never: 625 (36.3); former: 780 (45.3); current: 315 (18.3). | NR | BMI <23: 461 (26.8); BMI 23–27: 813 (47.3); BMI>27: 466 (27.1). | NR
PHS
Cook, 2000^104^ | 53.0 (9.5); range: 40–84. | 0 (0); ethnicity NR | Never: 11036 (50); former: 8608 (39); current 2428 (11.0). | Rare: 3222 (14.6%); monthly: 2428 (11.0); weekly: (49.5); daily: 5518 (25.0). | 24.9 | Current multivitamin use: 4304 (19.5).
Frieling, 2000^86^
Liu, 1999^108^
Hennikens, 1996^95^
WHS
Lee, 1999^96^ | 53.9 (7.1) | 39876 (100); Caucasian, 37802 (94.8); Latino, 917 (2.3),; Asian, 558 (1.4) | Never: 20377 (51.1); former: 14355 (36); current: 5224 (13.1). | Never: 17984 (45.1). | 26.0; BMI>27.3: 13119 (32.9%). | Vitamin C use: 3788 (9.5); current regular multivitamin use: 11644 (29.2).
Linxian General Population Study
Mark, 1998^66^ | Median (female) 51; median (male): 53; range: 44–60. | 16271 (55); ethnicity NR | Current (female): 3254 (20); current (male): 8929 (67). | Current (female): (10); current (male): (40). | Median BMI (female): 21.9; median BMI (male): 21.6. | NR
Blot, 1993^64^ | <50: 12425 (42%); 50–59: 10354 (35%); ≥60: 6804 (23%). | | Never: 20709 (70); ever smoked for >6 months: 8875 (30). | Never: 22780 (77); any use in past 12 months: 6804 (23). | NR

ATBC = Alpha-tocopherol Bata-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; NSCP = Nambour Skin Cancer Prevention Trial; SCP = Skin Cancer Prevention Study; PHS = Physicians Health Study; WHS = Womens Health Study; BMI = Body Mass Index; NR not reported

Evidence Table 3d. Results of studies of the efficacy of vitamin A and/or beta-carotene in preventing chronic disease

Author, year | Disease endpoint | Study supplement | Total Number in study (active/inactive) | Number of disease events (active/inactive) | Incidence of disease endpoint (active/inactive) | Unadjusted estimates (95% CI) | P-value | Comment
Cancer
ATBC
ATBC, 1994^97^ | Lung cancer | Beta-carotene | 14564/14564 | 474/402 | 56.3/47.5 per 10000 py | RR 1.18 (1.03–1.36) | .01
| Lung cancer mortality | Beta-carotene | | 302/262 | 35.6/30.8 per 10000 py | RR 1.08 (1.01–1.16) | .02
Albanes, 1996^98^ | Lung cancer | Beta-carotene vs. no beta-carotene | 14560/14573 | 482/412 | 58.0/41.2 per 10000 py | RR 1.16 (1.02–1.33) | .01 | RR 1.39, 95% CI 1.03–1.88 in those aged 65–69; RR 1.25, 95% CI 1.07–1.46 in those smoker 20+ cigarettes/day; RR 1.23, 95% CI 1.04–1.47 in those who always inhale cigarette smoke; RR 1.17, 95% CI 1.03–1.34 in those exposed to asbestos; RR 1.40, 95% CI 1.10–1.78 in those with dietary intake <8.1 mg/d; RR 1.35, 95% CI 1.01–1.81 in those drank ethanol >11 g/d; RR 1.33, 95% CI 1.01–1.73 in those with baseline serum α-tocopherol 11.6–13.1 mg/L; Non significant findings for lng cancer in the subgroups defined by baseline dietary intake of β- carotene, vitamin C, or retinol, and by serum β-carotene or retinol.
Albanes, 2000^102^ | Colorectal cancer | Beta-carotene | 7282/7287 | 39/37 | NR | RR 1.06 (0.68–1.66)
| | Beta-carotene vs. no beta-carotene | 14560/ 14573 | 69/66 | | RR 1.05 (0.75–1.47) | .78 | P-value from log-rank test
| | Alpha-tocopherol +beta-carotene | 7278/7287 | 30/37 | | RR 0.82 (0.50–1.31)
| Colorectal cancer mortality | Beta-carotene vs. no beta-carotene | 14564/ 14569 | 22/24 | | RR 1.01 (0.56–1.79)
Malila, 1999 ^100^ | Colorectal Adnomas | Beta-carotene vs. no beta-carotene | 7761/7777 | 81/56 | NR | RR 0.98 (0.71–1.35) | .89 | P-value from log-rank test ; results did not change after excluding 15 cases with a prior history of polyps (RR 0.96)
Heinonen, 1998^101^ | Prostate cancer | Beta-carotene | 7282/7287 | 80/67 | NR | RR 1.20 (0.87–1.66)
| | Alpha–tocopherol +beta-carotene | 7278/7287 | 56/67 | | RR 0.84 (0.59–1.20)
| | Beta-carotene vs. no beta-carotene | 14560/ 14573 | 136/110 | | RR 1.23 (0.96–1.59)
| Prostate cancer mortality | Beta-carotene vs. no beta-carotene | 14560/ 14573 | 33/29 | | RR 1.15 (0.70–1.89)
Rautalahti, 1999^99^ | Pancreatic cancer | Beta-carotene vs. no beta-carotene | 14573/ 14560 | 38/51 | 0.45/0.60 per 1000 py | RR 0.75 (0.49–1.14)
| Carcinoma of the pancreas | Beta-carotene | 7282/7287 | 12/26 | NR | RR 0.46 (0.23–0.92)
| Pancreatic cancer mortality | Beta-carotene vs. no beta-carotene | 14573/ 14560 | 35/48 | NR | RR 0.81 (0.53–1.26)
Varis, 1998^90^ | Gastric dysplasia, carcinoma, or carcinoid | Beta-carotene | 329/333 | 13/18 | NR | NR
| | Alpha-tocopherol + beta-carotene | 361/333 | 19/18
| | Beta-carotene vs. no beta-carotene | 690/654 | 32/31 | | RR 0.98 (0.59–1.62) | | Adjusted RR 1.13 (0.65–1.95)
CARET
Omenn, 1996a ^105^ | Lung Cancer | Retinyl palmitate + beta-carotene | 9420/8894 | 229/159 | 5.9/4.6 per 1000 | RR 1.28 (1.04–1.57) | .02
| Lung cancer mortality | | 9420/8894 | NR | | RR 1.46 (1.07–2.00) | .02
| Leukemia | | 9420/8894 | 18/8 | | RR 2.18 (0.95–5.03) | .06
| Mesothelioma | | 9420/8894 | 14/9 | | RR 1.52 (0.66–3.52) | .32
| Breast Cancer | | 3208/3081 | 59/65 | | RR 0.78 (0.55–1.12) | .18
| Colorectal cancer | | 9420/8894 | 56/50 | | RR 1.02 (0.70–1.50) | .91
| Head/neck cancer | | 9420/8894 | 32/22 | | RR 1.26 (0.73–2.19) | .41
| Lymphoma | | 9420/8894 | 13/13 | | RR 0.91 (0.42–1.98) | .81
| Prostate cancer | | 9420/8894 | 161/139 | | RR 1.01 (0.80–1.27) | .95
| Bladder cancer | | 9420/8894 | 42/36 | | RR 1.08 (0.69–1.70) | .73
Omenn, 1996b^93^ | Lung Cancer | Retinyl palmitate + beta-carotene | 9420/8894 | Total 388, Confirmed: 286 | Total 5.4 per 1000 py; Active:confirmed: 5.92 per 1000 py; Placebo 4.62 per 1000 py | RR 1.28 (1.04–1.57) | .02
| Lung Cancer death | | | NR | | RR 1.46 (1.07–2.0)
| Mesothelioma | | | 14/9 | | NR | | Described as “no statistically significant effect”
Goodman, 1993^92^ | Lung Cancer | Active group follow up (had received vitamin A and beta-carotene) | 8744/8396 | 376/311 | | RR 1.12 (0.97–1.31) | .13
| Lung cancer mortality | Active group follow up (had received vitamin A and beta-carotene) | | 294/227 | | RR 1.20 (1.01–1.43)
NCSP
Green, 1999^84^ | Basal-cell carcinoma | Beta-carotene | 820/801 | 102/93 | 3954/3806 per 100,000 | RR 1.04 (0.73–1.27) | | Data based on persons with and without a history of skin cancer
| Squamous-cell carcinoma | Beta-carotene | | 40/28 | 1508/1146 per 100,000 | RR 1.35 (0.84–2.19)
PHS
Frieling, 2000^86^ | Nonmelanoma skin cancer | Beta-carotene | 10941/10943 | 1786/1821 | | RR 0.98 (0.92–1.05) | | Adjusted for age and aspirin use
| Basal cell carcinoma | | 10941/10943 | 1574/1598 | | RR 0.99 (0.92–1.06)
| Squamous cell carcinoma | | 10941/10943 | 340/352 | | RR 0.97 (0.84–1.13)
Hennikens, 1996^95^ | All cancer | Beta-carotene | 11036/11035 | 1273/1293 | | RR 0.98 (0.91–1.06) | .65
| All cancer mortality | | | 386/380 | | RR 1.02 (0.89–1.18) | .76
SCP
Greenberg, 1996^85^ | Cancer deaths | Beta-carotene | | 38/44 | NR | HR 0.86 (0.56–1.32) | .48, adjusted .41 | Adjusted for age, sex, center, quetelet index, smoking; adjusted HR 0.83 (0.54–1.29)
Cook, 2000^104^ | Non-melanoma skin cancer | Beta-carotene | 11036/11035 | 1314/1353 | | RR 1.0 (0.9–1.0) | .41
| Prostate cancer | | | 551/566 | | RR 1.0 (0.9–1.1) | .62
| Colon cancer | | | 128/139 | | RR 0.9 (0.7–1.2) | .48
| Rectal cancer | | | 42/37 | | RR 1.1 (0.7–1.8) | .58
| Lung cancer | | | 85/93 | | RR 0.9 (0.7–1.2) | .54
| Lymphoma | | | 89/85 | | RR 1.0 (0.8–1.4) | .77
| Leukemia | | | 36/45 | | RR 0.8 (0.5–1.2) | .31
| Melanoma | | | 68/77 | | RR 0.9 (0.6–1.2) | .45
| Brain cancer | | | 25/33 | | RR 0.8 (0.5–1.3) | .29
| Bladder cancer | | | 62/41 | | RR 1.5 (1.0–2.2) | .04
| Stomach cancer | | | 20/21 | | RR 0.9 (0.5–1.8) | .87
| Thyroid cancer | | | 19/2 | | RR 9.5 (2.2–40.7) | .003
| All cancer incidence | | | 1314/1353 | | RR 1.0 (0.9–1.0) | .41
| All cancer mortality | | | 414/406 | | RR 1.0 (0.9–1.2) | .71
WHS
Lee, 1999^96^ | All cancers not non-melanoma skin cancer | Beta-carotene | 19939/ 19937 | 378/369 | | RR 1.03 (0.89–1.18) | .73 | Adjusted for age, randomized aspirin assignment, and randomized vitamin E assignment.
| Cancer mortality | | | 31/28 | | RR 1.11 (0.67–1.85) | .69
Linxian General Population Study
Blot, 1993^64^ | Gastric cancer incidence | Retinol + zinc | | | | RR 0.96 (0.81–1.14)
| Esophageal cancer incidence | | | | | RR 1.07 (0.92–1.25)
| Stomach cancer death | | | | | RR 1.03 (.83–1.28)
| Stomach cancer incidence | | | | | RR 1.02 (.85–1.24)
| Total cancer incidence | | | | | RR 1.00 (.89–1.11)
ATBC
Rapola, 1996^106^ | Angina | Beta-carotene vs. no beta-carotene | 11348/ 11119 | 1020/963 | 21.2/20.0 per 1000 py | RR 1.05 (0.97–1.16)
| | Beta-carotene alone | 5602/5549 | 548/487 | 22.8/20.2 per 1000 py | RR 1.13 (1.00–1.27)
| | Alpha-tocopherol + beta-carotene | 5548/5549 | 472/487 | 19.6/20.2 per 1000 py | RR 0.96 (0.85–1.09)
Cardiovascular Disease
Leppala, 2000 ^107^ | Intracerebral hemorrhage | Beta-carotene vs. no beta-carotene | 14246/ 14273 | 69/43 | 8.4/5.2 per 10000 yr | RR 1.62 (1.10–2.36) | .01
| Death from Intracerebral hemorrhage | | | 29/21 | 3.5/2.5 per 10000 yr | RR 1.39(0.79–2.44) | .25
| Subarachoid hemorrhage | | | 45/40 | 5.5/4.9 per 10000 yr | RR 1.13 (0.74–1.73) | .57
| Death from Subarachoid hemorrhage | | | 15/23 | 1.8/2.8 per /61/1 per 10000 yr | RR 0.65 (0.34–1.25) | .20
| Cerebral infarction | | | 415/392 | 50.7/47.6 per 10000 yr | RR 1.07 (0.93–1.22) | .36
| Death from Cerebral infarction | | | 35/30 | 4.3/3.6 per 10000 yr | RR 1.17 (0.72–1.91) | .52
| All strokes | | | 554/503 | 67.7/61.1 per 10000 yr | RR 1.29 (0.94–1.76) | .11
| Death from all strokes | | | 82/78 | 10.0/9.5 per 10000 yr | RR 1/06 (0.78–1.44) | .72
CARET
Omenn, 1996b^93^ | CV death | Vitamin A + beta-carotene | 9420/8894 | | NR | RR 1.26 (0.99–1.61) | | ICD codes 459 and 798, by 9th revision
SCP
Greenberg, 1996^85^ | CV deaths | Beta-carotene | | 68/59 | NR | HR 1.15 (0.81–1.63), adjusted HR 1.16 (0.82–1.64) | 0.44, Adjusted 0.41 | Adjusted for age, sex, center, quetelet index, smoking; Persons with baseline serum β-carotene in the highest quartile had the lower risk of CV death [RR 0.52 (0.34–0.95)]
PHS
Liu, 1999^108^ | Type 2 DM | Beta-carotene | 10756/ 10712 | 396/402 | NR | RR 0.98 (0.85–1.12) | NR
Hennekens, 1996^95^ | MI | Beta-carotene | 11036/11035 | 468/489 | NR | RR 0.96 (0.84–1.09) | .50
| Stroke | | | 367/382 | | RR 0.96 (0.83–1.11) | .60
| All CV events | | | 967/972 | | RR 1.00 (0.91–1.09) | .90
| Death; CV causes | | | 338/313 | | RR 1.09 (0.93–1.27) | .28
PHS
Liu, 1999^108^ | Type 2 DM | Beta-carotene | 10756/ 10712 | 396/402 | NR | RR 0.98 (0.85–1.12) | NR
Hennekens, 1996^95^ | MI | Beta-carotene | 11036/11035 | 468/489 | NR | RR 0.96 (0.84–1.09) | .50
| Stroke | | | 367/382 | | RR 0.96 (0.83–1.11) | .60
| All important CV events | | | 967/972 | | RR 1.00 (0.91–1.09) | .90
| Death from CV causes | | | 338/313 | | RR 1.09 (0.93–1.27) | .28
WHS
Lee, 1999^96^ | MI | Beta-carotene | 19939/ 19937 | 42/50 | | RR 0.84 (0.56–1.27) | .41
| Stroke | | | 61/43 | | RR 1.42 (0.96–2.10) | .08
| All important CV events combined | | | 116/102 | | RR 1.14 (0.87–1.49) | .34
| Death from CV causes | | | 14/12 | | RR 1.17 (0.54–2.53) | .69
Linxian General Population Study
Mark, 1998^66^ | Stroke deaths | Retinol + zinc | | | | RR 0.99 (0.84–1.18) | NA
Eye Disease
ATBC
Teikari, 1997^109^ | Nuclear cataract | Beta-carotene | 469/428 | 55/51 | NA | OR 0.9 (0.5–1.6) | | All ORs adjusted
| | Alpha-tocopherol + beta-carotene | 475/428 | 65/51 | | OR 1.2 (0.7–2.1)
| Cortical cataract | Beta-carotene | 469/428 | 102/86 | | OR 1.2 (0.8–1.9)
| | Alpha-tocopherol + beta-carotene | 475/428 | 108/86 | | OR 1.3 (0.8–1.9)
| Posterior subcapsular cataract | Beta-carotene | 469/428 | 21/25 | | OR 0.7 (0.3–1.5)
| | Alpha-tocopherol + beta-carotene | 475/428 | 34/25 | | OR 1.1 (0.5–2.2)
Teikari, 1997 ^110^ | ARM | Beta-carotene vs. no beta-carotene | 491/450 | 141/128 | NA | 1.04 (0.74–1.47)
Linxian General Population Study
Sperduto, 1993^65^ | Nuclear cataracts | Retinol and zinc | | | NA | OR 0.77 (0.58–1.02)
| Posterior subcapsular cataracts | | | | | OR 0.59 (0.31–1.14)
| Cortical cataracts | | | | | OR 1.08 (0.92–1.27)

ATBC = Alpha-tocopherol Bata-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; NSCP = Nambour Skin Cancer prevention Trial; SCP = Skin Cancer prevention Study; PHS = Physicians Health Study; WHS = Women's Health Study; OR = odds ratio; RR = relative risk; HR = hazard ratio; 95% CI = 95 confidence interval; CV = cardiovascular; cum = cumulative; MI = myocardial infraction; DM = diabetes mellitus; ARM = age-related maculopathy; ANOVA = analysis of variance; py = person-year

Evidence Table 3e. Total mortality in studies of vitamin A and/or beta-carotene used to prevent chronic disease

Author, year | Study supplement | Total number in study (active/ placebo) | Number of disease events (active/ placebo) | Incidence per 1000 person-years (active/placebo) | Unadjusted estimates (point estimate and 95% CI) | P-value | Comments
ATBC
ATBC, 1994^97^ | Beta-carotene | 14573/14560 | NR | NR | RR 1.08 (1.01–1.16) | .02
SCP
Greenberg, 1996^85^ | Beta-carotene | NR | 146/139 | NR | HR 1.05 (0.83–1.32) | .71 | Adjusted for age, sex, center, quetelet index, smoking.
WHS
Omenn, 1996b ^93^ | Beta-carotene | 19939/19937 | 59/55 | NR | RR 1.07 (0.74–1.56) | .7 | Adjusted for age, randomized aspirin assignment, and randomized vitamin E assignment.
CARET
Omenn, 1996b ^93^ | Vitamin A; beta-carotene. | 9420/8894 | NR | 14.45/11.91 | RR 1.17 (1.03–1.33) | .02
Gooodman, 2004^94^ | Vitamin A; beta-carotene. | 8744/8396 | 1225/1047 | NR | RR 1.08 (0.99–1.17) | .07
Linxian General Population Study
Mark, 1998^66^ | Retinol + zinc | | 265/280 | 14.1/15.0 per 1000 py | RR 0.94, CI (0.79–1.11)
| Retinol + zinc vs. placebo | | 296/280 | 15.8/15.0 per 1000 py | RR 1.05, CI (0.89–1.24)
| Retinol + zinc | | | | RR 1.00 (.92–1.09) | NA

ATBC = Alpha-tocopherol Bata-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; SCP = Skin Cancer prevention Study; WHS = Womens Health Study; CI = confidence interval; RR = relative risk; AREDS = Age-Related Eye Disease Study; NR = not reported; HR = hazard ratio; ATBC = Alpha-Tocopherol, Beta Carotene Cancer Prevention Trial; CARET = Beta Carotene and Retinol Efficacy Trial.

Evidence Table 3f. Characteristics of the studies on the efficacy of vitamin E (singly or paired) in preventing chronic disease

Author, year | Study design | Study period | Exclusion criteria | Total sample size enrolled | Mean/ median follow-up time | Study site | Recruitment setting
ATBC
Varis, 1998^90^ | RCT; Factorial design | 1985-1993 | Not 50–69; female; any previous or current cancer; symptomatic CV disease, CHD or major ischemic change in their ECG; atrophic gastritits at baseline or after 3-yr follow-up; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; not smoking 5 or more cigarettess/day at entry; anti-coagulant use. | 1344 | 5–8 years (total), 3.9 years (median, Helsinki), 5.8 years (median, outside Helsinki). | Finland | Community
Albanes, 1996^98^ | | | Not 50–69; female; any previous or current cancer; symptomatic CV disease, CHD or major ischemic change in their ECG; atrophic gastritits at baseline or after 3-yr follow-up; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; not smoking 5 or more cigarettess/day at entry; anti-coagulant use. | 1344 | 5–8 years (total), 3.9 years (median, Helsinki), 5.8 years (median, outside Helsinki).
Albanes, 2000^102^ | | | Not 50–69; female; not smoking 5 or more cigarettess/day at entry; cancer; serious illness; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses (>20 mg, >20000 IU, or >6mg); anti-coagulant use. | 29133 | 5–8 years (total)
ATBC, 1994^97^ | | | Not 50–69; female; any cancer except non-melanoma skin; chronic renal insufficiency; liver cirrhosis; chronic alcoholism; medical condition limiting participation; severe angina; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses. | 29133 | 6.1 years (median)
Rautalahti, 1999^99^ | | | Not 50–69; female; cancer; serious diseases; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; nonsmokers). | 29133 | 5–8 years (total), 6.1 years (median).
Heinonen, 1998^101^ | | | Not 50–69; female; cancer; serious diseases; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; not smoking 5 or more cigarettess/day at entry | 29133 | 5–8 years (total), 6.1 years (median).
Rapola, 1996^106^ | | | MI; any history of CHD at baseline and same criteria as general ATBC trial. | 22269 | 4.7 years (median)
ATBC
Lappala, 2000******^107^ | | | Not 50–69; female; cancer; serious diseases; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; not smoking 5 or more cigarettes/day at entry; anti-coagulant use | 28519 | 6.0 years (median)
Teikari, 1997^109^ | | | Not 50–69; female; cancer; serious diseases; vitamin E, vitamin A, and/or beta carotene in excess of predefined doses; nonsmokers). | 1828 | 6.6 years (median)
WHS
Lee, 2005^87^ | RCT, factorial design | 1992-2004 | All cancers except nonmelanoma skin cancer; all other major chronic disease; vitamin A, vitamin E, beta-carotene, aspirin, or NSAID use greater than once weekly; history of adverse effects from aspirin; use of anticoagulants; use of corticosteroids. | 39876 | 10.1 years (mean) | USA (nation-wide) | Health care professsionals
Lee, 1999^96^ | RCT, placebo controlled trial | 1993-1999 | Male; <45 years; cancer; coronary disease or cerebrovascular disease | 39876 | 4.1 years (median) | USA (nation-wide) | Women health study
PPP
DeGaetano, 2001^112^ | RCT; factorial design | 1994-1998 | Disease with poor short-term prognosis; history of vascular events or or disease; chronic use of vitamin E, antiinflammatory agents, anticoagulants, aspirin; predictable psychological or logistical difficulties affecting compliance. | 4495 | 3.6 years (mean) | Italy | Clinical
Sacco, 2003^181^ | | | | 1031 | 3.7 years (median)
VECAT
McNeil, 2004^113^ | RCT; placebo controlled trial | 1995-2000 | MI or type II diabetes in the previous 6 months; prior cataract surgery; advanced cataract in both eyes; glaucoma; major psychiatric illness; uncontrolled hypertension; terminal illness; continued use of vitamin E supplements; vitamin E sensitivity; long-term steroid or anti-coagulation treatment; bilateral intraocular pressure >22; inadequate pupillary dilation (<6.5mm). | 1193 | 4 years (total) | Melbourne, Australia | Clinical and community
CARET
Goodman, 2004^94^ | RCT (Post-inter-vention follow up) | 1985-1996 | Asbestos arm: not 45–74 years old in pilot period or 45–69 yrs in vanguard; smoking arm: not 50–69 yrs, male; any history of cancer except non-melanoma skin cancer in past 5 years; NASH; NAFLD; asbestos arm: no chest X-ray evidence of asbestos interstitial lung disease or not greater than or equal to 5 years high risk trade, SGOT or alkaline phosphate greater than 2.5x and 1.5x 95th percentile of normal, respectively, history of liver disease in past 12 months, any beta-carotene supplementation; smoking arm: < 20 pack-year smoking history, current or quit in past 6 years; smoking arm: premenopausal; asbestos arm: < 15 years since first occupational exposure. | 17140 | 5.9 years (total) | Seattle, Washington; Portland, Oregon; San Francisco, CA; Baltimore, MD; New Haven Conn; Irvine, CA. | Clinical and community

ATBC = Alpha-tocopherol Beta-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; WHS = Womens Health Study; PPP = Primary prevention Project; VECAT = Vitamin E and Cataract Randomized Controlled Trial.

Evidence Table 3g. Characteristics of the intervention in the studies of the efficacy of vitamin E in the prevention of chronic disease

Author, year | Control arm | Intervention | Chemical form | Dose/Frequency of use | Timing of use | Duration of use
ATBC
Varis, 1998^90^ | Placebo | Vitamin E; beta-carotene | dl-alpha-tocopherol; beta-carotene | 50 mg/1x/day; 20 mcg/1x/day | NS | 5.1 years; 3.9 years (Helsinki) and 5.4 years (outside)
Albanes, 1996^98^ | | | | | | 5.1 years; 3.9 years (Helsinki) and 5.4 years (outside)
Albanes, 2000^102^ | Placebo | Vitamin E; beta-carotene | dl-alpha-tocopherol; beta-carotene | 50 mg/1x/day; 20 mcg/1x/day | NS | 5–8 years
ATBC, 1994^97^ | | | | | | 6.1 years median
Rautalahti, 1999^99^ | | | | | | 6.1 years
Heinonen, 1998^101^ | | | | | | 6.1 years median
Rapola, 1996^106^ | | | | | | 4.7 years median
Lappala, 2000^107^ | | | | | | 6.0 years median
Teikari, 1997^109^ | | | | | | 5.1 years; 3.9 years (Helsinki) and 5.4 years (outside)
WHS
Lee, 2005^87^ | Placebo | Vitamin E | alpha-tocopherol | 600 IU/every other day | NS | 10.1 years
Lee, 1999^96^ | Placebo | beta-carotene | NS | 50mg/every other day | NS | 2.1 years median
PPP
DeGaetano, 2001^112^ | Placebo | Vitamin E | synthetic alpha tocopherol | 300 mg/1x/day | NS | 3.6 months (mean)
Sacco, 2003181 | | Vitamin E | alpha tocopherol | | | 3.7 years
VECAT
McNeil, 2004^113^ | Placebo | Vitamin E | d-alpha-tocopherol | 335 mg/1x/day | NS | 4 years
CARET
Goodman, 2004^94^ | Placebo | Vitamin A; beta-carotene | | 25000 IU/1x/day; 30 mg/1x/day | NS | 10 years; Until endpoint (NS)

ATBC = Alpha-tocopherol Beta-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; WHS = Womens Health Study; PPP = Primary prevention Project; VECAT = Vitamin E and Cataract Randomized Controlled Trial; NS = Not specified; mg = milligram; mcg = microgram; IU = international unit; μg = microgram

Evidence Table 3h. Characteristics of participants in studies of the efficacies of Vitamin E (singly or in nutrient pairs)

Author, year | Mean age (SD), and/or range | Women, n (%); Ethnicity, n (%) | Smokers, n (%) | Alcohol consumption, n (%) | Mean BMI in kg/m2 | Prior supplement use, type (%)
ATBC
Varis, 1998^90^ | 64.8 | 0 (0); ethnicity NR | Current: 1828 (100) | Mean intake (grams/day): 12.5. | 25.5 | Vitamin E: 0 (0); vitamin A: 0 (0); beta-carotene: 0 (0).
Albanes, 1996^98^ | Median: 56.9 | 0 (0); ethnicity NR | Current: 22269 (100) | NR | 26.0 | Vitamin E: 0 (0); vitamin A: 0 (0); beta-carotene: 0 (0).
Albanes, 2000^102^ | 57.2 | 0 (0); ethnicity NR | Current: 29133 (100) | Mean intake (grams/day): 11.0 | 26.0 | Vitamin E: 0 (0); vitamin A: 0 (0); beta-carotene: 0 (0).
ATBC, 1994^97^ | 64.2 (7.5) | 534 (51.8); ethnicity NR | Former: 257 (25.2); current: 168 (16.5). | NR | 29.0 | NR
Rautalahti, 1999^99^ | 53.0 (9.5); range: 40–84. | 0 (0); ethnicity NR | Never: 11036 (50); former: 8608 (39); current 2428 (11.0). | Rare: 3222 (14.6%); monthly: 2428 (11.0); weekly: (49.5); daily: 5518 (25.0). | 24.9 | Current multivitamin use: 4304 (19.5).
Heinonen, 1998^101^ | 57.2 | 0 (0); ethnicity NR | Current: 29133 (100) | Mean intake (grams/day): 11.0 | 26.0 | Vitamin E: 0 (0); vitamin A: 0 (0); beta-carotene: 0 (0).
Rapola, 1996^106^ | Median: 57; range: 50–69. | 0 (0); ethnicity NR | Current: 29133 (100) | Mean intake (grams/day): 11.0 | 26.0 | Vitamin E: 0 (0); vitamin A: 0 (0); beta-carotene: 0 (0).
Lappala, 2000 ^107^ | 57.7 | 0 (0); ethnicity NR | Current: 28519 (100) | Mean intake (grams/day): 18.1 | 26.3 | Vitamin E: 0 (0); vitamin A: 0 (0); beta-carotene: 0 (0).
Teikari, 1997^109^ | Median: 57; range: 50–69. | 0 (0); ethnicity NR | Current: 29133 (100) | Mean intake (grams/day): 11.0. | 26.0 | Vitamin E: 0 (0); vitamin A: 0 (0); beta-carotene: 0 (0).
WHS
Lee, 2005^87^ | 58.8 | 0 (0); ethnicity NR | Current: 1344 (100) | Mean intake (grams/day): 8.9. | NR | Vitamin E: 0 (0); vitamin A: 0 (0); beta-carotene: 0 (0).
Lee, 1999^96^ | NA | 39876 (100); ethnicity NR | NA | NA | NA | NA
PPP
DeGaetano, 2001^112^ | Median: 48 | (50); ethnicity NR | Current: (36) | Current: (37.0) | NR | NR
Sacco, 2003^181^ | 64.4 (7.6) | 1912 (42); ethnicity NR | Former: 1080 (24); current: 667 (15). | NR | 27.6 | NR
VECAT
McNeil, 2004^113^ | 65.7 | 670 (56); ethnicity NR | Current: 24 (2); ever: 577(48) | NA | >=27: 468 (39) | Vitamin E: 289 (24)
CARET
Goodman, 2004^94^ | 62 | 6007 (35); Caucasian, 15988 (93.3) | Never: 116 (0.7); former: 8988 (52.4); current: 8036 (46.9). | NR | NR | NR

ATBC = Alpha-tocopherol Bata-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; WHS = Womens Health Study; PPP = Primary prevention Project; VECAT = Vitamin E and Cataract Randomized Controlled Trial; BMI = Body Mass Index; NR = not reported

Evidence Table 3i. Results of studies of the efficacy of vitamin E in preventing chronic disease

Author, year | Disease endpoint | Study supplement | Total Number in study (active/non-active) | Number of disease events (active/non-active) | Incidence of disease endpoint (active/non-active) | Unadjusted estimates (95% CI) | P-value | Comments
Cancer
ATBC
Varis, 1998^90^ | Gastric dysplasia, carcinoma, or carcinoid | Alpha-tocopherol | 321/333 | 13/18 | NR | NR
| | Alpha-tocopherol + beta-carotene | 361/333 | 19/18
| | Alpha-tocopherol vs. no alpha-tocopherol | 682/662 | 32/31 | | RR 1.00 (0.60–1.66) | | Adjusted RR 0.98 (0.57–1.69)
Albanes, 1996^98^ | Lung cancer | Alpha-tocopherol vs. no alpha-tocopherol | 14564/14569 | 444/450 | 53.2/54.5 per 10000 person years | RR 0.99 (0.87–1.13) | 0.86 | No effect of α-tocopherol in subgroups defined by age, cigarettes smoking, years of cigarette smoking, cigarette smoke inhalation, asbestos exposure, dietary intake of vitamin E, β-carotene, vitamin C, retinol, or alcohol as ethanol, and serum levels of α-tocopherol, β-carotene, and retinol
Albanes, 2000^102^ | Colorectal cancer | Alpha-tocopherol vs. placebo | 7286/7287 | 29/37 | NR | RR 0.79 (0.48–1.28)
| | Alpha-tocopherol vs. no alpha-tocopherol | 14564/14569 | 59/76 | NR | RR 0.78 (0.55–1.09) | 0.15 | P-value from log-rank test
| | Alpha-tocopherol + beta-carotene | 7278/7287 | 30/37 | NR | RR 0.82 (0.50–1.31)
| Colorectal cancer mortality | Alpha-tocopherol vs. no alpha-tocopherol | 14564/14569 | 22/24 | NR | RR 0.92 (0.51–1.64)
ATBC, 1994^97^ | Lung cancer | Alpha-tocopherol | 14564/14564 | 433/443 | 51.3/52.4 per 10000 person year | RR 0.98 (0.86–1.12) | 0.8
| Lung cancer mortality | Alpha-tocopherol | 14564/14564 | 285/279 | 33.6/32.6 per 10000 person year | RR1.03 | | Confidence interval NR
Rautalahti, 1999^99^ | Pancreatic cancer | Alpha-tocopherol vs. no alpha-tocopherol | 14564/14569 | 51/38 | 0.60/0.45 per 1000 person year | RR 1.34 (0.88–2.05)
| Carcinoma of the pancreas | Alpha-tocopherol | 7286/7287 | 25/26 | NR | RR 0.94 (0.56–1.67)
| Pancreatic cancer mortality | Alpha-tocopherol vs. no alpha-tocopherol | 14564/14569 | 49/34 | NR | RR 1.11 (0.72–1.72)
Malila, 1999^100^ | Colorectal Adnomas | Alpha-tocopherol vs. no alpha-tocopherol | 7768/7770 | 81/56 | NR | RR 1.66 (1.19–2.32) | 0.003 | Results did not change after excluding 15 cases with a prior history of polyps (RR 1.63)
Heinonen, 1998^101^ | Prostate cancer | Alpha-tocopherol | 7286/7287 | 43/67 | NR | RR 0.64 (0.44–0.94)
| | Alpha-tocopherol + beta-carotene | 7278/7287 | 56/67 | NR | RR 0.84 (0.59–1.20)
| | Alpha-tocopherol vs. no alpha-tocopherol | 14564/14569 | 99/147 | NR | RR 0.68 (0.53–0.88) | 0.002
| Prostate Cancer mortality | Alpha-tocopherol vs. no alpha-tocopherol | 14564/14569 | 23/39 | NR | RR 0.59 (0.35–0.99)
WHS
Lee, 2005^87^ | Total invasive cancer | Vitamin E | 19937/19939 | 1437/1428 | NR | RR 1.01 (0.94–1.08) | 0.87
| Breat cancer | | | 616/614 | | RR 1.00 (0.90–1.12) | 0.95
| Lung cancer | | | 107/98 | | RR 1.09 (0.83–1.44) | 0.52
| Colon cancer | | | 107/107 | | RR 1.00 (0.77–1.31) | 0.99
| Cancer death | | | 308/275 | | RR 1.12 (0.95–1.32) | 0.17
Cardiovascular Disease
ATBC
Rapola, 1996^106^ | Angina | Alpha-tocopherol vs. no alpha-tocopherol | 11118/11351 | 948/1035 | 19.6/21.5 per 1000 py | RR 0.91 (0.83–0.99)
| | Alpha-tocopherolalone | 5570/5549 | 476/487 | 19.7/20.2 per 1000 py | RR 0.97 (0.85–1.10)
| | Alpha-tocopherol + beta-carotene | 5548/5549 | 472/487 | 19.6/20.2 per 1000 py | RR 0.96 (0.85–1.09)
Lappala, 2000^107^ | Intracerebral hemorrhage | Alpha-tocopherol vs. no alpha-tocopherol | 14238/14281 | 57/55 | 7.0/6.7 per 10000 py | RR 1.04 (0.72–1.51) | 0.84
| Death from Intracerebral hemorrhage | | | 31/19 | 3.8/2.3 per 10000 py | RR 1.64 (0.93–2.90) | 0.09
| Subarachoid hemorrhage | | | 51/34 | 6.2/4.1 per 10000 py | RR 1.50 (0.97–2.32) | 0.07
| Death from Subarachoid hemorrhage | | | 28/10 | 3.4/2.1 per 10000 py | RR 2.81 (1.37–5.79) | 0.005
| Cerebral infarction | | | 373/434 | 45.5/52.8 per 10000 py | RR 0.86 (0.75–0.99) | 0.03
| Death from Cerebralinfarction | | | 29/36 | 3.5/4.4 per 10000 py | RR 0.81 (0.49–1.32) | 0.39
| All strokes | | | 509/548 | 62.1/66.6 per 10000 py | RR 0.93 (0.83–1.05) | 0.25
| Death from all strokes | | | 90/70 | 11.0/8.5 per 10000 py | RR 1.29 (0.94–1.76) | 0.11
WHS
Lee, 2005^87^ | Combined first major CV event | Vitamin E | 19937/19939 | 482/517 | NR | RR 0.93 (0.82–1.05) | 0.26
| MI | | | 196/195 | | RR 1.01 (0.82–1.23) | 0.96
| Nonfatal MI | | | 184/181 | | RR 1.02 (0.83–1.25) | 0.87
| Fatal MI | | | 12.0/14 | | RR 0.86 (0.40–1.85) | 0.7
| Stroke | | | 241/246 | | RR 0.98 (0.82–1.17) | 0.82
| Nonfatal stroke | | | 220/222 | | RR 0.99 (0.82–1.19) | 0.93
| Fatal stroke | | | 21/24 | | RR 0.88 (0.49–1.57) | 0.66
| Ischemic stroke | | | 194/197 | | RR 0.99 (0.81–1.20) | 0.88
| Hemorrhagic stroke | | | 44/48 | | RR 0.92 (0.61–1.38) | 0.68
| Cardiovascular death | | | 106/140 | | RR 0.76 (0.59–0.98) | 0.03
PPP
DeGaetano, 2001^112^ | CV deaths, non fatal MI and non-fatal stroke | Vitamin E | | 56/53 | | RR 1.07 (0.74–1.56)
| Total CV events/diseases | | | 158/170 | | RR 0.94 (0.77–1.16)
| CV Deaths | | | 22/26 | | RR 0.86 (0.49–1.52)
| Non-CV deaths | | | 50/42 | | RR 1.21 (0.80–1.81)
| All MI | | | 22/25 | | RR 0.89 (0.52–1.58)
| Non-fatal MI | | | 19/18 | | RR 1.01 (0.56–2.03)
| All Stroke | | | 22/18 | | RR 1.24 (0.66–2.31)
| Non fatal Stroke | | | 20/13 | | RR 1.56 (0.77–3.13)
| TIA | | | 33/35 | | RR 0.96 (0.60–1.53)
| PAD | | | 16/30 | | RR 0.54 (0.30–0.99) | 0.043
| Revascularization procedures | | | 27/22 | | RR 1.25 (0.71–2.18)
| Anginapectoris | | | 66/55 | | RR 1.22 (0.86–1.73)
Sacco, 2003^182^ | CV deaths, nonfatal MI and non-fatal stroke | Vitamin E vs. placebo | 509/522 | 22/20 | | RR 1.13 (0.62–2.04) | | No significant effects in persons without diabetes at baseline except a reduction in the risk of peripheral artery disease (RR 0.37, 95% CI 0.14–0.96)
| Total CV events | In persons with type 2 diabetes | | 51/61 | | RR 0.86 (0.60–1.22)
| CV deaths | | | 10/8 | | RR 1.28 (0.51–3.22)
| Non CV deaths | | | 13/14 | | RR 0.95 (0.45–2.01)
| All MI | | | 7/8 | | RR 0.90 (0.33–2.46)
| All stroke | | | 8/11 | | RR 0.75 (0.30–1.83)
| Angina pectoris | | | 14/15 | | RR 0.93 (0.45–1.90)
| TIA | | | 6/11 | | RR 0.54 (0.21–1.43)
| PAD | | | 8/14 | | RR 0.71 (0.32–1.58)
| Revascularisation procedure | | | 9/9 | | RR 1.00 (0.40–2.48)
Eye Disease
VECAT
McNeil, 2004^113^ | Cortical cataract | Vitamin E | 442/442 | 19/22 | 4.5%/5% | 0.9 (0.5–1.6) | 0.75 | Incidence of cataract
| Nuclear cataract | | 480/486 | 62/59 | 12.9%/12.1% | 1.1 (0.8–1.5) | 0.77
| Posterior subcapsular cataract | | 479/486 | 8/17 | 1.7%/3.5% | 0.5 (0.2–1.1) | 0.08
| Any cataract | | 409/430 | 70/72 | 17.1%/16.7% | 1.0 (0.8–1.4) | 0.92
| Cortical cataract | | 156/147 | 26/27 | 16.7%/18.4% | 0.9 (0.5–1.6) | 0.76 | Progression of lens opacities
| Nuclear cataract | | 501/503 | 57/60 | 11.4%/11.9% | 0.9 (0.7–1.3) | 0.84
| Posterior subcapsular cataract | | 18/18 | 5/2 | 28%/10% | 2.5 (0.6–11.2) | 0.2
| Any cataract | | 504/508 | 83/85 | 16.5%/16.7% | 1.0 (0.7–1.3) | 0.93
ATBC
Teikari, 1997^109^ | Nuclear cataract | Alpha-tocopherol | 456/428 | 51/51 | NA | OR 0.8 (0.4–1.4) | | Adjusted OR
| | Alpha-tocopherol + beta-carotene | 475/428 | 65/51 | | OR 1.2 (0.7–2.1)
| Cortical cataract | Alpha-tocopherol | 456/428 | 90/86 | | OR 0.9 (0.6–1.4)
| | Alpha-tocopherol + beta-carotene | 475/428 | 108/86 | | OR 1.3 (0.8–1.9)
| Posterior subcapsular cataract | Alpha-tocopherol | 456/428 | 25/25 | | OR 0.9 (0.4–1.8)
| | Alpha-tocopherol + beta-carotene | 475/428 | 34/25 | | OR 1.1 (0.5–2.2)
Teikari, 1998^110^ | Age-related maculopathy | Alpha-tocopherol vs. no alpha-tocopherol | 492/447 | 148/121 | | OR 1.13 (0.81–1.59)

ATBC = Alpha-tocopherol Bata-carotene Prevention Study; CARET = Beta-carotene and Retinol Efficacy Trial; WHS = Women's Health Study; PPP = Primary prevention Project; VECAT = Vitamin E and Cataract Randomized Controlled Trial; OR = odds ratio; 95% CI = 95 confidence interval; py = person years; CV = cardiovascular; cum = cumulative; PSA = prostate-specific antigen; MI = myocardial infraction; ANOVA = analysis of variance; TIA = Transient ischemic attacks; PAD = peripheral artery disease

Evidence Table 3j. Total mortality in studies of vitamin E used to prevent chronic disease

Author, year | Study supplement | Total number in study (active/ placebo) | Number of disease events (active/ placebo) | Person years (active/ placebo) | Incidence per 1000 person-years (active/placebo) | Unadjusted estimates (point estimate and 95% CI) | P-value
ATBC, 1994^97^ | Alpha-tocopherol vs. placebo | 14564/14564 | NR | NR | NR | RR 1.02 (0.95–1.09) | 0.6
Lee, 2005^87^ | Vitamin E | 19937/19939 | 636/615 | NR | NR | 1.04 (0.93–1.16) | 0.53
DeGaetano, 2001^112^ | Vitamin E | 2231/2264 | 72/68 | NR | NR | RR 1.07 (0.77–1.49) | NR
Sacco, 2003^181^ | Vitamin E | 509/522 | 23/22 | NR | NR | RR 1.07 (0.61–1.90) | NR

CI = confidence interval; RR = relative risk; NR = not reported; WHS = Women's Health Study; ATBC = Alpha-Tocopherol, Beta Carotene Cancer Prevention Trial; PPP = Primary Prevention Project.

Evidence Table 3k. Characteristics of the studies on the efficacy of selenium, B vitamins, or other single nutrients (singly or paired) in preventing chronic disease

Author, year | Nutrient(s) | Study design | Study period | Exclusion criteria | Total sample size enrolled | Mean/ median follow-up time | Study site | Recruitment setting
NCP
Calrk, 1996^133^ | Selenium | RCT; Placebo controlled | 1983-1993 | History of 2 or more BCC or 1 SCC of the skin, with 1 of these carcinomas occurring within the prior year; liver or kidney disease history; internal malignancies treated within the previous 5 years; life expectancy not greater than 5 years; female; no non-melanoma skin cancer; life expectancy not greater than 5 years; reported internal malignancies treated within the previous 5 years | 974–1312 | 10 years (total), 6.4 years (mean) | Eastern USA | Clinical
Calrk, 1998^134^
Reid, 2002^135^ | | | | Not having valid baseline plasma selenium value collected on day of randomization +/-4 days; no noncutaneous malignancy within previous 5 years. | 1250 | 13 years (total), 7.9 years (mean) | Eastern USA | Clinical
Duffield-Lillico, 2002^136^ | | | | History of 2 or more BCC or 1 SCC of the skin, with 1 of these carcinomas occurring within the prior year; liver or kidney disease history; internal malignancies treated within the previous 5 years; life expectancy not greater than 5 years; Not having valid baseline plasma selenium value collected on day of randomization +/-4 days; no noncutaneous malignancy within previous 5 years; not NPC participant; female; Initial blood not drawn within first 4 days of randomization; history of prostate cancer | 927–1250 | 13 years (total), selenium 7.6 years (mean), placebo 7.3 years (mean), 7.4 years (mean) | Eastern USA | Clinical
Linxian General Populatiton Study
Mark, 1998^66^ | Vitamin A + zinc; riboflavin + niacin; vitamin C + molyb-denum | RCT; Factorial design | 1986-1991 | Not 40–46 years old; history of cancer; history of debilitating diseases. | 29584 | 5 years (total) | Linxian province, China | Community
Sperduto, 1993^64^ | | | | Not 40–69; stomach or esophageal; debilitating disease; does not live in one of 4 communes in Linxian | 29584 | 5.25 years (total)
Other Study
Yu, 1991^139^ | | | | Not in Qidong county; Not HBVsAg carrier; Abnormal liver function; not a member of family with hereditary predisposition to cancer | 226–2474 | 2–4 years (total) | Qidong County, China | Community

NPC = Nutritional Prevention of Cancer Study Group; ARED = Age-related Eye Disease Study Group.

Evidence Table 3l. Characteristics of the intervention in the studies of the efficacy of other nutrients in the prevention of chronic disease

Author, year | Contorl Arm | Interventnion | Chemical form | Dose/Frequency of use | Timing of use | Duration of use
NPC
Clark, 1996^133^ | Placebo | Selenium | Selenium yeast | NS | NS | 4.3 years
Clark, 1998^134^ | Placebo | Selenium | Selenium yeast | NS | NS | 4.4 years
Reid, 2002^135^ | Placebo | Selenium | Selenium yeast | 200 mcg/1x/day | NS | 7.9 years
| | | | | NS
Duffield-Lillico, 2002^136^ | Placebo | | Yeast | NS | NS | NS
| | Selenium | Selenium yeast | 200 mcg/1x/day | NS | NS
Duffield-Lillico, 2003^137^ | Placebo | | Yeast | NS | NS | NS
| | Selenium | Selenium yeast | 200 mcg/1x/day | NS | NS
Linxian General Population Study
Mark, 1998^66^ | Placebo | Placebo 1 | | | NS | 5 years
| | Vitamin A | Retinol palmitate | 10000 IU/NS
| | Zinc | Zinc oxide | 45 mg/NS
| | Vitamin B2 | Riboflavin | 5.2 mg/NS
| | Niacin | Niacin | 40 mg/NS
| | Vitamin C | Ascorbic acid | 180 mg/NS
| | Molybdenum | Yeast complex | 30 mg/NS
Sperduto, 1993^64^ | Placebo 1
| | Vitamin A | Retinol palmitate | 5000 IU/daily | NS | 5.25 years
| | Zinc | Zinc oxide | 22.5 mg/daily
| | Vitamin B2 | Riboflavin | 3.2 mg/1x/day
| | Niacin | Niacin | 40 mg/1x/day
| | Vitamin C | Ascorbic acid | 120 mg/1x/day
| | Molybdenum | Molybendum | 30 mcg/1x/day
ARED
AREDS, 2001b^75^ | Placebo 1 | | | NS | NS | 6.3 years
| | Vitamin E | Dl-alpha-tocopherol acetate | 200 IU/2x/day (2 tablets in the morning, 2 in the evening) | With meals
| | Vitamin C | Ascorbic acid | 250 mg/2x/day (2 tablets in the morning, 2 in the evening)
| | Vitamin A | Beta-carotene | 7.5 mg/2x/day (2 tablets in the morning, 2 in the evening)
| | Zinc | Zinc oxide | 40 mg/2x/day (2 tablets in the morning, 2 n the evening)
| | Selenium | Selenium yeast | 200 mcg/1x/day | | 4.5 years
Other Study
Yu, 1991^139^ | Placebo 1 | | Trial 2 control group (plain yeast tablet) | NS | NS | 4 years
| Placebo 2 | | Trial 3 control group (placebo, undefined) | NS | NS | 2 years
| | Selenium | Selenium yeast | 200 mcg/1x/day | NS | 2–4 years

NPC = Nutritional Prevention of Cancer Study Group; ARED = Age-related Eye Disease Study Group; NS = Not specified; mg = milligram; mcg = microgram; IU = international unit

Evidence Table 3m.Characteristics of participants in studies of the efficacies of selenium, B vitamins or other nutrients (singly or in nutrient pairs)

Author, year | Mean age (SD), and/or range | Women, n (%); Ethnicity, n (%) | Smokers, n (%) | Alcohol consumption, n (%) | Mean BMI in kg/m2 | Prior supplement use, type (%)
NPC
Clark, 1996^133^ | 63.2; range: 18–80. | 332 (25.3); ethnicity, NR | Never: 428 (32.6); former: 514 (39.2); current: 369 (28.2). | NR | NR | NR
Clark, 1998^134^ | 63.8 | 0 (0); ethnicity, NR | NR | NR | NR
Reid, 2002^135^ | 63.2 (10.0) | 316 (25.0); ethnicity, NR | Never: 398 (31.8); former: 497 (39.8); current: 355 (28.4). | Mean drinks/week: 12.9. | NR
Duffield-Lillico, 2002^136^ | 63.2; range: 18–80. selenium: 63.4 (10.2); placebo 63 (9.9) | 332 (25.3); ethnicity, NR | Never: 428 (32.6); former: 514 (39.2); current: 369 (28.2). | NR | 25.5
Duffield-Lillico, 2003^137^ | 64.4; selenium: 64.9 (8.8); placebo 63.7 (9.4) | 0 (0); ethnicity, NR | Never: 213 (23); former: 431 (46.5); current: 283 (30.5). | NR | 25.9
Linxian General Population Study
Mark, 1998^66^ | Median (female) 51; median (male): 53; range: 44–60. | 16271 (55); ethnicity, NR | Current (female): 3254 (20); current (male): 8929 (67). | Current (female): (10); current (male): (40). | Median BMI (female): 21.9; median BMI (male): 21.6. | NR
Sperduto, 1993^64^ | <50: 12425 (42%); 50–59: 10354 (35%); ≥60: 6804 (23%). | | Never: 20709 (70); ever smoked for >6 months: 8875 (30). | Never: 22780 (77); any use in past 12 months: 6804 (23). | NR
ARED
AREDS, 2001b^75^ | Median: 69 | 2021 (56); Caucasian, 3483 (96); African-American, 153 (3) | Former: 1751 (49); current: 298 (8.0). | NR | NR | Multivitamin or supplement containing a study compound: 2047 (57); Centrum: 2418 (67).
Other Study
Yu, 1991^139^ | Range: 21–63; Range: 15–75 | NR; Asian (100) | NR | NR | NR

NPC = Nutritional Prevention of Cancer Study Group; ARED = Age-related Eye Disease Study Group; BMI = Body Mass Index; NR = not reported.

Evidence Table 3n. Results of studies of the efficacy of other single or paired nutrients in preventing chronic disease

Author, year | Disease endpoint | Study supplement | Total Number in study (active/ placebo) | Number of disease events (active/ placebo) | Incidence of disease endpoint (arm1/arm2) | Unadjusted estimates (95% CI) | P-value | Comments
Cancer
NPC
Clark, 1996^133^ | Lung cancer | Selenium | 653/659 | 17/31 | | HR 0.56 (0.31–1.01) | .05 | Lung cancer mortality
| Prostate cancer | | | 13/35 | | HR 0.35 (0.18–.65) | .001
| Colorectal cancer | | | 8/19 | | HR 0.39 (0.17–0.90) | .03
| Head and neck | | | 6/8 | | HR 0.77 (0.27–2.24) | .64
| Bladder | | | 8/6 | | HR 1.27 (0.44–3.67) | .66
| Esophageal | | | 2/6 | | HR 0.30 (0.06–1.49) | .14
| Breast | | | 9/3 | | HR 2.95 (0.80–10.9) | .11
| Other specific carcinomas | | | 5/9 | | HR 0.54 (0.18–1.62) | .27
| Total carcinomas | | | 59/104 | | HR 0.54 (0.39–0.75) | <.001
| Melanomas | | | 8/8 | | HR 0.92 (0.34–2.45) | .87
| Leukemia/ lymphomas | | | 8/5 | | HR 1.50 (0.49–4.60) | .48
| Other specific non-carcinomas | | | 3/3 | | HR 0.99 (0.20–4.94) | .99
| Total non-carcinomas | | | 19/16 | | HR 1.16 (0.60–2.27) | .65
| Total cancer | | | 77/119 | | HR 0.61 (0.46–0.82) | <.001
| Total cancer mortality | | | 29/57 | | HR 0.48 (0.31–0.76) | .001
| Lung cancer mortality | | | 12/25 | | HR 0.47 (0.23–0.93) | .03
| Other carcinoma mortality | | | 15/25 | | HR 0.56 (0.30–1.07) | .08
Clark, 1998^134^ | Prostate cancer | Selenium | 479/495 | 13/35 | | RR 0.37 | .002
Reid, 2002^135^ | All lung cancer | Selenium | 621/629 | 25/35 | 0.063/0.085 | RR 0.70 (0.40–1.21); HR 0.74 (0.44–1.24) | .18 for RR; .26 for HR | Earlier publication from this trial (1983-1993 only showed RR 0.54 (0.30–0.98); this study adds 3 years of follow-up.
Duffield-Lillico, 2003^136^ | Prostate Cancer | Selenium | 621/629 | 22/42 | | RR 0.51 (0.29–0.87) | .009
| Lung Cancer | | | 25/35 | | RR 0.7 (0.4–1.21) | .18
| Colorectal Cancer | | | 9/19 | | RR 0.46 (0.19–1.08) | .055
| Cancer mortality | | | 40/66 | | RR 0.59 (0.39–0.89) | .008
| Head and neck cancer | | | 9/7 | | RR1.27 (0.42–4.01) | .65
| Bladder cancer | | | 10/8 | | RR 1.24 (0.44–3.61) | .66
| Esophageal cancer | | | 2/5 | | RR 0.39 (0.04–2.41) | .28
| Breast | | | 11/6 | | RR 1.82 (0.62–6.01) | .24
| Other specific carcinomas | | | 6/9 | | RR 0.66 (0.19–2.07) | .44
| Melanomas | | | 11/9 | | RR 1.21 (0.46–3.3) | .68
| Leukemia/ lymphomas | | | 40/66 | | RR 1.32 (0.4–4.61) | .62
Duffield-Lillico, 2002^137^ | Prostate cancer | Seleniu | 457/470 | 22/42 | | RR 0.51 (0.29–0.88) | .009
Linxian General Population Study
Blot, 1993^67^ | Gastric cancer incidence | Retinol + zinc | 539 total | | | RR 0.96 (0.81–1.14)
| | Riboflavin + niacin | | | | RR 1.04 (0.88–1.23)
| | Vitamin C + molybdenum | | | | RR 1.10 (0.92–1.30)
| Esophageal cancer incidence | Retinol + zinc | 640 total | | | RR 1.07 (0.92–1.25)
| | Riboflavin + niacin | | | | RR 0.86 (0.74–1.01)
| | Vitamin C + molybdenum | | | | RR 1.06 (0.91–1.24)
| Stomach cancer death | Retinol + zinc | 331 total | | | RR 1.03 (0.83–1.28)
| | Riboflavin + niacin | | | | RR 1.00 (0.81–1.24)
| | Vitamin C + molybdenum | | | | RR 1.09 (0.88–1.36)
| Stomach cancer incidence (noncardia) | Retinol + zinc | 331 total | | | RR .73 (0.49–1.08)
| | Riboflavin + niacin | | | | RR .92 (0.63–1.35)
| | Vitamin C + molybdenum | | | | RR 1.21 (0.82–1.78)
Other studies
Yu, 1991^139^ | Primary liver cancer | Selenium | 1444/1030 | 10/16 | 0.69% vs 1.26% | | <.05 | In Hep B carriers,
Cardiovascular Disease
NPC
Clark, 1996^133^ | CVD and cerebro-vascular diseases mortality | | | 47/46 | | HR 0.96 (0.64–1.44) | .83
| All other causes mortality | | | 32/26 | | HR 1.16 (0.69–1.95) | .57
| Respiratory disease mortality | | | 14/11 | | HR 1.26 (0.57–2.77) | .57
| All cause mortality | | | 108/129 | | HR 0.79 (0.61–1.02) | .07
Linxian General Population Study
Mark, 1998^66^ | Stroke deaths | Retinol + zinc + riboflavin + niacin | | | NA | RR .85 (.61–1.18) | NA
| | Retinol + zinc + vitamin C + molybdenum | | | | RR .91 (.66–1.27)
| | Riboflavin + niacin, vitamin C + molybdenum | | | | RR .78 (.55–1.09)
| | Retinol + zinc | | | | RR .99 (.84–1.18)
| | Riboflavin + niacin | | | | RR .94 (.79–1.11)
| | Vitamin C + molybdenum | | | | RR 1.04 (.88–1.24)
Eye Disease
Linxian Cataract Study
Sperduto, 1993^64^ | Cortical cataracts | Retinol + zinc | | | | OR 1.08 (0.92–1.27)
| | Riboflavin + niacin | | | | OR 1.08 (0.92–1.27)
| | Vitamin C + molybdenum | | | | OR .92 (0.79–1.09)

NPC = Nutritional Prevention of Cancer Study Group; ARED = Age-related Eye Disease Study Group; OR = odds ratio; RR = relative risk; HR = hazard ratio; 95% CI = 95 confidence interval; MVM = cum = cumulative; ANOVA = analysis of variance; py = person-years; AMD = age-related macular degeneration

Evidence Table 3o. Total mortality in studies of the efficacy of other single or paired nutrients in preventing chronic disease

Author, year | Disease endpoint | Study supplement | Total Number in study (active/ placebo) | Number of disease events (active/ placebo) | Incidence of disease endpoint (arm1/arm2) | Unadjusted estimates (95% CI) | P-value
Clark, 1996^133^ | All cause mortality | | | 108/129 | | HR 0.79 (0.61–1.02) | .07
Mark, 1998^66^ | Total mortality | Retinol + zinc | | | NA | RR 1.00 (.92–1.09) | NA
| | Riboflavin + niacin | | | | RR .98 (.90–1.06)
| | Vitamin C + molybdenum | | | | RR 1.01 (.92–1.10)

NPC = Nutritional Prevention of Cancer Study Group

Evidence Table 3p. Systematic reviews on calcium and/or vitamin D: supplement information

Author, Year | Study aim | Trials included, n | Publication yrs (range of dates) | Supplements/ other therapies in treated groups | Chemical forms | Range of daily doses | Types of comparison groups
Prevention of Bone Loss
Shea, 2004^47^ | Assess effects of calcium supplementation on bone loss and postmenopausal women. | 10 | 1978-1998 | [underlined: Calcium Vitamin D:] - In 2 trials, (n=140), vitamin D given to both treatment & control groups.[underlined: Exercise:] In 2 trials (n=121), exercise prescribed for both treatment & control groups | Calcium carbonate, Calcium gluconate ± lactate Calcium citrate ± malate, Calcium (salt form not stated. Vitamin D forms not stated. | Ca carbonate 500–2000 mg Ca gluconate ± lact 1000 mg Ca citrate ± malate 500–1000mg Ca(no salt) 500–1000mg Vitamin D 300,000 IU at start of 1.5 yr study (=~550 IU/day) Vitamin D 400 IU | [underlined: Placebo Vitamin D]- given simultaneously to both treatment & control groups in equal dose [underlined: Exercise] -
Papadimitriopoulos, 2004^49^ | vitamin D in preventing osteoporosis in postmenopausal women with bone density in the normal or near-normal range. | 25 total trials -10 of which involved vitamin D doses ≤ 2000 IU/day ("standard vit D"). Of these 10 trials, 4 measured BMD fracture reduction ± BMD changes, and 6 monitored BMD changes only. | 1980-1999 | Vitamin D ± calcium | Cholecalciferol (vitamin D_3_); Calcium salts not described | Cholecalciferol 300–2000 IU; Calcium 377 mg-1000 mg; | Placebo; Calcium
Mackerras, 1997^52^ | Separate analyses of first- and second-year effects of calcium of bone mineral density in postmenopausal women | 8 | 1987-1995 | Calcium; Milk Powder | calcium carbonate, calcium citrate malate, lactogluconate, lactate-gluconate, combination, milk powder | Ca carbonate 500–2000 mg; Ca lactate gluconate 1000–2000 mg; Ca citrate maleate 500 mg Ca in milk powder 1000 mg | Placebo; Placebo + exercise
Prevention of Bone Loss & Fractures
Shea, 2004^47^ | Assess effects of calcium supplementation on bone loss and fractures in postmenopausal women. | 5 | 1978-1998 | Calcium Vitamin D | Calcium carbonate, Calcium gluconate Calcium citrate Calcium (salt form not stated); Vitamin D formulations not described. | Ca carb 1000–2000 mg Ca gluc 1000 mg Calcium 1000 mg Calcium citrate 1600 mg | Placebo
Papadimitriopoulos, 2004^49^ | vitamin D in preventing osteoporosis in postmenopausal women | 25 total trials, 10 eligible for our review. 4 of these 10 evaluiated fracture reduction. | 1980-1999 | Vitamin D ± calcium | Cholecalciferol (vitamin D_3_); Neither calcium nor phosphate salt forms described | Cholecalciferol 400–800 IU Calcium 300–1200 mg; Phosphate 600 mg | Placebo; Calcium
Avenell, 2005^143^ | Vitamin D for preventing fractures associated with involutional and post-menopausal osteoporosis | Of total 38 trials, 11 eligible for our review (involved rx with vitamin D in doses <2000 IU (upper limit advised by the Food & Nutrition Board. | 1983-2005 | Vitamin D ± calcium | Cholecalciferol (vitamin D_3_); Ca carbonate; Tricalcium phosphate; Calcium lactate; Calcium | Cholecalciferol 400–1000 IU; Calcium salts to provide 500–1200 mg; | Placebo (single & double); Calcium

Evidence Table 3q. Systematic reviews on calcium and/or vitamin D: participant characteristics

Author, Year | Inclusion/ exclusion criteria | Treatment, n | Controls, n | Ca alone, n | Ca + Vit D, n | Ca + exercise, n | Vit D alone, n | Exercise alone, n | Dietary calcium intake/ fall prevention, couseling | PBO Total | Range of mean ages (SD) | Women (%) | Comments
Prevention of Bone Loss
Shea, 2004^47^ | Inclusison: RCT; | 745 | 497 | 629 | 69 | 47 | 71 | 52 | 0 | 374 | 46–72.1 | 100 | It was explained in paper that baseline BMD for groups was not pooled because of heterogeneity in techniques used to measure BMD. Rather calculations of BMD changes were based on % change from baseline
| PMP women >45 yrs old with amenorrhea ≥ 6 months; Treatment in which intervention was calcium supplementation or usual dietary calcium intake; | | | | | | | | | | (0.6)
| Vit D supplementation ≤400 IU/day & equivalent in Rx & control grps.
| Exclusion: Males
| Calcium <400mg/d;
| Vit D rx >400 IU/d and/or that differed between rx & pbo groups; Trial duration <1 yr; BMD measured only at ultra-distal forearm site;
| BMD measurement by technique other than SPA, DPA, or DXA; Failure of contacted authors of eligible studies to provide requested data; A priori selected outcomes not included
Papadimitriopoulos, 2004^49^ | Inclusion: PMP women >45 yrs old with amenorrhea ≥ 6 mos; included studies with interventions of vitamin D ± calcium and control grp intakes of vitamin D ≤100 IU/day ± calcum | 445 | 511 | 373 | 387 | NA | 578 | NA | 0 | 275 | 49.9–71.5 | 100 | Calculations were made for each bone density site (rather than pooling results); measurements of % change in BMD from baseline were used to calculate weighted mean differences in BMD between Rx & control groups
| Exclusion: Males;
| Women < 45 y/o and/or amenorrheic < 6 mos;
| vitamin D daily intake ≤ 400 IU/d; follow-up < 1 year;BMD (g/cm or g/cm2) not measured by single-photon absorptiometry, dual-photon absroptiometry, or dual x-ray absroptiometry in at least 1 of several designated sites (femoral neck, total hip, trochanter, lumbar spine, total body, or combined forearm); reporting total number of fractures for a group as opposed to reporting fracture results on individual patients; studies that compared different types or doses of vitamin D
Mackerras, 1997^52^ | Inclusion: PMP women; any indication that study was randomized. | 999 | 387 | 612 | 34 Aloia study) | 75 | 36 | 35 | 352 | 352 | 51–66 | 100
| Exclusion: report not in English; less than 2 years of follow-up; no group received calcium supplement or dairy products; no randomized control group; no intention-to-treat analysis reported and/or reconstructable from the data given; a crossover study using subjects as their own controls; obviously nonrandomized studies; combination therapy arms involving calcium and another drug with known strong effects on bone; not postmenopausal women
Prevention of Fractures
Shea, 2004^47^ | Inclusion: PMP women >45 years old with amenorrhea ≥ 6 months; Vit D supplementation ≤ 400 IU & same in Rx & control groups | 270 | 279 | 270 | 0 | 0 | 0 | 0 | 279 | 279 | 50(2.8) to 73.5 (7.1) | 100
| Exclusion: Males;
| calcium <400mg/d;
| vit D rx >400 IU/d and/or that differed between rx & pbo groups; trial duration <1 yr; BMD measured only at ultra-distal forearm site; BMD measurement by technique other than SPA, DPA, or DXA; Failure of contacted authors of eligible studies to provide requested data;
| A priori selected outcomes not included
Papadimitri-opoulos, 2004^49^ | Inclusion: PMP women >45 yrs old with amenorrhea ≥ 6 mos; Included studies with interventions of vitamin D ± calcium and control grp intakes of vitamin D ≤100 IU/day ± calcum. | 2892 | 2888 | 123 | 1636 received vit D together with ca 1200 mg and phosphate 600 mg per day | 0 | 2210 | 0 | 2765 | 2765 | 49.9 to 84.0 | 100
| Exclusion: Males;
| women < 45 y/o and/or amenorrheic < 6 mos; vitamin D daily intake ≤ 400 IU/d; follow-up < 1 year; BMD (g/cm or g/cm2) not measured by single-photon absorptiometry, dual-photon absroptiometry, or dual x-ray absoroptiometry in at least 1 of several designated sites (femoral neck, total hip, trochanter, lumbar spine, total body, or combined forearm); reporting total number of fractures for a group as opposed to reporting fracture results on individual patients; studies that compared different types or doses of vitamin D.
Avenell, 2005^143^ | Inclusion; Men & PMP women ≥ age 65; either community-living & institutionalized; | 12653 | 15485 | 3918 | 9935 | 0 | 2718 | 0 | 7042 | 7042 | 52.7–85 | 65 | Randomization and blinding not always clear( as for Chapuy 2004, Larsen)
| Included trials whose subjects had previous fractures and neurologic disorders impairing mobility (e.g. Parkinson's); Included both randomized & pseudorandomized trials
| Exclusion; Women and men younger than 65 years of age; cognitive impairment;cancer within previous 10 yr of type likely to metastasize to bone; life expectancy <6 months; trials in which subjects were on glucocorticoid Rx; interventions that included agents other than vitamin D & calcium; disorders (e.g. nephrolithiasis, hyperparathyroidism) or drugs (e.g. bisphosphonates, HRT, vitamin D >200 IU/day) known to affect bone metabolism

Ca = calcium; vit = vitamin; PBO = placebo; SD = standard deviation; RCT = randomized controlled trial; PMP = post-menopausal; BMD = bone mineral density; SPA = single-photon absorbency; DPA = double-photon absorbency; DXA = dual x-ray absorbency

Evidence Table 3r. Systematic reviews on calcium and/or vitamin D for prevention of bone loss and fractures: efficacy measures

| | | BMD Measurements | | | | Fracture Risk
Author, year | Outcome | Intervention | BMD Site | Trials (n) | WMD (95% CI) ^1^ | Heterogeneity p-value | FX Site | Trials (n) | Weighted RR^2^ | Heterogeneity p-value | Comments
Shea, 2004^47^ | Effect of calcium on BMD & FXs in PMP women. | Calcium500–2000 mg/d | L-spine (2 y) | 9 (845) | 1.66 (0.92, 2.39) p<0.01 | 0.02 | Vert. | 5 (576) | 0.79 (0.55, 1.13) p= 0.14 | 0.40 | Heterogeneity of BMD differences not explained by primary vs secondary studies, loss to follow-up, type or dose of Ca or by BMD site. Lack of uniformity of outcome measures problematic.
| Follow-up 1 to 4 yr | ±Vit. D_3_ | L-spine (3–4 y) | 2 (218) | 1.13 (-0.11, 2.38) p=0.07 | 0.71 | Non-Vert. | 2 (222) | 0.86 (0.43, 1.72) p=0.66 | 0.54
| | | Combined hip | 8 (830) | 1.64 (0.70, 2.57) p<0.01 | 0.04
| | | 1/3 distal radius | 6 (615) | 1.91 (0.33, 3.50) p=0.02 | <0.01
| | | Total body | 4 (358) | 2.05 (0.24, 3.86) p=0.03 | <0.01
Papadimitriopoulos, 2004^49^ | Effect of Vit. D on BMD & FXs in pmp women. | Vit. D_3_, 300–2000 IU/day ± Ca | L-spine (1 y) | 4 (563)) | 0.86 (0.17, 1.54) p=0.01 | 0.10 | Vert. | 1 (160) | 0.33 (0.01, 8.05) p= 0.49 | NA | Potential causes of heterog. Include variable Ca use in treated & controls & population-dependent D effects. OH-vit D forms more potent.
| Follow-up 1 to 5 yr | | L-spine (2–5 y) | 4 (608) | -0.40 (-2.06, 1.25) p=0.63 | <0.00 | Non-Vert. | 3 (5399) | 0.78 (0.55, 1.09) p=0.15 | 0.05
| | | Femoral neck (1–5 y) | 5 (862) | 0.98 (0.10, 1.85) p=0.03 | 0.22
| | | Combined forearm (1–2 y) | 5 (597) | -0.48 (-1.18, 0.22) p=0.18 | 0.42
| | | Total body (1–3 y) | 3 (508) | 0.40 (-0.25, 1.05) p=0.23 | <0.01

Evidence Table 3r-1. Systematic reviews on calcium for prevention of bone loss (upper panel) and vitamin D for prevention of falls (lower panel): efficacy measures

| | | Year-by-year differences in rate of bone loss^1^
Author, year | Outcome | Intervention | BMD Site | First yr (95% CI) | Second yr (95% CI) | 2 yr total | Comments
Mackerras, 1997^52^ | Year-by-year effect of calcium on BMD in postmeno-pausal women. | Calcium, 500–2000 mg/d | L-spine | 1.9 (0.9, 2.8) p<0.001 | 0.00 (-1.2, 1.1) p=1.0 | 1.9 (0.8, 2,9) p=0.001
| Follow-up 2 to 3 yr. | ± Vit. D_3_ 400 IU/d | Femoral neck | 2.2 (1.0, 3.5) p=0.001 | 0.1 (-1.4, 1.6) p=0.9 | 2.3 (1.0, 3.6) p=0.001
| | | Trochante | 2.9 (1.5, 4.2) p<0.001 | -0.4 (-2.0, 1.3) p=0.7 | 2.5 (1.1, 3.9) p=0.001
| | | Distal forearm | 0.9 (-1.2, 3.1) p=0.04 | 1.1 (-1.6, 3.7) p=0,04 | 1.9 (-0.3, 4.3) p=0.09
| | | Proximal forearm | 2.1 (0.8, 3.4) p=0.002 | 0.5 (-1.0, 2.1) p=0.5 | 2.6 (1.3, 4.0) p=<0.001

Author, year | Outcome | Interventtion | Trials (n) | Corrected pooled odds ratio for prevention of falls by vitamin D supplementation | Pooled risk difference | | Comment
Bischoff-Ferrari 2004^145^ | Effect of vitamin D on falls in older persons. | Vit. D_3_, 400–800 IU/day or active vitamin D (calcitriol or alpha calcidiol | 5 (1237) | 0.78 (95% CI 0.64–0.92) | 7% (95% CI 2%–12%; p=0.007) NNT 15 (95% CI 8–53) | | No statistically significant heterogeneity. Effect sizes similar for studies using active vit D & D_3_ ± Ca, and in community or institution-dwellers. Pooled odds ratios ranged from 0.77–0.83 for variable Ca regimens or no Ca.
| Follow-up 3 to 14 mos. | ± Ca 800–1200/day | Subgroup analyses
| | | Trials using vitamin D_3_ 400–800 IU/day (active vitamin D trials excluded) | | Trials using only vitamin D_3_ 800 IU/day (400 IU/day vitamin D trial excluded)
| | | No. of trials (n) | Corrected odds ratio of falling | No. of trials (n) | Corrected odds ratio of falling
| | | 3 (613) | 0.83 (95% CI 0.65,1.06) | 2 (259) | 0.65 (95% CI 0.40,1.00)

Author, year | Outcome | Interventtion | FX Site | Daily Vitamin D dose | Trials (n) | Weighted RR^2^ (95% CI) | Heterogeneity p-value | Pooled Risk Difference | Comment
Bischoff-Ferrari 2005^40^ | Effect of vitamin D in prevention of hip and nonvertebral fractures in older persons. | Vit. D_3_ 400–800 IU/day | Hip | 400–800 IU | 5 (9294) | 0.88 (0.69, 1.13) | 0.09 | | Meta-regression revealed an inverse relationship between serum 25OH Vit. D (during follow-up) and reduction in hip fracture risk.
| Follow-up. 1.5 to 5 yrs | ± calcium, 500–1200 mg/d | Hip | 700–800 IU | 3 (5572) | 0.74 (0.61, 0.88) | 0.74 | 2% (95% CI, 1%–4%) p<0.001 (for treatment 2–5 y) | Optimal fracture prevention appeared to occur with achieved mean 25OH Vit. D levels of 100 nmol/L.
| | | Hip | 400 IU | 2 (3722) | 1.15 (0.88,1.50) | 0.68 | | These results suggest that doses higher than 700–800 IU/d may be needed for people with low baseline 25OH D.
| | | Any non-vert. | 400–800 IU | 7 (9820) | 0.83 (0.70, 0.98) | 0.07
| | | Any non-vert. | 700–800 IU | 5 (6098) | 0.77 (0.68, 0.87) | 0.41 | 4% (95% CI, 2%–5%) p=0.02 (for treatment 1–5 y)
| | | Any non-vert. | 400 IU | 2 (3722) | 1.03 (0.86, 1.24) | 0.36

Evidence Table 3r-2. Systematic review on vitamin D ± calcium for prevention of fractures in elderly people: efficacy measures

| | Fracture Risk
| | Hip | | | Vertebral | | | Non-vertebral
Author, year | Intervention | # Trials (n) | Weighted RR^2^ (95% CI) | Heterogeneity p-value | # Trials (n) | Weighted RR^2^ (95% CI) | Heterogeneity p-value | # Trials (n) | Weighted RR^2^ 95% CI) | Heterogeneity P-value
Avenell, 2005^143^ | Vit. D vs placebo or control | 7 (18668) | 1.17 (0.98, 1.41) p=0.09 | 0.67 | 4 (5698) | 1.13 (0.50, 2.55) p=0.8 | 0.08 | 8 (18903) | 0.99 (0.91, 1.09) p=0.90 | 0.09
| Vit. D vs Ca | 2 (2739) | 1.08 (0.72, 1.51)p=0.7 | 0.21 | 3 (2997) | 2.76 (1.27–6.00) p=0.01 | 0.72 | 3 (2997) | 1.02 (0.84, 1.22) =0.9 | 0.36
| Vit. D + Ca vs placebo or control | 7 (10376) | 0.81 (0.68, 0.96) p=0.02 | 0.66 | 2 (2708) | 0.34 (0.01, 8.34) p=0.50 | N/A | 7 (10376) | 0.87 (0.78, 0.97 p=0.01 | 0.39
| Vit. D + Ca vs Ca | 3 (6866) | 0.81 (0.60, 1.10) p=0.20 | 0.50 | 2 (2681) | 0.14 (0.01–2.77) p=0.2 | N/A | 4 (3061) | 0.96 (0.79, 1.16) p=0.6 | 0.34

1 Weighted mean difference (WMD) in BMD (treated group - control group) using percentile change from baseline

2 Aggregate estimate (Relative Risk (RR), 95% confidence interval (CI)) of risk of event with vs without supplement

Abbreviations: BMD, bone mineral density; FX, fracture; pmp, postmenopausal; IU, international unit; Vert., vertebral; NA, not applicable

Evidence Table 3s. Randomized controlled trials on the efficacy of calcium and/or vitamin D in preventing chronic disease that were not included in previous systematic reviews: characteristics of studies

Author, year | Study name | Nutrient(s) | Study period | Total sample size enrolled | Mean/ median follow-up time | Mean participant age | Women, n (%)
Jackson, 2006^146^ | WHI | Calcium/ Vitamin D | 1993-1998 | 36,282 | 7 | 62.4 | 36,282 (100)
Wactawski-Wende, 2006^152^ | WHI | Calcium/ Vitamin D | 1993-1998 | 36,282 | 7 | 62.4 | 36,282 (100)
Meier, 2004^147^ | | Calcium/ Vitamin D | NS | 55 | Planned 2 years | 56.2 | 29 (52.7)
Hunter, 2000^148^ | | Calcium/ Vitamin D | NS | 158 | Planned 2 years | 58.7 | 158 (100)
Storm, 1998^149^ | | Calcium | NS | 60 | Planned 2 years | 71 | 60 (100)

Evidence Table 3t. Randomized controlled trials on the efficacy of calcium and/or vitamin D in preventing chronic disease that were not included in previous systematic reviews: characteristics of the intervention

Author, year | Intervention | Chemical form | Dose/Frequency of use | Timing of use | Duration of use
Jackson, 2006^146^ | Placebo | | | 2 x/day | Until censoring (Mean duration 7.0 years)
| Calcium | Calcium Carbonate | 500 mg | | Until censoring (Mean duration 7.0 years)
| Vitamin D | Vitamin D3 | 200 IU | | Until censoring (Mean duration 7.0 years)
Wactawski-Wende, 2006^152^ | Placebo | | | 2 x/day | Until censoring (Mean duration 7.0 years)
| Calcium | Calcium Carbonate | 500 mg | | Until censoring (Mean duration 7.0 years)
| Vitamin D | Vitamin D3 | 200 IU | | Until censoring (Mean duration 7.0 years)
Meier, 2004^147^ | No treatment
| Calcium | NS | 500 mg | 1 x/day | 7 months
| Vitamin D | Cholecalciferol | 500 IU | | 7 months
Hunter, 2000^148^ | Placebo | | | 1 x/day | 2 years
| Vitamin D | Cholecalciferol | 800 IU | | 2 years
Storm, 1998149 | Placebo | | | 2x/day | 2 years
| Calcium | Calcium Carbonate | 500 mg

Evidence Table 3u. Randomized controlled trials on the efficacy of calcium and/or vitamin D in preventing chronic disease that were not included in previous systematic reviews: results

Author, year | Study supplement | Total Number in study (active/ placebo) | Main results | Total number of disease events (active/ placebo) | Hazard Ratio | Mean % change in BMD | Unadjusted estimates (95% CI) | P-value
Jackson, 2006^146^ | Calcium/ Vitamin D | 18,176/ 18106 | Hip Fracture | 175/199 | 0.88 | | 0.72–1.08
Wactawski-Wende, 2006^152^ | Calcium/ Vitamin D | 18,176/ 18106 | Invasive Colorectal Cancer | 168/154 | 1.08 | | 0.86–1.34
Meier, 2004^147^ | Calcium/ Vitamin D | 30/25 | Change in lumbar and hip BMD (Pretreatment vs post treatment) | | | Lumbar spine of treatment group: +0.8%; femoral neck of treatment group: +0.1%; No significant change in controls | | Lumbar spine of treatment group: 0.04; Femoral neck of treatment group: >.05
Hunter, 2000^148^ | Calcium/ Vitamin D | 79/79 | Intrapair difference (treatment vs. control) change in Spine and Femoral neck BMD | | | Difference in Spine BMD: -0.001; Difference in Femur neck BMD: +0.003 | SD difference in spine -0.046; SD difference in Femur neck -0.033 | >.05
Storm 1998^149^ | Calcium/ Vitamin D | NR/NR | Change in BMD over 2 years | | | Treatment FN BMD change +3%; Placebo FN BMD change -0.3%; Treatment GT BMD no sig diff change; Placebo -3%; Treatment Lumbar BMD change +3.7%; Placebo Lumbar BMD change no sig diff change | | FN difference p=.1; GT difference p=.05; lumbar spine difference p<.01

Evidence Table 4a. Characteristics of the interventions in studies of the safety of vitamin A and/or beta-carotene supplements

Author, year | Control arm (duration of use) | INTERVENTION ARMS
| | Nutrient/supplement | chemical form(s) | Dose/Frequency of use | Timing of use | Duration of use
Omenn, 1994 ^153^ | Placebo (10 years or until endpoint) | Vitamin A; beta-carotene | Retinol in pilot phase (1985-1988) then retinyl palmitate in Vanguard (1988-1996) | 25000 IU; 30 mg; 15 mg in asbestos pilot; 30 mg in one arm of smoker pilot; 30 mg in Vanguard cohort (1988-1996) | 1× per day | 8–10 years or until endpoint
Omenn, 1996 ^93^ | Placebo (10 years) | Active Treatment (vitamin A; beta-carotene) | Retinyl palmitate ; beta-carotene | 25000 IU; 30 mg | 1× per day | NS
Sibulesky, 1999 ^77^ | | Trace nutrients | All-rac-alpha tocopherol; Retinyl palmitate; | 3 IU (2.2 tocopherol equivalent); 75 IU (23 retinol equivalent) | 1× per day | 4–6 years
Cartmel, 1999^185^ | Placebo (3.8 years) | Retinol; vitamin E; vitamin A | Retinol; all-rac-alpha tocopherol; retinol palmitate | 7576 retinol equivalents; 3 IU (2.2 tocopherol equivalent); 4500 RE (15,000 IU) | NS | 3.8 years
Goodman, 1993 ^92^ | Placebo (3 years) | Retinol; beta-carotene | Retinol; beta-carotene | 25000 IU; 30 mg | 1× per day | NS
Xuan, 1991 ^78^ | | Vitamin A; beta-carotene; vitamin E; selenium | Retinol; beta-carotene; d-alpha-tocopherol; selenium yeast | 25,000 IU; 30 mg | 1× per day | 6 months
Ragavan, 1982 ^186^ | | Vitamin A | NS | Up to 75,000 IU | NS | NS
Stauber, 1991^187^ | | Vitamin A | NS | 0–47,000 IU | NS (supplement plus dietary intake) | 5 years
Lee, 1999^96^ | Placebo (2.1 years) | Beta-carotene | Beta-carotene | 50 mg | Every other day | 2.1 years
Green, 1999^84^ | Placebo (4.5 years) | Beta-carotene | Beta-carotene | 30 mg | 1× per day (with meals) | 4 years
Hennekens, 1996 ^95^ | | Beta-carotene | Beta-carotene | 50 mg | Every other day | 12 years
Omenn, 1993 ^91^ | Placebo (3 years) | Vitamin A/Beta-Carotene | Retinol; beta-carotene | 25000 IU; 15 mg | 1× per day | NS
Micozzi, 1988 ^188^ | Placebo (constant and low total carotenoid content (0.5–1.6 mg/d for 3000 kcal intake level)), (6 weeks) | Vitamin A | Retinol; beta-carotene | 30 mg; 12 mg | 1× per day (with meals) | 6 weeks

Evidence Table 4b. Results of studies with information on clinical adverse effects of vitamin A supplements in the prevention of chronic diseases

Author, year | Nutrient | Adverse effect | Adverse effects in supplement group, n (%) | Adverse effects in inactive group, n (%) | Point estimate in active group, indicate what type | Statistical significance (p-value) | Comment
Omenn, 1994 ^153^ | Beta carotene and/or retinol | hypertriglyceridemia | NA | NA | NA | P<0.05 | Actual difference between arms were very small and negligible
Omenn, 1996 ^93^ | Beta carotene and/or retinol | NR | NR | NR | NR | NR
Sibulesky, 1999 ^77^ | Vitamin A | Liver enzymes | NA | NA | NR | NS
| | Symptoms (joint or bone pain, headaches, hairloss, erythema or scaly skin, unusually dry skin, desquamation, exfoliation, or eruption, red rash, unusually brittle or soft nails, lip fissures or chapping, nausea, diarrhea) | 3 | 13 | | | Within each randomized group, those withdrew due to side effect had similar serum concentration to those without side effect.
| | Blood cell counts, chemistries, urine studies | NR | NR | | | Standard blood and urine chemistries were comparable between groups.
Cartmel, 1999^185^ | Retinol | Alopecia | 7 | 3 | NR | Not significant at 1, 13, 25, 37, 46 or 61 months
| | Conjunctivitis | 2 | 2
| | Epistaxis | 2 | 1
| | Cheilitis | 10 | 10
| | Dry skin | 21 | 9
| | Exanthema | 10 | 9
| | Peeling palms | 3 | 0
| | Skin infection | 0 | 0
| | Headaches | 19 | 31
| | Fatigue | 11 | 12
| | Stiffness | 3 | 5
| | Dysuria | 2 | 0
| | Menstrual changes | 0 | 0
| | Nausea or vomiting | 2 | 0
| | WBC abnormality | 92 | 122
| | Liver enzymes abnormality | 134 | 186
| | Cholesterol | 65 | 97
| | Hemoglobin | 267 | 298
| | Platelet count | 7 | 7
Goodman, 1993 ^92^ | Retinol; beta-carotene | Yellowing of skin | 1 | 0 | NR
| | Skin redness/dryness | 14 | 19
| | Nosebleeds | 4 | 0
| | Weight loss/appetite | 5 | 6
| | Headaches | 11 | 9
| | Anxiety/depression | 21 | 15
| | Fatigue | 13 | 13
| | Bone pain | 14 | 13
| | Nausea/vomiting | 1 | 0
| | Bowel movements | 8 | 9
| | SGOT | 0 | 2
| | Alkaline phosphatase | 0 | 1
Xuan, 1991 ^78^ | Vitamin A | Hypercalcemia | 1 | NA | NA | | Case study
| | Muscle atrophy
| | Total body alopecia
| | Erosive dermatitis
| | Psychiatric disturbances
Ragavan, 1982 ^186^ | Vitamin A | Liver function as measured by aspartate aminotransferase (AST) activity | NA | NA | NA | | Retinyl esters explained only 12% of the variability in AST activity. The association of retinyl esters and AST was significant in females (r=0.47).
Stauber, 1991^187^ | Vitamin A | Liver function as measured by aspartate aminotransferase (AST) activity | NA | NA | NA | 0.0002 | Retinyl esters explained only 12% of the variability in AST activity (Spearman's correlation coefficient, r=0.34).
Lee, 1999^96^ | Beta-carotene | Yellowing of the skin | 2131 | 1944 | 0.5 (0.24–1.03)
Green, 1999^84^ | Beta-carotene | Symptoms (not specified) | 65 | 64 | NR | NS
Hennekens, 1996 ^95^ | Beta-carotene | Skin yellowing | 1745 | 1535 | NR
| | Minor gastrointestinal symptoms (e.g., belching) | 275 | 124
Omenn, 1993 ^91^ | Vitamin A/Beta-carotene | Increased alkaline phosphatase | 1 | 1 | NR
| | Threshold level adverse symptoms | 154 | 142 | | | Text reported no difference in overall rates or rates of individual symptoms except change in bowel habits.
| | Change in bowel habits | NR | NR | | | Text reported that rates were different between arms, but direction and magnitude were not specified.
Micozzi, 1988 ^189^ | Beta-carotene | Carotenodermia | 5 | 1 | NR | | Carotenodermia was assessed by physical exam of the skin; skin yellowing was graded into 3 degrees based on subjective reading.

NR = Not reported; NS = Not significant; NA = Not applicable

Evidence Table 4c. Results of studies with information on lipid profiles associated with the use of vitamin A and/or beta-carotene supplements

Author, year | Nutrient | Adverse effect | Adverse effects in supplement group, n (%) | Adverse effects in inactive group, n (%) | Change in active group (indicate mean (95% CI)), mean (SD), mean (SE), median or other measurements | Change in inactive group (indicate mean (95% CI)), mean (SD), mean (SE), median or other measurements | Statistical significance (p-value) | Comment
Omenn, 1994 ^153^ | Retinol; beta-carotene | Increased triglyceride levels | NA | NA | Mean: 0 mg/dL after 72 months | Mean: -25 mg/dL after 72 months | p<0.01 | TG were significantly higher in the treatment group for all time-points after baseline.
Cartmel, 1999^185^ | Retinol | Triacylglycerol | NA | NA | Mean (95% CI): baseline: 1.42 mmol/L (1.35–1.48); 49 months: 1.77 mmol/L (1.69–1.85) | Mean (95% CI): baseline: 1.38 mmol/L (1.32–1.45); 49 months: 1.59 mmol/L (1.52–1.66) | | Significantly higher triacylglycerol levels over time in the retinol group, beginning at 1 mo and continuing throughout
| | HDL | | | Mean (95% CI): baseline: 1.26 mmol/L (1.22–1.29); 49 months: 1.16 mmol/L (1.13–1.19) | Mean (95% CI): baseline: 1.24 mmol/L (1.21–1.28); 49 months 1.17 mmol/L (1.14–1.20) | | Decreased over time in both groups, but decline was singificantly greater in the retinol group
| | LDL | | | Mean (95% CI): baseline: 3.55 mmol/L (3.47–3.63); 49 months: 3.61 mmol/L (3.53–3.70) | Mean (95% CI): baseline: 3.55 mmol/L (3.47–3.63); 49 months: 3.49 mmol/L (3.42–3.57)

NA = Not applicable; NR = Not Reported; LDL = low-density lipoprotein; HDL = high-density lipoprotein; SD = Standard Deviation; SE = Standard Error.

Evidence Table 4d. Assessment of the likelihood that reported adverse effect were caused by use of a vitamin A and or beta-carotene supplements

Author, year | Nutrient | Adverse effect | Temporal relationship | Dose-response relationship | Adverse effects disappeared after discontinuation of supplementation | Evidence of supplement use | Lack of alternative cause | Recurrence after reuse of supplement
Omenn, 1994 ^153^ | Beta carotene and/or retinol | hypertriglyceridemia | Yes | NR | NR | NR | NR | NR
Omenn, 1996 ^93^ | Beta carotene and/or retinol | NR | NA | NA | NA | NA | NA | NA
Sibulesky, 1999 ^77^ | Vitamin A | Liver enzymes | Yes | NR | NR | Yes | NR | NR
Cartmel, 1999^185^ | Retinol | Alopecia | Yes | NR | NR | NR | NR | NR
| | Conjunctivitis
| | Epistaxis
| | Cheilitis
| | Dry skin
| | Exanthema
| | Peeling palms
| | Skin infection
| | Headaches
| | Fatigue
| | Stiffness
| | Dysuria
| | Menstrual changes
| | Nausea or vomiting
| | White blood cell count abnormality
| | Liver enzymes abnormality
| | Hemoglobin
| | Platelet count
Goodman, 1993 ^92^ | Retinol; beta-carotene | Yellowing of skin | Yes | No | NR | Yes | No | NR
| | Skin redness/dryness
| | Nosebleeds
| | Weight loss/appetite
| | Headaches
| | Anxiety/depression
| | Fatigue
| | Bone pain
| | Nausea/vomiting
| | Bowel movements
| | Serum glutamic oxaloacetic transaminase
| | Alkaline phosphotase
Xuan, 1991 ^78^ | Vitamin A, beta-carotene, Vitamin E, selenium | Muscle cramps | Yes | NR | NR | Yes | NR | NR
| | Diarrhea
| | Poor appetite
| | Runny nose
| | Joint pain
| | Chapping of lips/face
| | Yellowing of skin
| | Broken nails
| | Hair loss
| | Tingling in limbs
| | Headache
| | Lethargy
Ragavan, 1982 ^186^ | Vitamin A | Hypercalcemia | | | Yes | | Yes
| | Muscle atrophy
| | Total body alopecia
| | Erosive dermatitis
| | Psychiatric disturbances
| | Thyroid function
Stauber, 1991^187^ | Vitamin A | Liver function as measured by aspartate aminotransferase activity | Yes | NR | Yes | No | NR
Lee, 1999^96^ | Beta-carotene | Yellowing of the skin | Yes | NR | NR | Yes | NR | NR
Green, 1999 ^84^ | Beta-carotene | Symptoms (not specified) | NR | NR | NR | NR | NR | NR
Hennekens, 1996 ^95^ | Beta-carotene | Skin yellowing | NR | NR | NR | Yes | NR | NR
| | Minor GI symptoms (e.g. belching)
Omenn, 1993 ^91^ | Vitamin A/beta-carotene | Increased alkaline phosphate | Yes | NR | NR | Yes | No | NR
Micozzi, 1988 ^188^ | Beta-carotene | Carotenodermia | Yes | Yes | Yes | Yes | NR

NR = Not reported

Evidence Table 4e. Characteristics of the interventions in studies of the safety of vitamin E supplements

Author, year | Control arm (duration of use) | INTERVENTION ARMS
| | Nutrient/supplement | chemical form(s) | Dose/Frequency of use | Timing of use | Duration of use
Lee, 2005 ^87^ | Placebo (10.1 years) | Vitamin E | Alpha-tocopherol | 600 IU | every other day | 10.1 years
McNeil, 2004 ^113^ | | Vitamin E | D-alpha-tocopherol | 335 mg | 1 × per day | 4 years
de Gaetano, 2001^117^ | No vitamin E (3.6 months) | Vitamin E | Synthetic alpha tocopherol | 300 mg | 1× per day | 3.6 months (mean)
Sibulesky, 1999 ^77^ | | Trace nutrients | All-rac-alpha tocopherol; Retinyl palmitate; | 3 IU (2.2 tocopherol equivalent); 75 IU (23 retinol equivalent) | 1× per day | 4–6 years
| | Treatment 2; treatment 3 | D-alpha-tocopherol | 1000 IU; 1500IU
Xuan, 1991 ^78^ | | Vitamin A; beta-carotene; vitamin E; selenium | Retinol; beta-carotene; d-alpha-tocopherol; selenium yeast | 25000 IU; 30 mg; 50 mg; 800 IU; 400 mcg | 1× per day | 6 months
Simons, 1996 ^189^ | Placebo (soybean oil), (6 weeks) | Treatment 1 (500IU/d) | D-alpha-tocopherol | 500 IU | NS | 6 weeks
Tsai, 1978 ^190^ | Placebo (4 weeks) | Intervention - megavitamin E | Dl-alpha-tocopherol acetate | 200 IU | 3× per day (with meals) | 4 weeks

NS - Not specified

Evidence Table 4f. Results of studies with information on clinical adverse effects of vitamin E supplements in the prevention of chronic diseases

Author, year | Nutrient | Adverse effect | Adverse effects in supplement group, n (%) | Adverse effects in inactive group, n (%) | Point estimate in active group, indicate what type | Statistical significance (p-value) | Comment
Lee, 2005 ^87^ | Vitamin E | Epistaxis | NR | NR | 1.06 (1.01–1.11) | 0.02
McNeil, 2004 ^113^ | Vitamin E | Adverse events | 351 | 327 | NR | 0.56
| | Major adverse event (death, disability, hospitalization) | 127 | 128
de Gaetano, 2001^117^ | Vitamin E | Bleeding: gastrointestinal bleed; intracranial bleed; ocular bleed; epistaxis; other | 16; 11; 2; 1; 1; | 14; 11; 0; 1; 1; 1 | NA
| | Gastrointestinal disease other than bleed | 6 | 5
| | Other events | 30 | 27 | NR | 0.003
Sibulesky, 1999^77^ | Vitamin E; vitamin A | Liver enzymes | NA | NA
| | Symptoms (joint or bone pain, headaches, hairloss, erythema or scaly skin, unusually dry skin, desquamation, exfoliation, or eruption, red rash, unusually brittle or soft nails, lip fissures or chapping, nausea, diarrhea) | 3 | 13
| | Blood cell counts, chemistries, urine studies | NR | NR
Xuan, 1991 ^78^ | Vitamin E, selenium | Stroke | 1 (vitamin E + selenium) | 1 (placebo) | NR
Simons, 1996 ^189^ | Vitamin E | Nausea | 1 | 0 | NR | | In the 1500 IU/d arm
| | Increased bowel frequency
| | Recurrent tenosynovitis in ankle
Tsai, 1978 ^190^ | Vitamin E | Muscular weakness | 13/17 (male/female) | 12/14 (male/female) | NR | | No significant effect on serum cholesterol level in both gender; level of tryglyceride increased but not statistically significant in females.
| | Gastrointestinal disorder | 0/6 (male/female) | 0/0 (male/female)
| | Worse work performance | 4/6 (male/female) | 4/4 (male/female)
| | Worse sexuality | 1/0 (male/female) | 0/1 (male/female)
| | Worse general well-being | 5/10 (male/female) | 5/6 (male/female)
| | Serum cholesterol level | NA | NA
| | Serum triglyceride level | NA | NA

NR= Not reported; NS = Not significant; NA = Not applicable

Evidence Table 4g. Assessment of the likelihood that reported adverse effect were caused by use of a vitamin E supplement

Author, year | Nutrient | Adverse effect | Temporal relationship | Dose-response relationship | Adverse effects disappeared after discontinuation of supplementation | Evidence of supple-ment use | Lack of alter-native cause | Recurrence after reuse of supplement
Lee, 2005 ^87^ | Vitamin E | Epistaxis | Yes | NR | NR | NR | NR | NR
McNeil, 2004 ^113^ | Vitamin E | Adverse events | Yes | NR | NR | Yes | NR | NR
| | Major adverse event (death, disability, hospitalization)
de Gaetano, 2001^117^ | Vitamin E | Bleeding: gi bleed; intracranial bleed; ocular bleed; epistaxis; other | Yes | NR | NR | NR | NR | NR
| | GI disease other than bleed
| | Other events
Sibulesky, 1999 ^77^ | Vitamin A | Liver enzymes | Yes | NR | NR | Yes | NR | NR
| | Symptoms (joint or bone pain, headaches, hairloss, erythema or scaly skin, unusually dry skin, desquamation, exfoliation, or eruption, red rash, unusually brittle or soft nails, lip fissures or chapping, nausea, diarrhea)
| | Blood cell counts, chemistries, urine studies
Xuan, 1991 ^78^ | Vitamin E, selenium | Stroke | Yes | NR | NR | Yes | NR | NR
Simons, 1996 ^189^ | Vitamin E | Nausea | Yes | NR | NR | Yes | NR | NR
| | Increased bowel frequency
| | Recurrent tenosynovitis in ankle
Tsai, 1978 ^190^ | Vitamin E | Muscular weakness, gastrointestinal disorder, worse work performance, worse sexuality, worse general well-being, serum cholesterol level, serum triglyceride level | Yes | NR | NR | Yes | NR | NR

NR= Not reported

Evidence Table 4h. Characteristics of the interventions in studies of the safety of other supplements

Author, year | Control arm (duration of use) | INTERVENTION ARMS
| | Nutrient/supplement | Chemical form(s) | Dose/Frequency of use | Timing of use | Duration of use
Clark, 1996 ^133^ | Placebo (10 years) | Selenium | Selenium yeast | 200 mcg | NS | 10 years
Xuan, 1991 ^78^ | | Vitamin A | Retinol | 25000 IU; 30 mg | 1× per day | 6 months
| | Beta carotene | Beta-carotene | 50 mg
| | Vitamin E | D-alpha-tocopherol | 800 Iu
| | Selenium | Selenium yeast | 400 mcg
Coplin, 1991 ^191^ | | Chelated iron (bis-glycino iron II) | Bis-glycino iron chelate | 50 mg | 1× per day (before breakfast) | NS
| | Ferrous sulfate
Idjradinata, 1994 ^159^ | Placebo (syrup), (4 month) | Iron | Ferrous sulfate | 3 mg/kg | NS | 4 months
MMWR, 1993 ^192^ | | Iron | Ferrous sulfate | 30–40 tablets of 325 mg/tablet | Accidental poisoning | NS

NS = Not specified

Evidence Table 4i. Results of studies with information on clinical adverse effects of other supplements in the prevention of chronic diseases

Author, year | Nutrient | Adverse effect | Adverse effects in supplement group, n (%) | Adverse effects in inactive group, n (%) | Point estimate in active group | Statistical significance (p-value) | Comment
Clark, 1996 ^133^ | Selenium | Gastrointestinal upset | 21 | 14 | NR
Xuan, 1991 ^78^ | Vitamin E, selenium | See comments | See comments | See comments | NR | | See comments in the same study above
| | Stroke | 1 (vitamin E + selenium) | 1 (placebo)
Coplin, 1991 ^191^ | Iron | Moderate-to-severe adverse symptoms (abdominal pain, bloating, constipation, diarrhea, nausea, vomiting, headache, fatigue) | 14 (ferrous sulfate) | 8 (chelate form) | NR | | The remaining 16 women had same symptom profile with both preparations.
| | Abdominal pain | 7 (ferrous) | 9 (chelated)
| | Bloating | 10 (ferrous) | 9 (chelated)
| | Constipation | 13 (ferrous) | 13 (chelated)
| | Diarrhea | 9 (ferrous) | 7 (chelated)
| | Nausea | 12 (ferrous) | 9 (chelated)
| | Vomiting | 0 (ferrous) | 0 (chelated)
| | Gastrointestine | 25 (ferrous) | 23 (chelated)
| | Headache | 5 (ferrous) | 7 (chelated)
| | Fatigue | 6 (ferrous) | 6 (chelated)
| | Overall total | 26 (ferrous) | 25 (chelated)
Idjradinata, 1994 ^159^ | Iron | Growth retardation (in wt gain, measured by kg every 2 weeks) | NR | NA | NA | | Mean (SE) change (kg) every two weeks in active group 0.070 (0.011), in placebo group 0.106 (0.010)
MMWR, 1993 ^192^ | Iron | Deaths | 5 | NR | NR | | Poisoning
Strause, 1994 ^193^ | Calcium; trace minerals; calcium and minerals; placebo | Adverse symptoms causing drop-out, most commonly gastrointestinal upset (nausea, gas, indigestion) | Ca 6, minerals 3, Ca and minerals 4 | Placebo 3 | NR
| | Drop-outs due to surgery, major illness, or death | Ca 2, minerals 1, Ca and minerals 2 | Placebo 1

NR = Not reported; NS = Not significant; NA = Not applicable

Evidence Table 4j. Assessment of the likelihood that reported adverse effects were caused by use of any other supplement

Author, year | Nutrient | Adverse effect | Temporal relationship | Dose-response relationship | Adverse effects disappeared after discontinuation of supplementation | Evidence of supplement use | Lack of alternative cause | Recurrence after reuse of supplement
Clark, 1996 ^133^ | Selenium | Gastrointestinal upset | Yes | NR | NR | Yes | NR | NR
Xuan, 1991 ^78^ | Vitamin E, selenium | Stroke | Yes | NR | NR | Yes | NR | NR
Coplin, 1991 ^191^ | Iron | Moderate-to-severe adverse symptoms (abdominal pain, bloating, constipation, diarrhea, nausea, vomiting, headache, fatigue) | NR | NR | NR | NR | NR
Idjradinata, 1994 ^159^ | Iron | Growth retardation (in wt gain, measured by kg every 2 weeks) | NR | NR | NR | Yes | NR
Strause, 1994 ^193^ | Calcium; trace minerals; calcium and minerals; placebo | Adverse symptoms, most commonly GI upset (nausea, gas, indigestion) | NR | No | NR | No | No | NR

NR = Not reported