# Appendix E: Example Review Forms

To see the the Example Review Forms, please select the link below. This link will take you to a PDF version of the forms.

Example Review Forms