# Appendix D: Excluded Articles

## References

Albanes D. Beta-carotene and lung cancer: a case study. Am J Clin Nutr. 99;69(6):1345S-1350S. Narrative review. [pmid: 10359235].
Allender PS, Cutler JA, Follmann D, et al. Dietary calcium and blood pressure: a meta-analysis of randomized clinical trials. Ann Intern Med. 96;124(9):825-31. Does not cover the defined disease endpoints. [pmid: 8610952].
Arab L, Steck-Scott S, Bowen P. Participation of lycopene and beta-carotene in carcinogenesis: defenders, aggressors, or passive bystanders?. Epidemiol Rev. 2001;23(2):211-30. Narrative review. [pmid: 12192734].
Arthur RS, Piraino B, Candib D, et al. Effect of low-dose calcitriol and calcium therapy on bone histomorphometry and urinary calcium excretion in osteopenic women. Miner Electrolyte Metab. 90;16(6):385-90. Includes ONLY patients with a particular chronic disease.
Audicana M, Schmidt R, Fernandez de Corres L, et al. Allergic contact dermatitis from nicotinic acid esters. Contact Dermatitis. 90;22(1):60-1. Does not address the use of supplements. [pmid: 2138960].
Balato N, Patruno C, Lembo G, et al. Allergic contact dermatitis from retinoic acid. Contact Dermatitis. 95;32(1):51. Does not apply to the key questions, does not address the use of supplements. [pmid: 7720378].
Baqui AH, de Francisco A, Arifeen SE, et al. Bulging fontanelle after supplementation with 25,000 IU of vitamin A in infancy using immunization contacts. Acta Paediatr. 95;84(8):863-6. Does not apply to the key questions, does not cover the defined disease endpoints, includes only infiants.
Baris B. Lung cancer chemoprevention with antioxidant vitamins. Turk J Med Sci. 94;22(1):63-64. Editorial.
Bartels CL, Miller SJ. Dietary supplements marketed for weight loss. Nutr Clin Prac. 2003;18(2):156-169. Does not apply to the key questions, does not address the use of supplements.
Bigby M, Stern RS. Adverse reactions to isotretinoin. A report from the Adverse Drug Reaction Reporting System. J Am Acad Dermatol. 88;18(3):543-52. Does not apply to the key questions, does not address the use of supplements. [pmid: 3280622].
Blondeel A. Contact allergy to vitamin A. Contact Dermatitis. 84;11(3):191-2. Does not apply to the key questions, does not address the use of supplements. [pmid: 6238796].
Blot WJ. Vitamin/mineral supplementation and cancer risk: international chemoprevention trials. Proc Soc Exp Biol Med. 97;216(2):291-6. Narrative review. [pmid: 9349699].
Bostick RM, Potter JD, Fosdick L, et al. Calcium and colorectal epithelial cell proliferation: a preliminary randomized, double-blinded, placebo-controlled clinical trial. J Natl Cancer Inst. 93;85(2):132-41. Does not cover the defined disease endpoints.
Boyd EM. Food and drug toxicity. A summary of recent studies. J Clin Pharmacol J New Drugs. 68;8(5):281-4. Narrative review. [pmid: 4877183].
Brawley OW, Thompson IM. The chemoprevention of prostate cancer and the Prostate Cancer Prevention Trial. Cancer Treat Res. 96;88:189-200. Narrative review. [pmid: 9239480].
Bridge EV. Chemoprophylaxis: a major adjunct in the prevention of tuberculosis. Mich Med. 67;66(24):1553-5. Does not apply to the key questions, does not address the use of supplements, does not cover the defined disease endpoints. [pmid: 6080307].
Brown BG, Zhao XQ, Chait A, et al. Simvastatin and niacin, antioxidant vitamins, or the combination for the prevention of coronary disease. N Engl J Med. 2001;345(22):1583-92. Includes ONLY patients with a particular chronic disease, does not apply to the key questions. [pmid: 11757504].
Brown S. Aspirin and vitamin E of little effect in the prevention of cardiovascular disease or cancers in older women. J Br Menopause Soc. 2005;11(3):80-81. Editorial.
Browne R, Boag F. What is your patient taking? Dietary supplements in an HIV-positive patient. Int J STD Aids. 2005;16(9):639-641. Includes ONLY patients with a particular chronic disease. [pmid: 16176636].
Bruppacher R. Epidemiological criteria for evidence of beneficial or adverse effects of elevated dosages of vitamins. Int J Vitam Nutr Res Suppl. 89;30(-):21-24. Editorial. [pmid: 2507699].
Bucher HC, Cook RJ, Guyatt GH, et al. Effects of dietary calcium supplementation on blood pressure. A meta-analysis of randomized controlled trials. JAMA. 96;275(13):1016-22. Does not cover the defined disease endpoints. [pmid: 8596234].
Buiatti E. Prevention trials on oesophageal and stomach cancer. Eur J Cancer Prev. 94;3(4):379-82. Narrative review. [pmid: 7950900].
Buring JE, Hennekens CH. beta-carotene and cancer chemoprevention. J Cell Biochem Suppl. 95;22:226-30. Narrative review. [pmid: 8538202].
Bussey HJ, DeCosse JJ, Deschner EE, et al. A randomized trial of ascorbic acid in polyposis coli. Cancer. 82;50(7):1434-9. Includes ONLY patients with a particular chronic disease. [pmid: 7049351].
Anonymous. Calcium supplements. Med Lett Drugs Ther 96;38(989):108–109. Narrative review
Anonymous. Calcium-D-glucarate. Altern Med Rev 2002;7(4):336–339. Does not address the use of supplements
Siegel BV, Leibovitz B. The multifactorial role of vitamin C in health and disease. Int J Vitam Nutr Res Suppl. 82;23:9-22. No human data. [pmid: 6181000].
Camarasa JG, Serra-Baldrich E, Lluch M. Contact allergy to vitamin B6. Contact Dermatitis. 90;23(2):115. Does not apply to the key questions, Does not address the use of supplements. [pmid: 2145120].
Camarasa JG, Serra-Baldrich E, Lluch M. Contact allergy to vitamin B6. Contact Dermatitis. 90;23(2):115. [pmid: 2145120].
Canner PL, Berge KG, Wenger N K, et al. Fifteen year mortality in Coronary Drug Project patients: long-term benefit with niacin. J Am Coll Cardiol. 86;8(6):1245-55. Includes ONLY patients with a particular chronic disease. [pmid: 3782631].
Canter PH, Ernst E. Herbal supplement use by persons aged over 50 years in Britain: Frequently used herbs, concomitant use of herbs, nutritional supplements and prescription drugs, rate of informing doctors and potential for negative interactions. Drugs Aging. 2004;21(9):597-605. Does not apply to the key questions, Does not address the use of supplements. [pmid: 15260514].
Cats A, Kleibeuker JH, Van der, et al. Randomized, double-blinded, placebo-controlled intervention study with supplemental calcium in families with hereditary nonpolyposis colorectal cancer. J Natl Cancer Inst. 95;87(8):598-603. Includes ONLY patients with a particular chronic disease, Does not cover the defined disease endpoints.
Chan JM, Pietinen P, Virtanen M, et al. Diet and prostate cancer risk in a cohort of smokers, with a specific focus on calcium and phosphorus (Finland). Cancer Causes Control. 2000;11(9):859-67. Does not address the use of supplements. [pmid: 11075876].
Chan P, Huang TY, Chen YJ, et al. Randomized, double-blind, placebo-controlled study of the safety and efficacy of vitamin B complex in the treatment of nocturnal leg cramps in elderly patients with hypertension. J Clin Pharmacol. 98;38(12):1151-4. Does not apply to the key questions.
Chapuy MC, Arlot ME, Duboeuf F, et al. Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med. 92;327(23):1637-42. Includes ONLY patients receiving specified treatments. [pmid: 1331788].
Chen M, Chow SN. Additive effect of alfacalcidol on bone mineral density of the lumbar spine in Taiwanese postmenopausal women treated with hormone replacement therapy and calcium supplementation: a randomized 2-year study. Clin Endocrinol (Oxf). 2001;55(2):253-8. Does not apply to the key questions. [pmid: 11531934].
Chesnut CH 3rd. Osteoporosis and its treatment. N Engl J Med. 92;326(6):406-8. Editorial. [pmid: 1729625].
Childers JM, Chu J, Voigt LF, et al. Chemoprevention of cervical cancer with folic acid: a phase III Southwest Oncology Group Intergroup study. Cancer Epidemiol Biomarkers Prev. 95;4(2):155-9. Does not cover the defined disease endpoints. [pmid: 7742723].
Christen WG, Gaziano JM, Hennekens CH. Design of Physicians' Health Study II--a randomized trial of beta-carotene, vitamins E and C, and multivitamins, in prevention of cancer, cardiovascular disease, and eye disease, and review of results of completed trials. Ann Epidemiol 20. 00;10(2):125-34. Narrative review.
Christiansen C, Christensen MS, McNair P, et al. Prevention of early postmenopausal bone loss: controlled 2-year study in 315 normal females. Eur J Clin Invest. 80;10(4):273-9. Does not apply to the key questions. [pmid: 6253303].
Christiansen C, Rodbro P, Lund M. Effect of vitamin D on bone mineral mass in normal subjects and in epileptic patients on anticonvulsants: a controlled therapeutic trial. Br Med J. 73;2(5860):208-9. Does not cover the defined disease endpoints.
Clarke R, Armitage J. Antioxidant vitamins and risk of cardiovascular disease. Review of large-scale randomised trials. Cardiovasc Drugs Ther. 2002;16(5):411-5. Narrative review. [pmid: 12652110].
Clayton AH. Complementary and alternative medicine. Prim Psychiatry. 2005;12(8):20-21. Editorial.
Clinical development plan: folic acid. J Cell Biochem Suppl. 96;26(-):100-113. Narrative review.
Anonymous. Update on isotretinoin (Accutane) for acne. Med Lett Drugs Ther 83;25(649):105–6. Includes ONLY patients with a particular chronic disease
Anonymous. Clofibrate and niacin in coronary heart disease. JAMA 75;231(4):360–81. Does not apply to the key questions
Coburn JW. An update on vitamin D as related to nephrology practice: 2003. Kidney Int Suppl. 2003;64(87):S125-S130. Includes ONLY patients receiving specified treatments, Does not apply to the key questions. [pmid: 14531785].
Combs GF, Clark LC, Turnbull BW. Reduction of cancer mortality and incidence by selenium supplementation. Med Klin (Munich). 97;92(Suppl):342-5. Includes ONLY patients receiving specified treatments, Includes ONLY patients receiving specified treatments.
Collins R, Peto R, Armitage J. The MRC/BHF Heart Protection Study: preliminary results. Int J Clin Pract. 2002;56(1):53-6. Does not apply to the key questions. [pmid: 11831837].
Combs GF, Combs SB. Selenium effects on drug and foreign compound toxicity. Pharmacol Ther. 87;33(23):303-15. Does not apply to the key questions, Does not address the use of supplements. [pmid: 3310035].
- General. Focus Altern Complement Ther. 2005;10(3):233-235. Editorial.
Compston JE. Pharmacological interventions for post-menopausal osteoporosis: An evidence-based approach. Rheumatology (UK). 2000;39(12):1309-1312. Editorial.
Cook NR, Stampfer MJ, Ma J, et al. (beta)-carotene supplementation for patients with low baseline levels and decreased risks of total and prostate carcinoma. Cancer. 99;86(9):1783-1792. Does not apply to the key questions, Does not address the use of supplements.
Cronin JR. Special report: Dietary supplements. Safety, certification, labeling, and efficacy. Altern Complement Ther. 2002;8(3):141-148. Does not apply to the key questions.
de Groo AC. Contact allergy to calcipotriol. Contact Dermatitis. 94;30(4):242-3. Does not apply to the key questions.
Cronin JR. Special report: Dietary supplements. Safety, certification, labeling, and efficacy. Altern Complement Ther. 2002;8(3):141-148.
Anonymous. Cutaneous drug reaction case reports: from the world literature. Am J Clin Dermatol 2003;4(5):365–70. Does not apply to the key questions, Does not address the use of supplements, Does not cover the defined disease endpoints
Czeizel AE, Dudas I, Fritz G, et al. The effect of periconceptional multivitamin-mineral supplementation on vertigo, nausea and vomiting in the first trimester of pregnancy. Arch Gynecol Obstet. 92;251(4):181-5. Includes ONLY pregnant women. [pmid: 1503509].
Czeizel AE. Reduction of urinary tract and cardiovascular defects by periconceptional multivitamin supplementation. Am J Med Genet. 96;62(2):179-83. Does not cover the defined disease endpoints. [pmid: 8882400].
Dangour AD, Sibson VL, Fletcher AE. Micronutrient supplementation in later life: limited evidence for benefit. J Gerontol A Biol Sci Med Sci. 2004;59(7):659-73. Narrative review. [pmid: 15304530].
Dawsey SM, Wang GQ, Taylor PR, et al. Effects of vitamin/mineral supplementation on the prevalence of histological dysplasia and early cancer of the esophagus and stomach: results from the Dysplasia Trial in Linxian, China. Cancer Epidemiol Biomarkers Prev. 94;3(2):167-72. Includes ONLY patients with a particular chronic disease.
Dawson MI. The importance of vitamin A in nutrition. Curr Pharm Des. 2000;6(3):311-325. Narrative review. [pmid: 10637381].
Dawson-Hughes B. Vitamin D and calcium: recommended intake for bone health. Osteoporos Int. 98;8(Suppl 2):S30-4. Narrative review. [pmid: 10197180].
de Groo A C. Contact allergy to calcipotriol. Contact Dermatitis. 94;30(4):242-3. Does not address the use of supplements.
de Klerk NH, Musk AW, Ambrosini GL, et al. Vitamin A and cancer prevention II: comparison of the effects of retinol and beta-carotene. Int J Cancer. 98;75(3):362-7. Includes ONLY patients with a particular chronic disease, Does not apply to the key questions.
Dean BS, Krenzelok EP. Multiple vitamins and vitamins with iron: Accidental poisoning in children. Vet Hum Toxicol. 88;30(1):23-25. Narrative review. [pmid: 3354178].
DeAngelis CD, Fontanarosa PB. Drugs Alias Dietary Supplements. JAMA. 2003;290(11):1519-1520. Editorial. [pmid: 13129996].
Debourdeau PM, Djezzar S, Estival JL, et al. Life-threatening eosinophilic pleuropericardial effusion related to vitamins B5 and H. Ann Pharmacother. 2001;35(4):424-6. Does not apply to the key questions, Does not address the use of supplements. [pmid: 11302404].
DeCosse JJ, Miller HH, Lesser ML. Effect of wheat fiber and vitamins C and E on rectal polyps in patients with familial adenomatous polyposis. J Natl Cancer Inst. 89;81(17):1290-7. Includes ONLY patients with a particular chronic disease. [pmid: 2549261].
Dembinska-Kiec A. Carotenoids: Risk or benefit for health. Biochim Biophys Acta. 2005;1740(2):93-94. Editorial. [pmid: 15949673].
Dennehy CE, Tsourounis C, Horn AJ. Dietary supplement-related adverse events reported to the California Poison Control System. Am J Health-Syst Pharm. 2005;62(14):1476-1482. Narrative review. [pmid: 15998927].
Dimery IW, Hong WK, Lee JJ, et al. Phase I trial of alpha-tocopherol effects on 13-cis-retinoic acid toxicity. Ann Oncol. 97;8(1):85-9. Includes ONLY patients with a particular chronic disease, Includes ONLY patients receiving specified treatment, Does not apply to the key questions, Does not cover the defined disease endpoints.
Domrongkitchaiporn S, Ongphiphadhanakul B, Stitchantrakul W, et al. Risk of calcium oxalate nephrolithiasis in postmenopausal women supplemented with calcium or combined calcium and estrogen. Maturitas. 2002;41(2):149-56. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 11836046].
Domrongkitchaiporn S, Sopassathit W, Stitchantrakul W, et al. Schedule of taking calcium supplement and the risk of nephrolithiasis. Kidney Int. 2004;65(5):1835-41. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 15086924].
Dursun N, Dursun E, Yalcin S. Comparison of alendronate, calcitonin and calcium treatments in postmenopausal osteoporosis. Int J Clin Pract. 2001;55(8):505-9. Does not apply to the key questions. [pmid: 11695068].
Duthie GG, Arthur JR, Beattie JA, et al. Cigarette smoking, antioxidants, lipid peroxidation, and coronary heart disease. NY Acad. 93;686:120-9. Does not address the use of supplements, Does not cover the defined disease endpoints.
El-Kadiki A, Sutton AJ. Role of multivitamins and mineral supplements in preventing infections in elderly people: Systematic review and meta-analysis of randomised controlled trials. BMJ. 2005;330(7496):871-874. Does not cover the defined disease endpoints. [pmid: 15805125]. [pmcid: 556155].
Elliott RB, Pilcher CC, Fergusson DM, et al. A population based strategy to prevent insulin-dependent diabetes using nicotinamide. J Pediatr Endocrinol Metab. 96;9(5):501-9. Efficacy study of subjects less than 19 years old only. [pmid: 8961125].
Engelen W, Keenoy BM, Vertommen J, et al. Effects of long-term supplementation with moderate pharmacologic doses of vitamin E are saturable and reversible in patients with type 1 diabetes. Am J Clin Nutr. 2000;72(5):1142-9. Includes ONLY patients with a particular chronic disease, Does not cover the defined disease endpoints. [pmid: 11063441].
Evans CDH, Lacey JH. Toxicity of vitamins: Complications of a health movement. BMJ. 86;292(6519):509-510. Narrative review. [pmid: 3081147].
Anonymous. Evidence of harm from antioxidant supplements. Pharm J 2004;273(7320):506. Editorial
Exner JH, Dahod S, Pochi PE. Pyogenic granuloma-like acne lesions during isotretinoin therapy. Arch Dermatol. 83;119(10):808-11. Does not apply to the key questions, Does not address the use of supplements, Does not cover the defined disease endpoints.
Fabricius P, Lange P. Diet and lung cancer. Monaldi Arch Chest Dis Pulm Ser. 2003;59(3):207-211. Does not apply to the key questions.
Fabricius P, Lange P. Diet and lung cancer. Monaldi Arch Chest Dis Pulm Ser. 2003;59(3):207-211. Narrative review.
Faivre J, Boutron MC, Doyon F, et al. The ECP calcium fibre polyp prevention study preliminary report. ECP Colon Group. Eur J Cancer Prev. 93;2(Suppl 2-):99-106. Includes ONLY patients with a particular chronic disease, Does not apply to the key questions, Does not cover the defined disease endpoints.
Faivre J, Couillault C, Belghiti C. Intervention trials on colorectal cancer prevention. IARC Sci Publ 96;(139):115–24. Narrative review
Faivre J, Doyon F, Boutron MC. The ECP calcium fibre polyp prevention study. The ECP Colon Group. Eur J Cancer Prev. 91;1(Suppl):283-9. Does not cover the defined disease endpoints.
Farvid MS, Jalali M, Siassi F, et al. The impact of vitamins and/or mineral supplementation on blood pressure in type 2 diabetes. J Am Coll Nutr. 2004;23(3):272-9. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 15190052].
Finer NN, Schindler RF, Peters KL, et al. Vitamin E and retrolental fibroplasia. Improved visual outcome with early vitamin E. Ophthalmology. 83;90(5):428-35. Includes only infiants. [pmid: 6348635].
Fisher AA. Three faces of vitamin E topical allergy. Cutis. 91;48(4):272-4. Does not address the use of supplements. [pmid: 1835916].
Fisher AA. Unusual acute, nonallergic eruptions of the scalp from combined use of minoxidil and retinoic acid. Cutis. 93;51(1):17-8. Does not apply to the key questions. [pmid: 8419103].
Floren LC, Zangwill AC, Schroeder DJ. Antioxidants may retard cataract formation. Ann Pharmacother. 94;28(9):1040-2. Editorial. [pmid: 7803880].
Florentino RF, Tanchoco CC, Ramos AC, et al. Tolerance of preschoolers to two dosage strengths of vitamin A preparation. Am J Clin Nutr. 90;52(4):694-700. Only covers nutritional deficiency. [pmid: 2403062].
Flynn CA. Calcium supplementation in postmenopausal women. Am Fam Phys. 2004;69(12):2822-2823. Narrative review.
Fox W, Robinson DK, Tall R, et al. A study of acute intolerance to ethionamide, including a comparison with prothionamide, and of the influence of a vitamin B-complex additive in prophylaxis. Tubercle. 69;50(2):125-43. Includes ONLY patients with a particular chronic disease, Includes ONLY patients receiving specified treatments, Does not apply to the key questions.
Fraga CG. Relevance, essentiality and toxicity of trace elements in human health. Mol Asp Med. 2005;26(45 SPEC. ISS.):235-244. Narrative review.
Frank DH, Roe DJ, Chow HH, et al. Effects of a high-selenium yeast supplement on celecoxib plasma levels: a randomized phase II trial. Cancer Epidemiol Biomarkers Prev. 2004;13(2):299-303. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 14973093].
Fraunfelder FW. The science and marketing of dietary supplements. Am J Ophthalmol. 2005;140(2):302-304. Does not apply to the key questions. [pmid: 16086950].
Fraunfelder FW. The science and marketing of dietary supplements. Am J Ophthalmol. 2005;140(2):302-304. Editorial. [pmid: 16086950].
Fuller CJ, Chandalia M, Garg A, et al. RRR-alpha-tocopheryl acetate supplementation at pharmacologic doses decreases low-density-lipoprotein oxidative susceptibility but not protein glycation in patients with diabetes mellitus. Am J Clin Nutr. 96;63(5):753-9. Includes ONLY patients with a particular chronic disease, Does not cover the defined disease endpoints.
Fuller CJ, Grundy SM, Norkus EP, et al. Effect of ascorbate supplementation on low density lipoprotein oxidation in smokers. Atherosclerosis. 96;119(2):139-50. Does not cover the defined disease endpoints. [pmid: 8808491].
Gardiner P. Dietary supplement use in children: Concerns of efficacy and safety. Am Fam Phys. 2005;71(6):1068-1071. Narrative review.
Garland C, Shekelle RB, Barrett-Connor E, et al. Dietary vitamin D and calcium and risk of colorectal cancer: a 19-year prospective study in men. Lancet. 85;1(8424):307-9. Does not address the use of supplements. [pmid: 2857364].
Gaulin C. Food poisoning involving a chemical product--Quebec. Can Commun Dis Rep. 93;19(11):80-3. Does not apply to the key questions, Does not address the use of supplements. [pmid: 8348102].
Gaziano JM, Hennekens CH. The role of beta-carotene in the prevention of cardiovascular disease. NY Acad. 93;691:148-55. Narrative review.
Geleijnse JM, Grobbee DE. Calcium intake and blood pressure: an update. J Cardiovasc Risk. 2000;7(1):23-9. Narrative review. [pmid: 10785870].
Goldberg SH, Von Feldt JM, Lonner JH. Pharmacologic therapy for osteoarthritis. Am J Orthop. 2002;31(12):673-80. Narrative review. [pmid: 12498526].
Goodman GE, Valanis B, Meyskens FL, et al. Strategies for recruitment to a population-based lung cancer prevention trial: the CARET experience with heavy smokers. Beta-Carotene and Retinol Efficacy Trial. Cancer Epidemiol Biomarkers Prev. 98;7(5):405-12.
Goorin AM, Abelson HT, Frei E, et al. Osteosarcoma: fifteen years later. N Engl J Med. 85;313(26):1637-43. Narrative review. [pmid: 3906399].
Greenberg ER, Baron JA, Stevens MM, et al. The Skin Cancer Prevention Study: design of a clinical trial of beta-carotene among persons at high risk for nonmelanoma skin cancer. Control Clin Trials. 89;10(2):153-66. Other. [pmid: 2666024].
Greenberg ER, Baron JA, Tosteson TD, et al. A clinical trial of antioxidant vitamins to prevent colorectal adenoma. New Engl J Med. 94;331(3):141-147. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 8008027].
Griffiths LL. Myoedema and vitamins. BMJ. 69;3(665):299. Editorial. [pmid: 5800373].
Gurlek A, Bayraktar M, Gedik O. Comparison of calcitriol treatment with etidronate-calcitriol and calcitonin-calcitriol combinations in Turkish women with postmenopausal osteoporosis: a prospective study. Calcif Tissue Int. 97;61(1):39-43. Includes ONLY patients with a particular chronic disease, Does not address the use of supplements.
Hall WD, Davis BR, Frost P et al. Systolic Hypertension in the Elderly Program (SHEP). Part 7: Baseline laboratory characteristics Hypertension 91;17(3 Suppl):II102–22. Does not apply to the key questions
Hanck A, Altman RF, Fidanza A, et al. Workshop on the role of vitamin C in lipid metabolism. Int J Vitam Nutr Res Suppl. 82;23(-):197-207. Editorial. [pmid: 6811481].
Hathcock JN. Vitamins and minerals: Efficacy and safety. Am J Clin Nutr. 97;66(2):427-437. Does not apply to the key questions. [pmid: 9250127].
Hayasaka E. Randomized trial of aspirin, vitamin E raises questions for future chemoprevention studies. J Natl Cancer Inst. 2005;97(17):1242-1243. Editorial. [pmid: 16145040].
Head A. Treatment of intermittent claudication with inositol nicotinate. Practitioner. 86;230(1411):49-54. Includes ONLY patients with a particular chronic disease, Does not cover the defined disease endpoints. [pmid: 3513149].
Helfman RJ, Brickman M, Fahey J. Isotretinoin dermatitis simulating acute pityriasis rosea. Cutis. 84;33(3):297-300. Does not address the use of supplements, Does not cover the defined disease endpoints. [pmid: 6233097].
Hennekens CH, Eberlein K. A randomized trial of aspirin and beta-carotene among U.S. physicians. Prev Med. 85;14(2):165-8. Narrative review. [pmid: 3900975].
Hennekens CH. Vitamin A analogues in cancer chemoprevention. Important Adv Oncol 86;23–35. Narrative review
Hercberg S, Galan P, Preziosi P, et al. Background and rationale behind the SU.VI.MAX Study, a prevention trial using nutritional doses of a combination of antioxidant vitamins and minerals to reduce cardiovascular diseases and cancers. Supplementation en Vitamines et Mineraux AntioXydants Study. Int J Vitam Nutr Res. 98;68(1):3-20. Narrative review.
Hercberg S, Galan P, Preziosi P, et al. The SU.VI.MAX trial on antioxidants. IARC Sci Publ. 2002;156:451-5. Does not apply to the key questions. [pmid: 12484233].
Hercberg S, Preziosi P, Briancon S, et al. A primary prevention trial using nutritional doses of antioxidant vitamins and minerals in cardiovascular diseases and cancers in a general population: the SU.VI.MAX study--design, methods, and participant characteristics. Supplementation en Vitamines et Mineraux AntioXydants. Control Clin Trials. 98;19(4):336-51. Other.
Hercberg S, Preziosi P, Galan P, et al. “The SU.VI.MAX Study”: a primary prevention trial using nutritional doses of antioxidant vitamins and minerals in cardiovascular diseases and cancers. Supplementation on Vitamines et Mineraux AntioXydants. Food Chem Toxicol. 99;37(910):925-30. Other.
Hofstad B, Almendingen K, Vatn M, et al. Growth and recurrence of colorectal polyps: a double-blind 3-year intervention with calcium and antioxidants. Digestion. 98;59(2):148-56. Includes ONLY patients receiving specified treatments. [pmid: 9586828].
Hoogwerf BJ, Young JB. The HOPE study. Ramipril lowered cardiovascular risk, but vitamin E did not. Cleve Clin J Med. 2000;67(4):287-93. Narrative review. [pmid: 10780101].
Horsman A, Gallagher JC, Simpson M, et al. Prospective trial of oestrogen and calcium in postmenopausal women. Br Med J. 77;2(6090):789-92. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 912324].
Hsu CH, Patel SR. Uremic toxins and vitamin D metabolism. Kidney Int Suppl. 97;51(62):S65-S68. Does not apply to the key questions, Does not address the use of supplements.
Kingston TP, Lowe NJ, Winston J, et al. Visual and cutaneous toxicity which occurs during N-(4-hydroxyphenyl) retinamide therapy for psoriasis. Clin Exp Dermatol. 86;11(6):624-7. Does not address the use of supplements. [pmid: 2959409].
Huttunen JK. Health effects of supplemental use of antioxidant vitamins. Experiences from the alpha-tocopherol beta-carotene (ATBC) cancer prevention study. Scand J Nutr. 95;39(3):103-104. Does not apply to the key questions.
Hyman J, Baron JA, Dain BJ, et al. Dietary and supplemental calcium and the recurrence of colorectal adenomas. Cancer Epidemiol Biomarkers Prev. 98;7(4):291-5. Narrative review. [pmid: 9568783].
Inkeles SB, Connor WE, Illingworth DR. Hepatic and dermatologic manifestations of chronic hypervitaminosis A in adults. Report of two cases. Am J Med. 86;80(3):491-6. [pmid: 2937294].
Jain S K, McVie R, Jaramillo J J, et al. The effect of modest vitamin E supplementation on lipid peroxidation products and other cardiovascular risk factors in diabetic patients. Lipids. 96;31(Suppl):S87-90. Includes ONLY patients with a particular chronic disease, Does not cover the defined disease endpoints.
Jansen T, Romiti R, Kreuter A, et al. Rosacea fulminans triggered by high-dose vitamins B6 and B12. J Eur Acad Dermatol Venereol. 2001;15(5):484-5. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 11763399].
Javed MS, Taylor I. A review of recent randomized trials in colorectal disease. Colorectal Dis. 2002;4(2):90-96. Narrative review. [pmid: 12780628].
Jeppsen RB. Toxicology and safety of Ferrochel and other iron amino acid chelates. Arch Latinoam Nutr. 2001;51(1 Suppl 1):26-34. Narrative review. [pmid: 11688078].
Jha P, Flather M, Lonn E, et al. The antioxidant vitamins and cardiovascular disease. A critical review of epidemiologic and clinical trial data. Ann Intern Med. 95;123(11):860-72. Narrative review. [pmid: 7486470].
Johnston CS. Biomarkers for establishing a tolerable upper intake level for vitamin C. Nutr Rev. 99;57(3):71-77. Does not apply to the key questions. [pmid: 10101920].
Kaikkonen J, Porkkala-Sarataho E, Morrow JD, et al. Supplementation with vitamin E but not with vitamin C lowers lipid peroxidation in vivo in mildly hypercholesterolemic men. Free Radic Res. 2001;35(6):967-78. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 11811547].
Kaplan G, Haettich B. Rheumatological symptoms due to retinoids. Baillieres Clin Rheumatol. 91;5(1):77-97. Narrative review.
Kaplan G, Haettich B. Rheumatological symptoms due to retinoids. Baillieres Clin Rheumatol. 91;5(1):77-97. Other. [pmid: 2070429].
Kato T, Chen JT, Katase K, et al. Effect of 1 alpha-hydroxyvitamin D3 on loss of bone mineral density immediately after artificial menopause. Endocr J. 97;44(2):299-304. Includes ONLY patients with a particular chronic disease. [pmid: 9228466].
Kelloff GJ, Crowell JA, Boone CW, et al. Clinical development plan: vitamin E. J Cell Biochem Suppl. 94;20(-):282-299. Other. [pmid: 7616751].
Kelloff GJ, Crowell JA, Boone CW, et al. Clinical development plan: beta-carotene and other carotenoids. J Cell Biochem Suppl. 94;20(-):110-140. Other. [pmid: 7616738].
Kelly JP, Kaufman DW, Kelley K, et al. Trends in dietary and herbal supplement use in the United States. J Clin Outcomes Manage. 2005;12(4):184-185. Editorial.
Kent S. Vitamin C therapy: colds, cancer, and cardiovascular disease. Geriatrics 78;33(10):91–4, 99. Narrative review
Kiely M, Flynn A, Harrington KE, et al. The efficacy and safety of nutritional supplement use in a representative sample of adults in the North/South Ireland Food Consumption Survey. Public Health Nutr. 2001;4(5A):1089-1097. Does not apply to the key questions. [pmid: 11820922].
Kiely M, Flynn A, Harrington KE, et al. The efficacy and safety of nutritional supplement use in a representative sample of adults in the North/South Ireland Food Consumption Survey. Public Health Nutr. 2001;4(5A):1089-1097. Other. [pmid: 11820922].
Kim I, Williamson DF, Byers T, et al. Vitamin and mineral supplement use and mortality in a US cohort. Am J Public Health. 93;83(4):546-550. Does not apply to the key questions. [pmid: 8460732].
Kingston TP, Lowe NJ, Winston J, et al. Visual and cutaneous toxicity which occurs during N-(4-hydroxyphenyl) retinamide therapy for psoriasis. Clin Exp Dermatol. 86;11(6):624-7. Does not apply to the key questions, Does not cover the defined disease endpoints.
Kingston TP, Lowe NJ, Winston J, et al. Visual and cutaneous toxicity which occurs during N-(4-hydroxyphenyl) retinamide therapy for psoriasis. Clin Exp Dermatol. 86;11(6):624-7. Other. [pmid: 2959409].
Kirkwood BR, Ross DA, Arthur P, et al. Effect of vitamin A supplementation on the growth of young children in northern Ghana. Am J Clin Nutr. 96;63(5):773-81. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 8615363].
Knodel LC, Talbert RL. Adverse effects of hypolipidaemic drugs. Med Toxicol. 87;2(1):10-32. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 3547004].
Knopp RH. Evaluating niacin in its various forms. Am J Cardiol. 2000;86(12A):51L-56L. Does not apply to the key questions.
Kritharides L, Stocker R. The use of antioxidant supplements in coronary heart disease. Atherosclerosis. 2002;164(2):211-9. Narrative review. [pmid: 12204790].
Krone CA, Harms LC, Leitzmann M F, et al. Re: Zinc supplement use and risk of prostate cancer (multiple letters) [4]. J Natl Cancer Inst. 2003;95(20):1556-1557. Editorial. [pmid: 14559884].
Krueger KJ, McClain CJ, McClave SA, et al. Nutritional supplements and alternative medicine. Curr Opin Gastroenterol. 2004;20(2):130-138. Narrative review. [pmid: 15703634].
Kruesi MJ, Rapoport JL. Diet and human behavior: how much do they affect each other? Annu Rev Nutr 86;6113–30. Narrative review
Kumar A, Aitas A T, Hunter AG, et al. Sweeteners, dyes, and other excipients in vitamin and mineral preparations. Clin Pediatr (Phila). 96;35(9):443-50. Does not apply to the key questions. [pmid: 8877241].
Lau EM, Woo J, Leung PC, et al. The effects of calcium supplementation and exercise on bone density in elderly Chinese women. Osteoporos Int. 92;2(4):168-73. Includes ONLY patients receiving specified treatments. [pmid: 1611221].
Leger CS, Teik Chye Ooi. Ferrous fumarate-induced malabsorption of thyroxine. Endocrinologist. 99;9(6):493-495. Does not apply to the key questions.
Levine MN, Anderson DR. Side-effects of antithrombotic therapy. Baillieres Clin Haematol. 90;3(3):815-29. Does not apply to the key questions, Does not address the use of supplements. [pmid: 2148698].
Li B, Taylor PR, Li JY, et al. Linxian nutrition intervention trials. Design, methods, participant characteristics, and compliance. Ann Epidemiol. 93;3(6):577-85. Does not apply to the key questions. [pmid: 7921303].
Liede K, Hietanen J, Saxen L, et al. Long-term supplementation with alpha-tocopherol and beta-carotene and prevalence of oral mucosal lesions in smokers. Oral Dis. 98;4(2):78-83. Does not apply to the key questions, Does not cover the defined disease endpoints.
Lim LS, Fink HA, Kuskowski MA, et al. Diuretic use and bone mineral density in older USA men: The osteoporotic fractures in men (MrOS) study [4]. Age Ageing. 2005;34(5):504-507. Does not apply to the key questions, Does not report supplement use separately. [pmid: 16107456]. [pmcid: 1963467].
Lonn EM, Yusuf S. Is there a role for antioxidant vitamins in the prevention of cardiovascular diseases? An update on epidemiological and clinical trials data. Can J Cardiol. 97;13(10):957-65. Narrative review. [pmid: 9374952].
Macdougall IC. Strategies for iron supplementation: oral versus intravenous. Kidney Int Suppl. 99;69(-):S61-66. Includes ONLY patients receiving specified treatments. [pmid: 10084288].
Machlin LJ. Use and safety of elevated dosages of vitamin E in adults. Int J Vitam Nutr Res Suppl. 89;30(-):56-68. Narrative review. [pmid: 2507707].
Maeda K, Okamoto N, Nishimoto M, et al. A multicenter study of the effects of vitamin B12 on sleep-waking rhythm disorders: in Shizuoka Prefecture. Jpn J Psychiatry Neurol. 92;46(1):229-30. Does not apply to the key questions. [pmid: 1635320].
Malten KE. Flare reaction due to vitamin B12 in a patient with psoriasis and contact eczema. Contact Dermatitis. 75;1(5):325-6. Does not apply to the key questions. [pmid: 139261].
Manson JE, Buring JE, Satterfield S, et al. Baseline characteristics of participants in the Physicians' Health Study: a randomized trial of aspirin and beta-carotene in U.S. physicians. Am J Prev Med. 91;7(3):150-4. Does not apply to the key questions.
Mariani SM. Phytoestrogens and antioxidants - Bits of experimental evidence. Medgenmed Medscape Gen Med. 2005;7(1):6p. Editorial.
Mark SD, Liu SF, Li JY, et al. The effect of vitamin and mineral supplementation on esophageal cytology: results from the Linxian Dysplasia Trial. Int J Cancer. 94;57(2):162-6. Includes ONLY patients with a particular chronic disease. [pmid: 8157352].
Marks J. The safety of the vitamins: an overview. Int J Vitam Nutr Res Suppl. 89;30(-):12-20. Narrative review. [pmid: 2507691].
Martin GJ. The myth of the magic bullet. Exp Med Surg. 64;22(2):199-211. Narrative review. [pmid: 5888678].
Mason P. New advice on safety of high doses of vitamins and minerals clarifies muddle. Pharm J. 2003;270(7249):677-678. Editorial.
Maxwell S, Greig L. Anti-oxidants-- a protective role in cardiovascular disease. Expert Opin Pharmacother. 2001;2(11):1737-50. Narrative review. [pmid: 11825313].
Mayne ST, Zheng T, Janerich DT, et al. A population-based trial of beta-carotene chemoprevention of head and neck cancer. Adv Exp Med Biol. 92;320:119-27. Includes ONLY patients with a particular chronic disease, Includes ONLY patients receiving specified treatments.
McCann MA. Dietary supplement labeling: Cognitive biases, market manipulation & consumer choice. Am J Law Med. 2005;31(23):215-268. Editorial. [pmid: 16146289].
McClinton-Adams JL, Hart LL. Cancer prevention with beta carotene. Ann Pharmacother. 94;28(4):470-2. Narrative review. [pmid: 8038470].
McKeown-Eyssen G, Holloway C, Jazmaji V, et al. A randomized trial of vitamins C and E in the prevention of recurrence of colorectal polyps. Cancer Res. 88;48(16):4701-5. Does not apply to the key questions, Does not cover the defined disease endpoints.
McLarty JW. An intervention trial in high-risk asbestos-exposed persons. Adv Exp Med Biol. 92;320:141-9. Does not cover the defined disease endpoints. [pmid: 1442279].
McLean J. The placebo effect. Drug trial considerations. Nurs Times. 90;86(17):31-3. Editorial. [pmid: 2185458].
Menna VJ. Index of suspicion. Case 2. Diagnosis: niacin overdose. Pediatr Rev. 93;14(11):433-5. Does not apply to the key questions. [pmid: 8284280].
Meunier PJ. Evidence based medicine and osteoporosis: a comparison of fracture risk reduction data from osteoporosis randomised clinical trials. Int J Clin Pract. 99;53(2):122. Does not report all trial results. [pmid: 10344048].
Meyskens FL, Gilmartin E, Alberts DS, et al. Activity of isotretinoin against squamous cell cancers and preneoplastic lesions. Cancer Treat Rep. 82;66(6):1315-9. Does not cover the defined disease endpoints. [pmid: 6211233].
Miettinen TA, Taskinen MR, Pelkonen R, et al. Glucose tolerance and plasma insulin in man during acute and chronic administration of nicotinic acid. Acta Med Scand. 69;186(4):247-53. Does not apply to the key questions, Does not cover the defined disease endpoints.
Miller KL, Liebowitz RS, Newby LK. Complementary and alternative medicine in cardiovascular disease. A review of biologically based approaches. Am Heart J. 2004;147(3):401-411. Narrative review. [pmid: 14999187].
Mills E, Prousky J, Raskin G et al. The safety of over-the-counter niacin. A randomized placebo-controlled trial. BMC Clin Pharmacol 2003;34. Does not apply to the key questions
Mitchell JR, Corcoran GB, Smith CV, et al. Alkylation and peroxidation injury from chemically reactive metabolites. Adv Exp Med Biol. 81;136(Pt A):199-223. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 7344457].
Montessori ML, Scheele WH, Netelenbos JC, et al. The use of etidronate and calcium versus calcium alone in the treatment of postmenopausal osteopenia: results of three years of treatment. Osteoporos Int. 97;7(1):52-8. Does not provide a placebo group.
Moon JC. A brief history of vitamin D toxicity. J Appl Nutr. 97;49(12):18-31. Narrative review.
MRC/BHF Heart Protection Study Collaborative Group. Heart Protection Study of cholesterol-lowering therapy and of antioxidant vitamin supplementation in a wide range of patients at increased risk of coronary heart disease death: early safety and efficacy experience. Eur Heart J. 99;20(10):725-41. Does not apply to the key questions.
Munoz N, Hayashi M, Bang LJ, et al. Effect of riboflavin, retinol, and zinc on micronuclei of buccal mucosa and of esophagus a randomized double-blind intervention study in China. J Natl Cancer Inst. 87;79(4):687-9. Does not cover the defined disease endpoints.
Nair KM. Alternate strategies for improving iron nutrition: Lessons from recent research. Br J Nutr. 2001;85(SUPPL. 2):S187-S191. Narrative review. [pmid: 11509109].
Nelson ME, Fisher EC, Dilmanian FA, et al. A 1-y walking program and increased dietary calcium in postmenopausal women: effects on bone. Am J Clin Nutr. 91;53(5):1304-11. Does not address the use of supplements. [pmid: 2021138].
Newport A, Lockwood B. Use of nutraceuticals for eye health. Pharm J. 2005;275(7364):261-264. Narrative review.
Noah BA. Foreword Dietary supplement regulation in flux. Am J Law Med. 2005;31(23):147-153. Editorial.
Nolan CR, DeGoes JJ, Alfrey AC. Aluminum and lead absorption from dietary sources in women ingesting calcium citrate. South Med J. 94;87(9):894-898. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 8091252].
Novick NL, Lawson W, Schwartz IS. Bilateral nasal bone osteophytosis associated with short-term oral isotretinoin therapy for cystic acne vulgaris. Am J Med. 84;77(4):736-9. Does not apply to the key questions, Does not address the use of supplements.
O'Brien KO. Combined calcium and vitamin D supplementation reduces bone loss and fracture incidence in older men and women. Nutr Rev. 98;56(5 Pt 1):148-50. Narrative review. [pmid: 9624885].
O'Brien MM, Kiely M, Harrington KE, et al. The North/South Ireland Food Consumption Survey: Vitamin intakes in 18–64-year-old adults. Public Health Nutr. 2001;4(5 A):1069-1079. Does not apply to the key questions, Does not address the use of supplements, Does not report supplement use separately. [pmid: 11820920].
Oldreive S. Safe intakes of vitamins and minerals: Recommendations from the Expert Group on Vitamins and Minerals. Nutr Bull. 2003;28(2):199-202. Does not apply to the key questions.
Omaye ST, Krinsky NI, Kagan VE, et al. (beta)-Carotene: Friend or Foe?. Fundam Appl Toxicol. 97;40(2):163-174. Narrative review. [pmid: 9441712].
Onel S. Dietary supplements: A definition that is black, white, and gray. Am J Law Med. 2005;31(23):341-348. Editorial. [pmid: 16146293].
Opara EC. Oxidative stress, micronutrients, diabetes mellitus and its complications. J R Soc Promot Health. 2002;122(1):28-34. Narrative review. [pmid: 11989140].
Pak RW, Lanteri VJ, Scheuch JR, et al. Review of vitamin E and selenium in the prevention of prostate cancer: implications of the selenium and vitamin E chemoprevention trial. Integr Cancer Ther. 2002;1(4):338-44. Narrative review. [pmid: 14664728].
Palestine AG. Transient acute myopia resulting from isotretinoin (accutane) therapy. Ann Ophthalmol 84;16(7):660, 662. Does not apply to the key questions, Does not cover the defined disease endpoints
Pandey DK, Shekelle R, Selwyn BJ, et al. Dietary vitamin C and beta-carotene and risk of death in middle-aged men. The Western Electric Study. Am J Epidemiol. 95;142(12):1269-7. Does not address the use of supplements, Does not report supplement use separately.
Papagaroufalis C, Megreli C, Hagjigeorgi C, et al. A trial of vitamin A supplementation for the prevention of intraventricular hemorrhage in very low birth weight neonates. J Perinat Med. 91;19(Suppl):1382-7. Does not address the use of supplements, Includes only infiants.
Parkman CA. NCCAM herbal supplement studies underway in the United States. Case Manager. 2005;16(3):41-43. Narrative review. [pmid: 15999084].
Patruta SI, Horl WH. Iron and infection. Kidney Int Suppl. 99;55(69):S125-S130. Does not address the use of supplements.
Pauling L, Anderson R, Banic S, et al. Workshop on vitamin C in immunology and cancer. Int J Vitam Nutr Res Suppl. 82;23(-):209-219. Editorial. [pmid: 6180999].
Pelton R. Keeping a watch on vision. Am Drug. 99;216(5):50-51. Narrative review.
Peng CC, Glassman PA, Trilli LE, et al. Incidence and Severity of Potential Drug-Dietary Supplement Interactions in Primary Care Patients. An Exploratory Study of 2 Outpatient Practices. Arch Intern Med. 2004;164(6):630-636. Narrative review. [pmid: 15037491].
Peretz A, Neve J, Duchateau J, et al. Adjuvant treatment of recent onset rheumatoid arthritis by selenium supplementation: preliminary observations. Br J Rheumatol. 92;31(4):281-2. Includes ONLY patients with a particular chronic disease, Does not apply to the key questions.
Perharic L, Shaw D, Colbridge M, et al. Toxicological problems resulting from exposure to traditional remedies and food supplements. Drug Saf. 94;11(4):284-29. Narrative review. [pmid: 7848547].
Pettinger MB, Waclawiw MA, Davis KB, et al. Compliance to multiple interventions in a high risk population. Ann Epidemiol. 99;9(7):408-18. Includes ONLY patients with a particular chronic disease, Does not cover the defined disease endpoints. [pmid: 10501408].
Pociot F, Reimers JI, Andersen HU. Nicotinamide--biological actions and therapeutic potential in diabetes prevention. IDIG Workshop, Copenhagen, Denmark, 4–5 December 1992. Diabetologia. 93;36(6):574-6. Does not apply to the key questions. [pmid: 8335182].
Pouilles JM, Tremollieres F, Ribot C. Prevention of post-menopausal bone loss with 1 alpha-hydroxy vitamin D3. A three-year prospective study. Clin Rheumatol. 92;11(4):492-7. Does not apply to the key questions. [pmid: 1486738].
Pozzilli P, Visalli N, Cavallo MG, et al. Vitamin E and nicotinamide have similar effects in maintaining residual beta cell function in recent onset insulin-dependent diabetes (the IMDIAB IV study). Eur J Endocrinol. 97;137(3):234-9. Includes ONLY patients with a particular chronic disease.
Anonymous. Preventing wintertime bone loss: effects of vitamin D supplementation in healthy postmenopausal women. Nutr Rev 92;50(2):52–4. Editorial
Prince RL, Smith M, Dick IM, et al. Prevention of postmenopausal osteoporosis. A comparative study of exercise, calcium supplementation, and hormone-replacement therapy. N Engl J Med. 91;325(17):1189-9. Does not apply to the key questions. [pmid: 1922205].
Puig L, Moreno A, Llistosella E, et al. Granulation tissue proliferation during isotretinoin treatment. Int J Dermatol. 86;25(3):191-3. Does not apply to the key questions, Does not address the use of supplements. [pmid: 2939033].
Quinn GE, Johnson L, Otis C, et al. Incidence, severity and time course of ROP in a randomized clinical trial of vitamin E prophylaxis. Doc Ophthalmol. 90;74(3):223-8. Includes only infants. [pmid: 2209380].
Rahmathullah L. Effect of receiving a weekly dose of vitamin A equivalent to the recommended dietary allowances among pre school children on mortality in south India. Indian J Pediatr. 91;58(6):837-47. Only covers nutritional deficiency, Does not apply to the key questions.
Reddy GK, Tyagi P, Jain VK, et al. Highlights from 26th annual San Antonio breast cancer symposium. San Antonio, Texas December 2003. Clin Breast Cancer. 2004;5(1):22-28. Includes ONLY patients with a particular chronic disease, Does not apply to the key questions, Does not address the use of supplements.
Redlich CA, Chung JS, Cullen MR, et al. Effect of long-term beta-carotene and vitamin A on serum cholesterol and triglyceride levels among participants in the Carotene and Retinol Efficacy Trial (CARET). Atherosclerosis. 99;145(2):425-3. Does not cover the defined disease endpoints.
Redlich CA, Van Bennekum AM, Wirth JA, et al. Vitamin A chemoprevention of lung cancer. A short-term biomarker study. Adv Exp Med Biol. 95;37:517-29. Does not cover the defined disease endpoints.
Rexrode KM, Lee IM, Cook NR, et al. Baseline characteristics of participants in the Women's Health Study. J Womens Health Gend Based Med. 2000;9(1):19-27. Does not apply to the key questions. [pmid: 10718501].
Reynolds LG, Klein M. Iron poisoning - a preventable hazard of childhood. S Afr Med J. 85;67(17):680-683. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 3992389].
Richy F, Ethgen O, Bruyere O, et al. Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis a meta analysis of their effects on bone mineral density and fracture rate. Osteoporos Int. 2004;15(4):301-10. Does not apply to the key questions. [pmid: 14740153].
Richy F, Ethgen O, Bruyere O, et al. Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis: a meta-analysis of their effects on bone mineral density and fracture rate. Osteoporos Int. 2004;15(4):301-10. Does not address the use of supplements. [pmid: 14740153].
Riley SJ, Stouffer GA. Cardiology Grand Rounds from the University of North Carolina at Chapel Hill. The antioxidant vitamins and coronary heart disease: Part II. Randomized clinical trials. Am J Med Sci. 2003;325(1):15-9. Narrative review. [pmid: 12544080].
Riley SJ, Stouffer G A. The antioxidant vitamins and coronary heart disease: Part II. Randomized clinical trials. Am J Med Sci. 2003;325(1):15-19. Narrative review. [pmid: 12544080].
Roberts HJ. Lead in calcium supplements. JAMA. 2000;284(24):3126-3127. Editorial. [pmid: 11135771].
Rock CL, Newman VA, Neuhouser ML, et al. Antioxidant supplement use in cancer survivors and the general population. J Nutr. 2004;134(11):3194S-3195. Does not cover the defined disease endpoints. [pmid: 15514304].
Roe DA. Health foods and supplements for the elderly - Who can say no. NY J Med. 93;93(2):109-112. Narrative review.
Roumie CL. Effect of folic acid supplementation on inflammatory markers. J Clin Outcomes Manage. 2005;12(8):386-387. Editorial.
Rudzki E, Grzywa Z. Dermatitis from retinoic acid. Contact Dermatitis. 78;4(5):305-6. Does not apply to the key questions, Does not address the use of supplements. [pmid: 154376].
Ryan-Harshman M, Aldoori W. Health benefits of selected vitamins. Can Fam Physician. 2005;51(-):965-968. Does not cover the defined disease endpoints. [pmid: 16060174]. [pmcid: 1479519].
Anonymous. Safety and tolerability of calcipotriol in psoriasis. Br J Clin Pract Suppl 96;8326–8. Does not apply to the key questions, Does not address the use of supplements
Saldanha RL, Cepeda EE, Poland R L. The effect of vitamin E prophylaxis on the incidence and severity of bronchopulmonary dysplasia. J Pediatr. 82;101(1):89-93. Includes ONLY patients with a particular chronic disease, Includes only infiants. [pmid: 7045320].
Salonen JT, Alfthan G, Huttunen JK, et al. Association between serum selenium and the risk of cancer. Am J Epidemiol. 84;120(3):342-9. Does not address the use of supplements. [pmid: 6475911].
Salonen JT. Epidemiological studies on antioxidants, lipid peroxidation and atherosclerosis. Arch Toxicol Suppl. 98;20:249-67. Narrative review. [pmid: 9442298].
Samman S, Roberts DC. The effect of zinc supplements on plasma zinc and copper levels and the reported symptoms in healthy volunteers. Med J Aust. 87;146(5):246-9. Does not apply to the key questions. [pmid: 3547053].
Sasaki S, Tsubono Y, Okubo S, et al. Effects of three-month oral supplementation of beta-carotene and vitamin C on serum concentrations of carotenoids and vitamins in middle-aged subjects: a pilot study for a randomized controlled trial to prevent gastric cancer in high-risk Japanese population. Jpn J Cancer Res. 2000;91(5):464-7. Other. [pmid: 10835489].
Schorah CJ. Ascorbic acid metabolism and cancer in the human stomach. Acta Gastroenterol Belg. 97;60(3):217-9. Narrative review. [pmid: 9396179].
Schrauzer GN. Nutritional selenium supplements: Product types, quality, and safety. J Am Coll Nutr. 2001;20(1):1-4. Narrative review. [pmid: 11293463].
Scragg R, Khaw KT, Murphy S. Effect of winter oral vitamin D3 supplementation on cardiovascular risk factors in elderly adults. Eur J Clin Nutr. 95;49(9):640-6. Does not cover the defined disease endpoints. [pmid: 7498100].
Seddon JM, Christen WG, Manson JE, et al. The use of vitamin supplements and the risk of cataract among US male physicians. Am J Public Health. 94;84(5):788-92. Other. [pmid: 8179050].
Shannon M. Alternative medicines toxicology: a review of selected agents. J Toxicol Clin Toxicol. 99;37(6):709-13. Does not apply to the key questions. [pmid: 10584583].
Shaw D, Leon C, Kolev S, et al. Traditional remedies and food supplements. A 5-year toxicological study (1991-1995). Drug Saf. 97;17(5):342-356. Narrative review. [pmid: 9391777].
Sherertz EF. Acneiform eruption due to “megadose” vitamins B6 and B12. Cutis. 91;48(2):119-20. Does not apply to the key questions. [pmid: 1834437].
Siegel BV, Leibovitz B. The multifactorial role of vitamin C in health and disease. Int J Vitam Nutr Res Suppl. 82;23(-):9-22. Narrative review. [pmid: 6181000].
Singh RB. Can dietary magnesium supplementation decrease coronary heart disease and sudden cardiac death?. Schriftenr Ver Wasser Boden Lufthyg. 93;88:474-90. Does not address the use of supplements. [pmid: 8460387].
Siqueira LM. Adolescents and nutritional supplements: Important behavioral issues. Int Pediatr. 2005;20(1):9-10. Editorial.
Sleeper RB, Kennedy SM. Adverse reaction to a dietary supplement in an elderly patient. Ann Pharmacother. 2003;37(1):83-6. Does not apply to the key questions. [pmid: 12503940].
Smallwood J, Ah-Kye D, Taylor I. Vitamin B6 in the treatment of pre-menstrual mastalgia. Br J Clin Pract. 86;40(12):532-3. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 3307864].
Smeeding SJW. Nutrition, supplements, and aging. Geriatr Nurs. 2001;22(4):219-224. Narrative review. [pmid: 11505253].
Spittle CR. Vitamin C and deep-vein thrombosis. Lancet. 73;2(7822):199-201. Editorial. [pmid: 4124271].
Sposito AC, Caramelli B, Serrano CV et al. Effect of niacin and etofibrate association on subjects with coronary artery disease and serum high-density lipoprotein cholesterol <35 mg/dl. Am J Cardiol 99;83(1):98‐100, A8. Includes ONLY patients with a particular chronic disease, Does not apply to the key questions
Stephens NG, Parsons A, Schofield PM, et al. Randomised controlled trial of vitamin E in patients with coronary disease: Cambridge Heart Antioxidant Study (CHAOS). Lancet. 96;347(9004):781-6. Includes ONLY patients with a particular chronic disease. [pmid: 8622332].
Stals H, Vercammen C, Peeters C, et al. Acanthosis nigricans caused by nicotinic acid: case report and review of the literature. Dermatology. 94;189(2):203-6. Does not cover the defined disease endpoints. [pmid: 8075456].
Stanner SA, Hughes J, Kelly CNM, et al. A review of the epidemiological evidence for the ‘antioxidant hypothesis’. Public Health Nutr. 2004;7(3):407-422. Narrative review. [pmid: 15153272].
Steiner M. Vitamin E, a modifier of platelet function: rationale and use in cardiovascular and cerebrovascular disease. Nutr Rev. 99;57(10):306-9. Narrative review. [pmid: 10575906].
Steinkjer B. Contact dermatitis from calcipotriol. Contact Dermatitis. 94;31(2):122. Does not apply to the key questions, Does not address the use of supplements. [pmid: 7750258].
Stephensen CB, Franchi LM, Hernandez H, et al. Adverse effects of high-dose vitamin A supplements in children hospitalized with pneumonia. Pediatrics. 98;101(5):E3. Includes ONLY patients with a particular chronic disease. [pmid: 9565436].
Stevens VL, McCullough ML, Diver WR, et al. Use of multivitamins and prostate cancer mortality in a large cohort of US men. Cancer Causes Control. 2005;16(6):643-50. Other. [pmid: 16049802].
Sutton NA. The safety of calcium fortification. Med Health RI. 2000;83(11):364-366. Narrative review.
Takahashi K. A multicenter study on sleep-wake rhythm disorders in Japan a preliminary results. Jpn J Psychiatry Neurol. 92;46(1):231-2. Does not apply to the key questions. [pmid: 1635322].
Tanaka M, Niizeki H, Shimizu S, et al. Photoallergic drug eruption due to pyridoxine hydrochloride. J Dermatol. 96;23(10):708-9. Does not apply to the key questions. [pmid: 8973037].
Tanji JL, Lew EY, Wong GY, et al. Dietary calcium supplementation as a treatment for mild hypertension. J Am Board Fam Pract. 91;4(3):145-50. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 2053453].
Teegarden D, Legowski P, Gunther CW, et al. Dietary calcium intake protects women consuming oral contraceptives from spine and hip bone loss. J Clin Endocrinol Metab. 2005;90(9):5127-33. Does not address the use of supplements. [pmid: 15998785].
The alpha-tocopherol, beta-carotene lung cancer prevention study design, methods, participant characteristics, and compliance. Ann Epidemiol. 94;4(1):1-10. Other.
Touvier M, Boutron-Ruault MC, Volatier JL, et al. Efficacy and safety of regular vitamin and mineral supplement use in France: Results from the ECCA study. Int. J Vitam Nutr Res. 2005;75(3):201-209. Does not apply to the key questions. [pmid: 16028636].
Update on isotretinoin (Accutane) for acne. Med Lett Drugs Ther 83;25(649):105–6. Does not address the use of supplements
Valentic JP, Barr RJ, Weinstein GD. Inflammatory neovascular nodules associated with oral isotretinoin treatment of severe acne. Arch Dermatol. 83;119(10):871-2. Does not apply to the key questions, Does not address the use of supplements. [pmid: 6225399].
Van D, Berg H. Responding to consumer needs Risk benefit analysis of fortification. Scand J Nutr Suppl. 99;43(4):112S-116. Narrative review.
van Zandwijk N, Hirsch FR. Chemoprevention of lung cancer: current status and future prospects. Lung Cancer. 2003;42(Suppl):1S71-9. Narrative review.
Vieth R. Vitamin D supplementation, 25-hydroxyvitamin D concentrations, and safety. Am. J. Clin. Nutr. 99;69(5):842-856. Narrative review. [pmid: 10232622].
Vitamins, minerals, supplements and dietary approaches. Focus Altern. Complement. Ther. 2005;10(3):227–232. Narrative review
Waine C. Vitamin and mineral supplements. Pharm J. 2001;267(7165):352-354. Narrative review.
Ward BJ. Retinol (Vitamin A) supplements in the elderly. Drugs Aging. 96;9(1):48-59. Narrative review. [pmid: 8818585].
Weisgerber UM, Boeing H, Owen RW, et al. Effect of longterm placebo controlled calcium supplementation on sigmoidal cell proliferation in patients with sporadic adenomatous polyps. Gut. 96;38(3):396-402. Does not cover the defined disease endpoints. [pmid: 8675093].
West KP, LeClerq SC, Shrestha SR, et al. Effects of vitamin A on growth of vitamin A-deficient children field studies in Nepal. J Nutr. 97;127(10):1957-65. Only covers nutritional deficiency. [pmid: 9311951].
Whiting SJ, Wood R, Kim K. Calcium supplementation. J Am Acad Nurse Pract. 97;9(4):187-192. Narrative review. [pmid: 9274239].
Wijewardene K. Does vitamin E prevent retinopathy of prematurity in low birth weight babies. Ceylon Med J. 90;35(2):37-9. Does not apply to the key questions, Includes only infiants. [pmid: 2199084].
Willett WC, MacMahon B. Diet and cancer--an overview. N Engl J Med. 84;310(10):633-8. Narrative review. [pmid: 6363924].
Woodson K, Tangrea JA, Barrett MJ, et al. Serum alpha-tocopherol and subsequent risk of lung cancer among male smokers. J Natl Cancer Inst. 99;91(20):1738-43. Does not address the use of supplements. [pmid: 10528024].
Wright HO. Vitamin A supplementation. J Appl Nutr. 95;47(12):32-33. Editorial.
Yamori Y, Mizushima S. A review of the link between dietary magnesium and cardiovascular risk. J Cardiovasc Risk. 2000;7(1):31-5. Narrative review. [pmid: 10785871].
Yu SY, Li WG, Zhu YJ, et al. Chemoprevention trial of human hepatitis with selenium supplementation in China. Biol Trace Elem Res. 89;20(12):15-22. Does not apply to the key questions, Does not address the use of supplements. [pmid: 2484394].
Yu SY, Mao BL, Xiao P, et al. Intervention trial with selenium for the prevention of lung cancer among tin miners in Yunnan, China. A pilot study. Biol Trace Elem Res. 90;24(2):105-8. Does not address the use of supplements. [pmid: 1702663].
Yu SY, Zhu YJ, Li WG, et al. A preliminary report on the intervention trials of primary liver cancer in high-risk populations with nutritional supplementation of selenium in China. Biol Trace Elem Res. 91;29(3):289-94. Does not apply to the key questions.
Yusuf S, Dagenais G, Pogue J, et al. Vitamin E supplementation and cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. 2000;342(3):154-60. Does not apply to the key questions. [pmid: 10639540].
Zhang YH, Kramer TR, Taylor PR, et al. Possible immunologic involvement of antioxidants in cancer prevention. Am J Clin Nutr. 95;62(6 Suppl):1477S-1482S. Does not apply to the key questions, Does not cover the defined disease endpoints. [pmid: 7495248].
Zhao XQ, Morse JS, Dowdy AA, et al. Safety and tolerability of simvastatin plus niacin in patients with coronary artery disease and low high-density lipoprotein cholesterol (The HDL Atherosclerosis Treatment Study). Am J Cardiol. 2004;93(3):307-12. Includes ONLY patients with a particular chronic disease, Does not apply to the key questions, Does not address the use of supplements, Does not cover the defined disease endpoints. [pmid: 14759379].