# Appendix C: Detailed Electronic Database Search Strategies

## MEDLINE Strategy

((((“Calcium, dietary”[mh] OR “dietary Calcium”[tiab] OR “Calcium supplement*”[tiab] OR “folic acid”[tiab] OR “folic acid”[mh] OR folate[tiab] OR “folate supplement*”[tiab] OR “Vitamin B 6”[tiab] OR “Vitamin B6”[tiab] OR Pyridoxine[tiab] OR “Vitamin B 6”[mh] OR “Vitamin B 12”[tiab] OR “Vitamin B12”[tiab] OR “Vitamin B 12”[mh] OR “Vitamin D”[tiab] OR Cholecalciferol[tiab] OR “Vitamin D”[mh] OR “Vitamin E”[tiab] OR Tocopherol[tiab] OR “Vitamin E”[mh] OR “Vitamin C”[tiab] OR “Ascorbic acid”[tiab] OR ascorbate[tiab] OR “Ascorbic acid”[mh] OR “Vitamin A”[tiab] OR “Vitamin A”[mh] OR “beta carotene”[tiab] OR “beta carotene”[mh] OR (iron[tiab] AND (“dietary supplement*”[tiab] OR supplement*[tiab])) OR “iron, dietary”[mh] OR (zinc[tiab] AND (“dietary supplement*”[tiab] OR supplement*[tiab])) OR (Magnesium[tiab] AND (“dietary supplement*”[tiab] OR supplement*[tiab])) OR “Vitamin B 1”[tiab] OR “Vitamin B1”[tiab] OR Thiamin[tiab] OR Thiamine[tiab] OR Thiamine[mh] OR “Vitamin B 2”[tiab] OR “Vitamin B2”[tiab] OR Riboflavin[tiab] OR Riboflavin[mh] OR Niacin[tiab] OR “Nicotinic acids”[tiab] OR “nicotinic acid”[tiab] OR “Nicotinic acids”[mh] OR Selenium[tiab] OR Selenium [mh] OR Multivitamin*[tiab] OR Vitamin*[tiab] OR Vitamins[mh] OR Mineral*[tiab] OR Minerals[mh] OR “Vitamin Supplement*”[tiab] OR “Mineral Supplement*”[tiab] OR “multivitamin supplement*”[tiab] OR “multimineral supplement*”[tiab]) AND (Neoplasms[mh] OR neoplasm*[tiab] OR “Cardiovascular diseases”[mh] OR “cardiovascular disease*”[tiab] OR “Endocrine system diseases”[mh] OR “Endocrine system diseases”[tiab] OR “Nervous system diseases”[mh] OR “Nervous system disease*”[tiab] OR “eye diseases”[mh] OR “eye disease*”[tiab] OR “hearing loss”[mh] OR “hearing loss”[tiab] OR “Musculoskeletal diseases”[mh] OR “Musculoskeletal disease*”[tiab] OR “digestive system diseases”[mh] OR “digestive system disease*”[tiab] OR “Kidney diseases”[mh] OR “Kidney disease*”[tiab] OR “Communicable diseases”[mh] OR “Communicable diseases”[tiab] OR “infectious disease”[tiab] OR “Lung diseases”[mh] OR “Lung disease*”[tiab] OR “Lung neoplasms”[tiab] OR “breast cancer”[tiab] OR “Breast neoplasms”[tiab] OR “colorectal cancer”[tiab] OR “Colorectal neoplasms”[tiab] OR “lung cancer”[tiab] OR “prostate cancer”[tiab] OR “Prostatic neoplasms”[tiab] OR “gastric cancer”[tiab] OR “stomach cancer”[tiab] OR “Stomach neoplasms”[tiab] OR “Abdominal neoplasms”[tiab] OR “colorectal polyps”[tiab] OR “Colon polyps”[tiab] OR adenomas[tiab] OR Polyps[tiab] OR “myocardial infarction”[tiab] OR “Heart arrest”[tiab] OR “myocardial ischemia”[tiab] OR “Coronary artery disease”[tiab] OR “heart attack”[tiab] OR “Ischemic heart disease”[tiab] OR stroke[tiab] OR “cerebrovascular accident”[tiab] OR “Cerebrovascular disease”[tiab] OR “type 2 diabetes”[tiab] OR “Diabetes mellitus”[tiab] OR “adult onset diabetes”[tiab] OR “Alzheimer's disease”[tiab] OR “Parkinson disease”[tiab] OR dementia[tiab] OR “Alzheimer's disease”[tiab] OR “Alzheimer disease”[tiab] OR cataract[tiab] OR cataracts[tiab] OR “macular degeneration”[tiab] OR deafness[tiab] OR osteoporosis[tiab] OR Fractures[tiab] OR “rheumatoid arthritis”[tiab] OR osteoarthritis[tiab] OR “Degenerative joint disease”[tiab] OR osteopenia[tiab] OR “Metabolic bone diseases”[tiab] OR “steatohepatitis”[tiab] OR NASH[tiab] OR “fatty-liver disease”[tiab] OR NAFLD[tiab] OR “renal insufficiency”[tiab] OR “Chronic kidney failure”[tiab] OR “nephrolithiasis”[tiab] OR Nephropathy[tiab] OR “HIV infection”[tiab] OR AIDS[tiab] OR “acquired immunodeficiency syndrome”[tiab] OR “hepatitis C”[tiab] OR tuberculosis[tiab] OR “chronic obstructive pulmonary disease”[tiab] OR Emphysema[tiab] OR “Chronic bronchitis”[tiab])) AND (“Randomized controlled trial”[pt] OR “controlled clinical trial”[pt] OR “Randomized controlled trials”[mh] OR “Random allocation”[mh] OR “double-blind method”[mh] OR “single-blind method”[mh])) OR ((“Calcium, dietary”[mh] OR “dietary Calcium”[tiab] OR “Calcium supplement*”[tiab] OR “folic acid”[tiab] OR “folic acid”[mh] OR folate[tiab] OR “folate supplement*”[tiab] OR “Vitamin B 6”[tiab] OR “Vitamin B6”[tiab] OR Pyridoxine[tiab] OR “Vitamin B 6”[mh] OR “Vitamin B 12”[tiab] OR “Vitamin B12”[tiab] OR “Vitamin B 12”[mh] OR “Vitamin D”[tiab] OR Cholecalciferol[tiab] OR “Vitamin D”[mh] OR “Vitamin E”[tiab] OR Tocopherol[tiab] OR “Vitamin E”[mh] OR “Vitamin C”[tiab] OR “Ascorbic acid”[tiab] OR “Ascorbic acid”[mh] OR “Vitamin A”[tiab] OR “Vitamin A”[mh] OR “beta carotene”[tiab] OR “beta carotene”[mh] OR “dietary iron”[tiab] OR “iron supplement*”[tiab] OR “iron, dietary”[mh] OR “dietary zinc”[tiab] OR “zinc supplement*”[tiab] OR “dietary Magnesium”[tiab] OR “Magnesium supplement*”[tiab] OR “Vitamin B 1”[tiab] OR “Vitamin B1”[tiab] OR Thiamin[tiab] OR Thiamine[tiab] OR Thiamine[mh] OR “Vitamin B 2”[tiab] OR “Vitamin B2”[tiab] OR Riboflavin[tiab] OR Riboflavin[mh] OR Niacin[tiab] OR “Nicotinic acids”[tiab] OR “nicotinic acid”[tiab] OR “Nicotinic acids”[mh] OR Multivitamin*[tiab] OR Vitamin*[tiab] OR Vitamins[mh] OR Mineral*[tiab] OR Minerals[mh] OR “Vitamin Supplement*”[tiab] OR “Mineral Supplement*”[tiab] OR “multivitamin supplement*”[tiab] OR “multimineral supplement*”[tiab] OR Selenium[tiab] OR “dietary selenium”[tiab] OR Selenium[mh]) AND (safety[mh] OR safety[tiab] OR “adverse event*”[tiab] OR “pharmacology”[mh] OR “adverse effects”[subheading] OR “adverse effect*”[tiab] OR “side effect*”[tiab] OR “product surveillance, postmarketing”[mh] “Adverse reaction*”[tiab] OR “drug toxicity”[mh] OR “drug toxicity”[tiab]))) AND (English[lang] NOT (animal[mh] NOT human[mh])) | 7880

## Cochrane Library (Reviews and CENTRAL) Strategy

(((TX dietary AND (TX Calcium OR TX “folic acid” OR TX folate OR TX “vitamin B6” OR TX vitamin B 6" TX OR pyridoxine OR TX “vitamin B12” OR TX “vitamin B 12” OR TX “Vitamin D” OR TX cholecalciferol OR TX “Vitamin E” OR TX tocopherol OR TX “Vitamin E” OR TX “Vitamin C” OR TX “Ascorbic Acid” OR TX ascorbate OR TX “Vitamin A” OR TX “beta carotene” OR TX Iron OR TX zinc OR TX magnesium OR TX “Vitamin B1” OR TX “Vitamin B 1” OR TX “Vitamin B1” OR TX “Vitamin B 2” Or TX Thiamine OR TX Thiamin OR TX Riboflavin OR TX Niacin OR TX “nicotinic acid” OR TX multivitamin OR TX Multimineral OR TX selenium)) OR ((TX Calcium OR TX “folic acid” OR TX folate OR TX “vitamin B6” OR TX vitamin B 6" TX OR pyridoxine OR TX “vitamin B12” OR TX “vitamin B 12” OR TX “Vitamin D” OR TX cholecalciferol OR TX “Vitamin E” OR TX tocopherol OR TX “Vitamin E” OR TX “Vitamin C” OR TX “Ascorbic Acid” OR TX ascorbate OR TX “Vitamin A” OR TX “beta carotene” OR TX Iron OR TX zinc OR TX magnesium OR TX “Vitamin B1” OR TX “Vitamin B 1” OR TX “Vitamin B1” OR TX “Vitamin B 2” Or TX Thiamine OR TX Thiamin OR TX Riboflavin OR TX Niacin OR TX “nicotinic acid” OR TX multivitamin OR TX Multimineral OR TX selenium) AND TX supplement)) AND ((TX Neoplasm OR TX “Cardiovascular disease” OR TX “Endocrine system disease” OR TX “Nervous system disease” OR TX “eye disease” OR TX “hearing loss” OR TX “Musculoskeletal disease” OR TX “digestive system disease” OR TX “Kidney disease” OR TX “Communicable disease” OR TX “infectious disease” OR TX “Lung diseases” OR TX “Lung neoplasms” OR TX “breast cancer” OR TX “Breast neoplasms” OR TX “colorectal cancer” OR TX “Colorectal neoplasms” OR TX “lung cancer” OR TX “prostate cancer” OR TX “Prostatic neoplasms” OR TX “gastric cancer” OR TX “stomach cancer” OR TX “Stomach neoplasms” OR TX “Abdominal neoplasms” OR TX “colorectal polyps” OR TX “Colon polyps” OR TX adenomas OR TX Polyps OR TX “myocardial infarction” OR TX “Heart arrest” OR TX “myocardial ischemia”) OR (TX “Coronary artery disease” OR TX “heart attack” OR TX “Ischemic heart disease” OR TX stroke OR TX “cerebrovascular accident” OR TX “Cerebrovascular disease” OR TX “type 2 diabetes” OR TX “Diabetes mellitus” OR TX “adult onset diabetes” OR TX “Alzheimer's disease” OR TX “Parkinson disease” OR TX dementia OR TX cataract OR TX “macular degeneration” OR TX deafness OR TX osteoporosis OR TX Fractures OR TX “rheumatoid arthritis” OR TX osteoarthritis OR TX “Degenerative joint disease” OR TX osteopenia OR TX “Metabolic bone diseases” OR TX “steatohepatitis” OR TX “fatty-liver disease” OR TX “renal insufficiency” OR TX “Chronic kidney failure” OR TX “nephrolithiasis” OR TX Nephropathy OR TX “HIV infection” OR TX AIDS OR TX “acquired immunodeficiency syndrome” OR TX “hepatitis C” OR TX tuberculosis OR TX “chronic obstructive pulmonary disease” OR TX Emphysema OR TX “Chronic bronchitis”)) OR (((TX dietary AND (TX Calcium OR TX “folic acid” OR TX folate OR TX “vitamin B6” OR TX vitamin B 6" TX OR pyridoxine OR TX “vitamin B12” OR TX “vitamin B 12” OR TX “Vitamin D” OR TX cholecalciferol OR TX “Vitamin E” OR TX tocopherol OR TX “Vitamin E” OR TX “Vitamin C” OR TX “Ascorbic Acid” OR TX ascorbate OR TX “Vitamin A” OR TX “beta carotene” OR TX Iron OR TX zinc OR TX magnesium OR TX “Vitamin B1” OR TX “Vitamin B 1” OR TX “Vitamin B1” OR TX “Vitamin B 2” Or TX Thiamine OR TX Thiamin OR TX Riboflavin OR TX Niacin OR TX “nicotinic acid” OR TX multivitamin OR TX Multimineral OR TX selenium)) OR ((TX Calcium OR TX “folic acid” OR TX folate OR TX “vitamin B6” OR TX vitamin B 6" TX OR pyridoxine OR TX “vitamin B12” OR TX “vitamin B 12” OR TX “Vitamin D” OR TX cholecalciferol OR TX “Vitamin E” OR TX tocopherol OR TX “Vitamin E” OR TX “Vitamin C” OR TX “Ascorbic Acid” OR TX ascorbate OR TX “Vitamin A” OR TX “beta carotene” OR TX Iron OR TX zinc OR TX magnesium OR TX “Vitamin B1” OR TX “Vitamin B 1” OR TX “Vitamin B1” OR TX “Vitamin B 2” Or TX Thiamine OR TX Thiamin OR TX Riboflavin OR TX Niacin OR TX “nicotinic acid” OR TX multivitamin OR TX Multimineral OR TX selenium) AND TX supplement)) AND (TX safety OR TX “adverse event” OR TX “pharmacology” OR TX “adverse effects” OR TX “adverse effect” OR TX “side effect” OR (TX postmarketing W1 “product surveillance”) OR TX “Adverse reaction” OR TX “drug toxicity” OR TX “drug toxicity”))) | 15

## EMBASE Strategy

((((((‘calcium’/exp/mj OR ‘calcium’) OR (‘folic acid’/exp/mj OR ‘folic acid’) OR (‘folate’/exp/mj OR ‘folate’) OR (‘vitamin b6’/exp/mj OR ‘vitamin b6’) OR (‘vitamin b 6’/exp/mj OR ‘vitamin b 6’) OR (‘pyridoxine’/exp/mj OR ‘pyridoxine’) OR (‘vitamin b12’/exp/mj OR ‘vitamin b12’) OR (‘vitamin b 12’/exp/mj OR ‘vitamin b 12’) OR (‘vitamin d’/exp/mj OR ‘vitamin d’) OR (‘cholecalciferol’/exp/mj OR ‘cholecalciferol’) OR (‘vitamin e’/exp/mj OR ‘vitamin e’) OR (‘tocopherol’/exp/mj OR ‘tocopherol’) OR (‘vitamin c’/exp/mj OR ‘vitamin c’) OR acorbate OR (‘ascorbic acid’/exp/mj OR ‘ascorbic acid’) OR (‘vitamin a’/exp/mj OR ‘vitamin a’) OR (‘beta carotene’/exp/mj OR ‘beta carotene’) OR ((‘vitamin b1’/exp/mj OR ‘vitamin b1’) OR (‘vitamin b 1’/exp/mj OR ‘vitamin b 1’) OR (‘thiamin’/exp/mj OR ‘thiamin’) OR (‘thiamine’/exp/mj OR ‘thiamine’) OR (‘vitamin b2’/exp/mj OR ‘vitamin b2’) OR (‘vitamin b 2’/exp/mj OR ‘vitamin b 2’) OR (‘riboflavin’/exp/mj OR ‘riboflavin’) OR (‘niacin’/exp/mj OR ‘niacin’) OR (‘nicotinic acid’/exp/mj OR ‘nicotinic acid’) OR (‘multivitamin’/exp/mj OR ‘multivitamin’) OR (‘vitamin’/exp/mj OR ‘vitamin’) OR vitmins OR (‘mineral’/exp/mj OR ‘mineral’) OR minerals OR multiminerals AND [english]/lim AND [humans]/lim) OR (((‘iron’/exp/mj OR ‘iron’) OR (‘zinc’/exp/mj OR ‘zinc’) OR (‘magnesium’/exp/mj OR ‘magnesium’)) AND (supplement OR (‘dietary supplement’/exp/mj OR ‘dietary supplement’)) AND [english]/lim AND [humans]/lim)) AND ((neoplasm or ‘hearing loss’ or ‘colorectal polyps’ or ‘colon polyps’ or adenoma or polyp or ‘myocardial infarction’ or ‘heart arrest’ or ‘myocardial ischemia’ or ‘heart attack’ or stroke or ‘cerebrovacular accident’ or ‘t ype 2 diabetes’ or ‘diabetes mellitus’ or ‘adult onset diabetes’ or dementia or cataract or cataracts or ‘macular degeneration’ or deafness or osteoporosis or osteoarthritis or osteopenia or fracture or ‘rheumatoid arthritis’ or ‘rheumatiod arthritis’ or steatohepatits or nash or nafld or ‘renal insufficiency’ or ‘chronic kidney failure’ or nephrolithiasis or nephropathy or ‘hiv infection’ or aids or ‘acquired immunodeficiency syndrome’ or ‘hepatitis c’ or tuberculosis or ‘chronic obstructive pulmonary disease’ or emphysema or ‘chronic bronchitis’)or AND ((cardiovascular OR ‘endocrin system’ OR (‘nervous system’/exp/mj OR ‘nervous system’) OR (‘eye’/exp/mj OR ‘eye’) OR musculoskeletal OR (‘digestive system’/exp/mj OR ‘digestive system’) OR (‘kidney’/exp/mj OR ‘kidney’) OR communicable OR infectious OR (‘lung’/exp/mj OR ‘lung’) OR (‘coronary artery’/exp/mj OR ‘coronary artery’) OR (‘ischemic heart’/exp/mj OR ‘ischemic heart’) OR cerebrovascular OR alzheimer's or parkinson's OR ‘degenerative joint’ OR ‘metabolic bone’ OR (‘fatty liver’/exp/mj OR ‘fatty liver’)) AND (‘disease’/exp/mj OR ‘disease’)) OR (((‘lung’/exp/mj OR ‘lung’) OR (‘breast’/exp/mj OR ‘breast’) OR (‘colon’/exp/mj OR ‘colon’) OR colorectal OR (‘prostate’/exp/mj OR ‘prostate’) OR gastric OR (‘stomach’/exp/mj OR ‘stomach’) OR abdominal) AND ((‘cancer’/exp/mj OR ‘cancer’) OR (‘neoplasm’/exp/mj OR ‘neoplasm’))) AND [english]/lim AND [humans]/lim)) AND (‘randomized controlled trial’:it OR ‘controlled clinical trial’:it AND [english]/lim AND [humans]/lim)) OR (((((‘calcium’/exp/mj OR ‘calcium’) OR (‘folic acid’/exp/mj OR ‘folic acid’) OR (‘folate’/exp/mj OR ‘folate’) OR (‘vitamin b6’/exp/mj OR ‘vitamin b6’) OR (‘vitamin b 6’/exp/mj OR ‘vitamin b 6’) OR (‘pyridoxine’/exp/mj OR ‘pyridoxine’) OR (‘vitamin b12’/exp/mj OR ‘vitamin b12’) OR (‘vitamin b 12’/exp/mj OR ‘vitamin b 12’) OR (‘vitamin d’/exp/mj OR ‘vitamin d’) OR (‘cholecalciferol’/exp/mj OR ‘cholecalciferol’) OR (‘vitamin e’/exp/mj OR ‘vitamin e’) OR (‘tocopherol’/exp/mj OR ‘tocopherol’) OR (‘vitamin c’/exp/mj OR ‘vitamin c’) OR acorbate OR (‘ascorbic acid’/exp/mj OR ‘ascorbic acid’) OR (‘vitamin a’/exp/mj OR ‘vitamin a’) OR (‘beta carotene’/exp/mj OR ‘beta carotene’) OR (‘vitamin b1’/exp/mj OR ‘vitamin b1’) OR (‘vitamin b 1’/exp/mj OR ‘vitamin b 1’) OR (‘thiamin’/exp/mj OR ‘thiamin’) OR (‘thiamine’/exp/mj OR ‘thiamine’) OR (‘vitamin b2’/exp/mj OR ‘vitamin b2’) OR (‘vitamin b 2’/exp/mj OR ‘vitamin b 2’) OR (‘riboflavin’/exp/mj OR ‘riboflavin’) OR (‘niacin’/exp/mj OR ‘niacin’) OR (‘nicotinic acid’/exp/mj OR ‘nicotinic acid’) OR (‘multivitamin’/exp/mj OR ‘multivitamin’) OR (‘vitamin’/exp/mj OR ‘vitamin’) OR vitmins OR (‘mineral’/exp/mj OR ‘mineral’) OR minerals OR multiminerals) OR ((‘iron’/exp/mj OR ‘iron’) OR (‘zinc’/exp/mj OR ‘zinc’) OR (‘magnesium’/exp/mj OR ‘magnesium’) OR (‘selenium’/exp/mj OR ‘selenium’)) AND (supplement OR (‘dietary supplement’/exp/mj OR ‘dietary supplement’))) AND [english]/lim AND [humans]/lim) AND ((‘safety’/exp/mj OR ‘safety’) OR ‘adverse event’ OR (‘pharmacology’/exp/mj OR ‘pharmacology’) OR ‘adverse effects’ OR (‘adverse effect’/exp/mj OR ‘adverse effect’) OR (‘side effect’/exp/mj OR ‘side effect’) OR ‘product surveillance’ OR (‘adverse reaction’/exp/mj OR ‘adverse reaction’) OR (‘drug toxicity’/exp/mj OR ‘drug toxicity’) AND [english]/lim AND [humans]/lim))) | 3350