# Appendixes B: Hand Searched Journals

All Journals Hand Searched January 2005 through February 2006

Annals of Epidemiology

Annals of Internal Medicine

Annals of the New York Academy of Science

Archives of Ophthalmology

Cancer Causes and Control

Cancer Research

Cancer Research

Controlled Clinical Trials

International Journal for Vitamin and Nutrition Research

Journal of Bone and Mineral Metabolism

Journal of the American Medical Association

Journal of the National Cancer Institute

Lancet

Osteoporosis International

The Journal of Nutrition