# Appendix A: Technical Experts and Peer Reviewers

## Technical Experts and Peer Reviewers

- Lindsay Allen, RD, PhD
- USDA - Agricultural Research Center
- Western Human Nutrition Research Center and Program in International Nutrition
- 1 Shields Avenue, SurgeE IV
- Davis, CA

- Bruce Ames, PhD
- Children's Hospital Oakland Research Institute (CHORI)
- 5700 Martin Luther King Jr. Way
- Oakland, CA

- John Beard, PhD
- Department of Nutritional Sciences,
- Penn State University
- S-128A Henderson South Bldg.
- University Park,PA

- John W. Erdman, Jr.
- Professor
- University of Illinois
- Division of Nutritional Sciences
- Urbana, IL

- Gary Goodman, MD, MS
- Fred Hutchinson Cancer Research Center
- Seattle, WA

- Alice Lichtenstein, DSc
- Senior Scientist
- Director of the Cardiovascular Nutrition Laboratory, Jean Mayer USDA Human Nutrition Research Center on Aging
- Professor of Family Medicine and Community Health
- Tufts University School of Medicine
- Boston, MA

- Joel A. Simon, MD, MPH
- General Internal Medicine Section (111A1)
- San Francisco Veterans Affairs Medical Center and University of California
- 4150 Clement Street
- San Francisco, CA

- Emily White, PhD
- Cancer Prevention Research Program
- Fred Hutchinson Cancer Research Center
- Seattle, WA

## Internal Technical Experts

- Leon Gordis, MD, DPH
- Professor
- Bloomberg School of Public Health
- Department of Epidemiology
- Baltimore, MD

- Alfred Sommer, MD
- Bloomberg School of Public Health
- Dean- Finance & Admin
- Baltimore, MD