# Appendixes

Appendix A: Technical Experts and Peer Reviewers

Appendixes B: Hand Searched Journals

Appendix C: Detailed Electronic Database Search Strategies

Appendix D: Excluded Articles

Appendix E: Example Review Forms

Appendix F: Evidence Tables

Appendix G: List of Acronyms