# Acronyms and Abbreviations

5-FU | 5-Fluorouracil
AAAHC | Accreditation Association for Ambulatory Health Care
ACS | American Cancer Society
ACS-COC | American College of Surgery Commission on Cancer
ADASP | Association of Directors of Anatomic and Surgical Pathology
AGA | American Gastroenterological Association
AHRQ | Agency for Healthcare Research and Quality
AJCC | American Joint Committee on Cancer
APR | Abdominal perineal resection
ASCO | American Society of Clinical Oncology
ASCRS | American Society of Colon and Rectal Surgeons
ASGE | American Society for Gastrointestinal Endoscopy
BE | Barium enema
CAP | College of American Pathologists
CDC | Centers for Disease Control and Prevention
CEA | Carcinoembryonic antigen
CMS | Centers for Medicare & Medicaid Services
CORI | Clinical Outcomes Research Initiative
CPT | Current Procedural Terminology
CRC | Colorectal cancer
CT | Computed tomography/tomographic
DCBE | Double contrast barium enema
EUS | Endoscopic ultrasound
FFS | Fee-for-service
FOBT | Fecal occult blood test
Gy | Gray
HCUP | Hospital Cost and Utilization Project
HMO | Health maintenance organization
HSCRC | Health Services Cost Review Commission
IOM | Institute of Medicine
MeV | Million electron volts
MRI | Magnetic resonance imaging
NCCS | North Carolina Cancer Study
NCDB | National Cancer Data Base
NCCN | National Comprehensive Cancer Network
NCI | National Cancer Institute
NCPB | National Cancer Policy Board
NCQA | National Committee for Quality Assurance
NIH | National Institutes of Health
NIS | Nationwide Inpatient Sample
NQF | National Quality Forum
NQMC | National Quality Measures Clearinghouse
PCS | Patterns of Care Study
RTOG | Radiation Therapy Oncology Group
SEER | Surveillance, Epidemiology, and End Results
SLN | Sentinel lymph node
TME | Total mesorectal excision
TNM | Tumor, Node, Metastasis Staging System
UICC | International Union Against Cancer
VA | Veterans Administration