# Listing of Included Studies (alphabetical)

Agarwal N, Leighton L, Mandile MA, et al. Outcomes of surgery for colorectal cancer in patients age 80 years and older. Am J Gastroenterol. 1990;85(9):1096-101. [pmid: 2389721].
Ayanian JZ, Zaslavsky AM, Fuchs CS, et al. Use of adjuvant chemotherapy and radiation therapy for colorectal cancer in a population-based cohort. J Clin Oncol. 2003;21(7):1293-300. [pmid: 12663717].
Baig N, Myers RE, Turner BJ, et al. Physician-reported reasons for limited follow-up of patients with a positive fecal occult blood test screening result. Am J Gastroenterol. 2003;98(9):2078-81. [pmid: 14499791].
Baxter N, Virnig D, Rothenberger D, et al. Lymph Node Evaluation in Colorectal Cancer Patients: A Population Based Study. J Natl Cancer Inst. 2005;97(3):219-25. [pmid: 15687365].
Baxter NN, Rothenberger DA, Morris AM, et al. Adjuvant radiation for rectal cancer: do we measure up to the standard of care? An epidemiologic analysis of trends over 25 years in the United States. Dis Colon Rectum. 2005;48(1):9-15. [pmid: 15690651].
Beart RW, Steele GD Jr, Menck HR, et al. Management and survival of patients with adenocarcinoma of the colon and rectum: a national survey of the Commission on Cancer. J Am Coll Surg. 1995;181(3):225-36. [pmid: 7670682].
Chiaverini L, Fulton JP, Darcy DM. Progress in the control of colorectal cancer in Rhode Island, 1987-2000. Med Health R I. 2002;85(7):226-8. [pmid: 12182097].
Coburn MC, Pricolo VE, Soderberg CH. Factors affecting prognosis and management of carcinoma of the colon and rectum in patients more than eighty years of age. J Am Coll Surg. 1994;179(1):65-9. [pmid: 8019727].
Coia L, Wizenberg M, Hanlon A, et al. Evaluation and treatment of patients receiving radiation for cancer of the rectum or sigmoid colon in the United States: results of the 1988-1989 Patterns of Care Study process survey. J Clin Oncol. 1994;12(5):954-9. [pmid: 8164047].
Colon Cancer Workgroup. Quality of Cancer Care Evaluation and Improvement: Commission on Cancer, American College of Surgeons, American Cancer Society and Tenet Health Care System, December, 2003. Electronically received February 7, 2005.
Cooper GS, Yuan Z, Chak A, et al. Geographic and patient variation among Medicare beneficiaries in the use of follow-up testing after surgery for nonmetastatic colorectal carcinoma. Cancer. 1999;85(10):2124-31. [pmid: 10326689].
Cooper GS, Yuan Z, Chak A, et al. Patterns of endoscopic follow-up after surgery for nonmetastatic colorectal cancer. Gastrointest Endosc. 2000;52(1):33-8. [pmid: 10882959].
Cooper GS, Yuan Z, Landefeld CS, et al. Surgery for colorectal cancer: Race-related differences in rates and survival among Medicare beneficiaries. Am J Public Health. 1996;86(4):582-6. [pmid: 8604797]. [pmcid: 1380567].
Demissie K, Oluwole OO, Balasubramanian BA, et al. Racial differences in the treatment of colorectal cancer: a comparison of surgical and radiation therapy between Whites and Blacks. Ann Epidemiol. 2004;14(3):215-21. [pmid: 15036226].
Dimick JB, Cowan JA Jr, Upchurch GR Jr, et al. Hospital volume and surgical outcomes for elderly patients with colorectal cancer in the United States. J Surg Res. 2003;114(1):50-6. [pmid: 13678698].
Dominitz JA, Samsa GP, Landsman P, et al. Race, treatment, and survival among colorectal carcinoma patients in an equal-access medical system. Cancer. 1998;82(12):2312-20. [pmid: 9635522].
Galvis CO, Raab SS, D'Amico F, et al. Pathologists' assistants practice: a measurement of performance. Am J Clin Pathol. 2001;116(6):816-22. [pmid: 11764069].
Govindarajan R, Shah RV, Erkman LG, et al. Racial differences in the outcome of patients with colorectal carcinoma. Cancer. 2003;97(2):493-8. [pmid: 12518374].
Harewood GC, Sharma VK, de Garmo P. Impact of colonoscopy preparation quality on detection of suspected colonic neoplasia. Gastrointest Endosc. 2003;58(1):76-9. [pmid: 12838225].
Harmon J, Tang D, Gordon T, et al. Hospital Volume Can Serve as a Surrogate for Surgeon Volume for Achieving Excellent Outcomes in Colorectal Resection. Ann Surg. 1999;230(3):404-13. [pmid: 10493487]. [pmcid: 1420885].
Haseman JH, Lemmel GT, Rahmani EY, et al. Failure of colonoscopy to detect colorectal cancer: evaluation of 47 cases in 20 hospitals. Gastrointest Endosc. 1997;45(6):451-5. [pmid: 9199899].
Hodgson DC, Zhang W, Zaslavsky AM, et al. Relation of hospital volume to colostomy rates and survival for patients with rectal cancer. J Natl Cancer Inst. 2003;95(10):708-16. [pmid: 12759388].
Hyman N, Labow SB. Vermont Chapter of the American College of Surgeons. The Vermont colorectal cancer project: self-portrait. Arch Surg. 2002;137(4):413-6. [pmid: 11926944].
Institute of Medicine. Asessing the Quality of Cancer Care: An Approach to Measurement in Georgia. Committee on Assessing Improvements in Cancer Care in Georgia. National Cancer Policy Board. The National Academies Press: Washington, DC; 2005.
Jessup JM, McGinnis LS, Steele GD Jr, et al. The National Cancer Data Base. Report on colon cancer. Cancer. 1996;78(4):918-26.
Keating N, Landrum M, Meara E, et al. Do Increases in the Market Share of Managed Care Influence Quality of Care in the Fee-For-Service Sector. J Natl Cancer Inst. 2005;97(4):257-64. [pmid: 15713960].
Kline RW, Smith AR, Coia LR, et al. Treatment planning for adenocarcinoma of the rectum and sigmoid: a patterns of care study. PCS Committee. Int J Radiat Oncol Biol Phys. 1997;37(2):305-11. [pmid: 9069301].
Ko CY, Chang JT, Chaudhry S, et al. Are high-volume surgeons and hospitals the most important predictors of in-hospital outcome for colon cancer resection?. Surgery. 2002;132(2):268-73. [pmid: 12219022].
LaFata EJ, Johnson C, Ben-Menachem T, et al. Sociodemographic differences in the receipt of colorectal cancer surveillance care following treatment with curative intent. Med Care. 2001;39(4):361-72. [pmid: 11329523].
Levin B, Hess K, Johnson C. Screening for colorectal cancer. A comparison of 3 fecal occult blood tests. Arch Intern Med. 1997;157(9):970-6. [pmid: 9140267].
Mahoney T, Kuo YH, Topilow A, et al. Stage III colon cancers: why adjuvant chemotherapy is not offered to elderly patients. Arch Surg. 2000;135(2):182-5. [pmid: 10668878].
Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343(22):1603-7. [pmid: 11096167].
Marble K, Banerjee S, Greenwald L. Colorectal carcinoma in young patients. J Surg Oncol. 1992;51(3):179-82. [pmid: 1434643].
Merrill RM, Brown ML, Potosky AL, et al. Survival and treatment for colorectal cancer Medicare patients in two group/staff health maintenance organizations and the fee-for-service setting. Med Care Res Rev. 1999;56(2):177-96. [pmid: 10373723].
Minnesota Gastroenterology PA. 2004 Colonoscopy Quality Assurance Initiative. Electronically received: January 26, 2005.
Minsky BD, Coia L, Haller DG, et al. Radiation therapy for rectosigmoid and rectal cancer: results of the 1992-1994 Patterns of Care process survey. J Clin Oncol. 1998;16(7):2542-7. [pmid: 9667276].
Morris AM, Billingsley KG, Baxter NN, et al. Racial disparities in rectal cancer treatment: a population-based analysis. Arch Surg. 2004;139(2):151-5. discussion 156. [pmid: 14769572].
Myers RE, Turner B, Weinberg D, et al. Impact of a physician-oriented intervention on follow-up in colorectal cancer screening. Prev Med. 2004;38(4):375-81. [pmid: 15020170].
National Committee for Quality Assurance (NCQA). Final List of Colon Cancer Measures Based on Domain Expert Review. Measures developed by Kaiser Permanente, Internountain Health Care and NCQA. Electronically delivered February 8, 2005.
National Quality Measures Clearinghouse (NQMC). Intra-procedure colonosopy complication rate: percentage of patients who developed one or more intrao-procedure complications. Available at: http://www.qualitymeasures.ahrq.gov/summary/summary.aspx?doc_id=4868. Accessed: March 21, 2005.
Nelson DB, McQuaid KR, Bond JH, et al. Procedural success and complications of large-scale screening colonoscopy. Gastrointest Endosc. 2002;55(3):307-14. [pmid: 11868001].
Neugut AI, Fleischauer AT, Sundararajan V, et al. Use of adjuvant chemotherapy and radiation therapy for rectal cancer among the elderly: a population-based study. J Clin Oncol. 2002;20(11):2643-50. [pmid: 12039925].
Newcomb PA, Carbone PP. Cancer treatment and age: patient perspectives. J Natl Cancer Inst. 1993;85(19):1580-4. [pmid: 8411231].
O'Connell JB, Maggard MA, Liu JH, et al. Are survival rates different for young and older patients with rectal cancer. Dis Colon Rectum. 2004;47(12):2064-9. [pmid: 15657655].
O'Connell JB, Maggard MA, Liu JH, et al. Do young colon cancer patients have worse outcomes. World J Surg. 2004;28(6):558-62. [pmid: 15366745].
Oliveria SA, Yood MU, Campbell UB, et al. Treatment and referral patterns for colorectal cancer. Med Care. 2004;42(9):901-6. [pmid: 15319616].
Potosky AL, Harlan LC, Kaplan RS, et al. Age, sex, and racial differences in the use of standard adjuvant therapy for colorectal cancer. J Clin Oncol. 2002;20(5):1192-202. [pmid: 11870160].
Purves H, Pietrobon R, Hervey S, et al. Relationship between surgeon caseload and sphincter preservation in patients with rectal cancer. Dis Colon Rectum. 2005;48(2):195-202. discussion 202–4. [pmid: 15812583].
Rabeneck L, Davila JA, Thompson M, et al. Outcomes in elderly patients following surgery for colorectal cancer in the veterans affairs health care system. Aliment Pharmacol Ther. 2004;20(10):1115-24. [pmid: 15569114].
Read TE, Myerson RJ, Fleshman JW, et al. Surgeon specialty is associated with outcome in rectal cancer treatment. Dis Colon Rectum. 2002;45(7):904-14. [pmid: 12130879].
Retchin SM, Brown B. Management of colorectal cancer in Medicare health maintenance organizations. J Gen Intern Med. 1990;5(2):110-4. [pmid: 2179490].
Roetzheim RG, Pal N, Gonzalez EC, et al. Effects of health insurance and race on colorectal cancer treatments and outcomes. Am J Public Health. 2000;90(11):1746-54. [pmid: 11076244]. [pmcid: 1446414].
Rogers SO, Ray WA, Smalley WE. A population-based study of survival among elderly persons diagnosed with colorectal cancer: does race matter if all are insured? (United States). Cancer Causes Control. 2004;15(2):193-9. [pmid: 15017132].
Rulyak SJ, Mandelson MT, Brentnall TA, et al. Clinical and sociodemographic factors associated with colon surveillance among patients with a history of colorectal cancer. Gastrointest Endosc. 2004;59(2):239-47. [pmid: 14745398].
Schrag D, Cramer LD, Bach PB, et al. Age and adjuvant chemotherapy use after surgery for stage III colon cancer. J Natl Cancer Inst. 2001;93(11):850-7. [pmid: 11390534].
Schrag D, Cramer LD, Bach PB, et al. Influence of hospital procedure volume on outcomes following surgery for colon cancer. JAMA. 2000;284(23):3028-35. [pmid: 11122590].
Schrag D, Gelfand SE, Bach PB, et al. Who gets adjuvant treatment for stage II and III rectal cancer? Insight from surveillance, epidemiology, and end results--Medicare. J Clin Oncol. 2001;19(17):3712-8. [pmid: 11533092].
Schrag D, Panageas KS, Riedel E, et al. Hospital and surgeon procedure volume as predictors of outcome following rectal cancer resection. Ann Surg. 2002;236(5):583-92. [pmid: 12409664]. [pmcid: 1422616].
Schrag D, Panageas KS, Riedel E, et al. Surgeon volume compared to hospital volume as a predictor of outcome following primary colon cancer resection. J Surg Oncol. 2003;83(2):68-78. discussion 78–9. [pmid: 12772198].
Shehadeh I, Rebala S, Kumar R, et al. Retrospective analysis of missed advanced adenomas on surveillance colonoscopy. Am J Gastroenterol. 2002;97(5):1143-7. [pmid: 12014718].
Shields HM, Weiner MS, Henry DR, et al. Factors that influence the decision to do an adequate evaluation of a patient with a positive stool for occult blood. Am J Gastroenterol. 2001;96(1):196-203. [pmid: 11197252].
Simons AJ, Ker R, Groshen S, et al. Variations in treatment of rectal cancer: the influence of hospital type and caseload. Dis Colon Rectum. 1997;40(6):641-6. [pmid: 9194456].
Steele GD Jr. The National Cancer Data Base report on colorectal cancer. Cancer. 1994;74(7):1979-89. [pmid: 8082105].
Steele G. National Cancer Database: Annual review of patient care, 1994. Atlanta, Ga. American Cancer Society. 1994;24–42.
Steele G, Jessup J. National Cancer Database: Annual review of patient care, 1995. Atlanta, Ga. American Cancer Society. 1995;66-83.
Sundararajan V, Grann VR, Jacobson JS, et al. Variations in the use of adjuvant chemotherapy for node-positive colon cancer in the elderly: a population-based study. Cancer J. 2001;7(3):213-8. [pmid: 11419029].
Temple LK, Hsieh L, Wong WD, et al. Use of surgery among elderly patients with stage IV colorectal cancer. J Clin Oncol. 2004;22(17):3475-84. [pmid: 15337795].
Tropman S, Hatzell T, Paskett E, et al. Colon cancer treatment in rural North and South Carolina. Cancer Detect Prev. 1999;23(5):428-34. [pmid: 10468896].
Ure T, Dehghan K, Vernava AM 3rd, et al. Colonoscopy in the elderly. Low risk, high yield. Surg Endosc. 1995;9(5):505-8. [pmid: 7676371].
Vernon SW, Hughes JI, Heckel VM, et al. Quality of care for colorectal cancer in a fee-for-service and health maintenance organization practice. [erratum appears in Cancer 1994 Dec 15;74(12):3249]. Cancer 1992;69(10):2418–25.
Weaver P, Harrison B, Eskander G, et al. Colon cancer in blacks: a disease with a worsening prognosis. J Natl Med Assoc. 1991;83(2):133-6. [pmid: 2005649]. [pmcid: 2627026].
Wei JT, Miller EA, Woosley JT, et al. Quality of colon carcinoma pathology reporting: a process of care study. Cancer. 2004;100(6):1262-7. [pmid: 15022295].
Whittle J, Steinberg EP, Anderson GF, et al. Results of colectomy in elderly patients with colon cancer, based on Medicare claims data. Am J Surg. 1992;163(6):572-6. [pmid: 1308654].
Wudel LJ Jr, Chapman WC, Shyr Y, et al. Disparate outcomes in patients with colorectal cancer: effect of race on long-term survival. Arch Surg. 2002;137(5):550-4. discussion 554–6. [pmid: 11982467].