# References Cited in the Evidence Report

1 Hewitt M, Simone V. Ensuring quality cancer care [electronic resource]. National Cancer Policy Board, Institute of Medicine and Commission on Life Sciences, National Research Council. [An electronic book accessible through the World Wide Web at http://www.netlibrary.com.] Washington, DC: National Academy Press; 1999.
2 Foley KM, Gelband H. Improving palliative care for cancer. National Cancer Policy Board. Washington, DC: National Academy Press; 2001.
3 Hewitt M, Simone V. nhancing data systems to improve the quality of cancer care. Institute of Medicine. Washington, DC: National Academy Press; 2000.
4 Jemal A, Murray T, Ward E, et al. Cancer statistics, 2005. CA Cancer J Clin. 2005;55(1):10-30. [pmid: 15661684].
5 Anonymous. Colorectal cancer test use among persons aged > or = 50 years--United States, 2001. MMWR Morb Mortal Wkly Rep. 2003;52(10):193–6.
6 Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. 2003;124(2):544-60. [pmid: 12557158].
7 Rockey D, Paulson E, Niedzwiecki D, et al. Analysis of air contrast barium enema, computed tomographic colonography and colonscopy: prospective comparison. Lancet. 2005;365:305-11. [pmid: 15664225].
8 Mulhall B, Veerappan G, Jackson J. Meta-analysis: computed tomographic colonography. Ann Intern Med. 2005;142(8):635-50. [pmid: 15838071].
9 Pickhardt P, Nugent P, Mysliwiec P, et al. Location of adenomas missed by optical colonoscopy. Ann Intern Med. 2004;141(5):352-9. [pmid: 15353426].
10 Gluecker TM, Johnson CD, Harmsen WS, et al. Colorectal cancer screening with CT colonography, colonoscopy, and double-contrast barium enema examination: prospective assessment of patient perceptions and preferences. Radiology. 2003;227(2):378-84. [pmid: 12732696].
11 Hobday TJ, Erlichman C. Colorectal cancer. In: Gospodarowick MK, Henson DE, Hutter RV, et al., editors. Prognostic factors in cancer. New York: Wiley-Liss; 2001. p. 333–47.
12 American Joint Committee on Cancer. Colon and rectum. In: AJCC cancer staging manual. 6th edition. New York: Springer; 2002. p. 113–24.
13 Institute of Medicine. Asessing the Quality of Cancer Care: An Approach to Measurement in Georgia. Committee on Assessing Improvements in Cancer Care in Georgia. National Cancer Policy Board. The National Academies Press: Washington, DC; 2005.
14 Greene FL, Page DL, Fleming ID, et al. (eds). AJCC Cancer Staging Manual. 6th edition. New York, NY: Springer; 2002.
15 National Institutes of Health (NIH). NIH consensus conference. Adjuvant therapy for patients with colon and rectal cancer. JAMA. 1990;264(11):1444-50. [pmid: 2202842].
16 Duke CE, Bussey HJ. The spread of rectal cancer and its effect on prognosis. Br J Surg. 1958;12:309-20.
17 Chapuis PH, Dent OF, Fisher R, et al. A multivariate analysis of clinical and pathological variables in prognosis after resection of large bowel cancer. Br J Surg. 1985;72(9):698-702. [pmid: 4041728].
18 Newland RC, Chapuis PH, Pheils MT, et al. The relationship of survival to staging and grading of colorectal carcinoma: a prospective study of 503 cases. Cancer. 1981;47(6):1424-9. [pmid: 7226068].
19 Compton CC, Fielding LP, Burgart LJ, et al. Prognostic factors in colorectal cancer. College of American Pathologists Consensus Statement 1999. Arch Pathol Lab Med. 2000;124(7):979-94. [pmid: 10888773].
20 Swanson RS, Compton CC, Stewart AK, et al. The prognosis of T3N0 colon cancer is dependent on the number of lymph nodes examined. Ann Surg Oncol. 2003;10(1):65-71. [pmid: 12513963].
21 Tepper JE, O'Connell MJ, Niedzwiecki D, et al. Impact of number of nodes retrieved on outcome in patients with rectal cancer. J Clin Oncol. 2001;19(1):157-63. [pmid: 11134208].
22 Heald RJ, Moran BJ, Ryall RD, et al. Rectal cancer: the Basingstoke experience of total mesorectal excision, 1978-1997. Arch Surg. 1998;133:894-9. [pmid: 9711965].
23 Benson AB 3rd, Schrag D, Somerfield MR, et al. American Society of Clinical Oncology recommendations on adjuvant chemotherapy for stage II colon cancer. J Clin Oncol. 2004;22(16):3408-19. [pmid: 15199089].
24 National Comprehensive Cancer Network (NCCN). Clinical practice guidelines in oncology: colon cancer. Version 3, 2005. Available at: http://www.nccn.org/professionals/physician_gls/PDF/colon.pdf. Accessed July 7, 2005.
25 National Comprehensive Cancer Network (NCCN). Clinical practice guidelines in oncology: rectal cancer. Version 3, 2005. Available at: http://www.nccn.org/professionals/physician_gls/PDF/rectal.pdf. Accessed July 7, 2005.
26 Sun W, Haller DG. Adjuvant therapy of colon cancer. Semin Oncol. 2005;32(1):95-102. [pmid: 15726511].
27 Gunderson LL, Sosin H. Areas of failure found at reoperation (second or symptomatic look) following “curative surgery” for adenocarcinoma of the rectum. Clinicopathologic correlation and implications for adjuvant therapy. Cancer. 1974;34(4):1278-92. [pmid: 4424091].
28 Dahlberg M, Glimelius B, Pahlman L. Improved survival and reduction in local failure rates after preoperative radiotherapy: evidence for the generalizability of the results of Swedish Rectal Cancer Trial. Ann Surg. 1999;229(4):493-7. [pmid: 10203081]. [pmcid: 1191734].
29 Martling A, Holm T, Johansson H, et al. The Stockholm II trial on preoperative radiotherapy in rectal carcinoma: long-term follow-up of a population-based study. Cancer. 2001;92(4):896-902. [pmid: 11550163].
30 Medical Research Council Rectal Cancer Working Party. Randomised trial of surgery alone versus radiotherapy followed by surgery for potentially operable locally advanced rectal cancer. Lancet. 1996;348(9042):1605-10. [pmid: 8961989].
31 Medical Research Council Rectal Cancer Working Party. Randomised trial of surgery alone versus surgery followed by radiotherapy for mobile cancer of the rectum. Lancet. 1996;348(9042):1610-4. [pmid: 8961990].
32 National Cancer Institute. Colorectal Cancer (PDQ®): Treatment. Available at http://www.cancer.gov/cancertopics/pdq/treatment/colon/HealthProfessional. Accessed July 1, 2005.
33 Jeffery GM, Hickey BE, Hider P. Follow-up strategies for patients treated for non-metastatic colorectal cancer. The Cochrane Database of Systematic Reviews 2002, Issue 1. Art. No.: CD002200. DOI: 10.1002/14651858.CD002200.
34 Renehan A, Egger M, Saunders M, et al. Impact on survival of intensive follow-up after curative resection for colorectal cancer: a systematic review and meta-analysis of randomised trials. BMJ. 2002;324:813. [pmid: 11934773]. [pmcid: 100789].
35 Pfister DG, Benson AB 3rd, Somerfield MR. Clinical practice. Surveillance strategies after curative treatment of colorectal cancer. N Engl J Med. 2004;350(23):2375-82. [pmid: 15175439].
36 Earle CC, Park ER, Lai B, et al. Identifying potential indicators of the quality of end-of-life cancer care from administrative data. J Clin Oncol. 2003;21(6):1133-8. [pmid: 12637481].
37 Brook RH, McGlynn EA, Cleary PD. Quality of health care. Part 2: measuring quality of care. N Engl J Med. 1996;335(13):966-70. [pmid: 8782507].
38 Davila RE, Rajan E, Adler D, et al. ASGE guideline: the role of endoscopy in the diagnosis, staging, and management of colorectal cancer. Gastrointest Endosc. 2005;61(1):1-7. [pmid: 15672048].
39 Rex DK, Cutler CS, Lemmel GT, et al. Colonoscopic miss rates of adenomas determined by back-to-back colonoscopies. Gastroenterology. 1997;112(1):24-8. [pmid: 8978338].
40 Rex D, Bond J, Winawer S, et al. Quality in the technical performance of colonoscopy and the continuous quality improvement process for colonoscopy: recommendations of the U.S. Multi-Society Task Force on Colorectal Cancer. Am J Gastroenterol. 2002;97(6):1296-308. [pmid: 12094842].
41 Shields HM, Weiner MS, Henry DR, et al. Factors that influence the decision to do an adequate evaluation of a patient with a positive stool for occult blood. Am J Gastroenterol. 2001;96(1):196-203. [pmid: 11197252].
42 Levin B, Hess K, Johnson C. Screening for colorectal cancer. A comparison of 3 fecal occult blood tests. Arch Intern Med. 1997;157(9):970-6. [pmid: 9140267].
43 Baig N, Myers RE, Turner BJ, et al. Physician-reported reasons for limited follow-up of patients with a positive fecal occult blood test screening result. Am J Gastroenterol. 2003;98(9):2078-81. [pmid: 14499791].
44 Myers RE, Turner B, Weinberg D, et al. Impact of a physician-oriented intervention on follow-up in colorectal cancer screening. Prev Med. 2004;38(4):375-81. [pmid: 15020170].
45 Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343(22):1603-7. [pmid: 11096167].
46 Marble K, Banerjee S, Greenwald L. Colorectal carcinoma in young patients. J Surg Oncol. 1992;51(3):179-82. [pmid: 1434643].
47 Minnesota Gastroenterology PA. 2004 Colonoscopy Quality Assurance Initiative. Electronically received: January 26, 2005.
48 Beart RW, Steele GD Jr, Menck HR, et al. Management and survival of patients with adenocarcinoma of the colon and rectum: a national survey of the Commission on Cancer. J Am Coll Surg. 1995;181(3):225-36. [pmid: 7670682].
49 Shehadeh I, Rebala S, Kumar R, et al. Retrospective analysis of missed advanced adenomas on surveillance colonoscopy. Am J Gastroenterol. 2002;97(5):1143-7. [pmid: 12014718].
50 Haseman JH, Lemmel GT, Rahmani EY, et al. Failure of colonoscopy to detect colorectal cancer: evaluation of 47 cases in 20 hospitals. Gastrointest Endosc. 1997;45(6):451-5. [pmid: 9199899].
51 Ure T, Dehghan K, Vernava AM 3rd, et al. Colonoscopy in the elderly. Low risk, high yield. Surg Endosc. 1995;9(5):505-8. [pmid: 7676371].
52 Nelson DB, McQuaid KR, Bond JH, et al. Procedural success and complications of large-scale screening colonoscopy. Gastrointest Endosc. 2002;55(3):307-14. [pmid: 11868001].
53 National Quality Measures Clearinghouse (NQMC). Intra-procedure colonosopy complication rate: percentage of patients who developed one or more intrao-procedure complications. Available at: http://www.qualitymeasures.ahrq.gov/summary/summary.aspx?doc_id=4868. Accessed: March 21, 2005.
54 Colon Cancer Workgroup. Quality of Cancer Care Evaluation and Improvement: Commission on Cancer, American College of Surgeons, American Cancer Society and Tenet Health Care System, December, 2003. Electronically received Febraru 7, 2005.
55 Harewood GC, Sharma VK, de Garmo P. Impact of colonoscopy preparation quality on detection of suspected colonic neoplasia. Gastrointest Endosc. 2003;58(1):76-9. [pmid: 12838225].
56 Levin B, Murphy GP. Revision in American Cancer Society recommendations for the early detection of colorectal cancer. CA Cancer J Clin. 1992;42(5):296-9. [pmid: 1515968].
57 Winawer SJ, Fletcher RH, Miller L, et al. Colorectal cancer screening: clinical guidelines and rationale. [see comment] [erratum appears in Gastroenterology 1997 Mar;112(3):1060]. Gastroenterology. 1997;112(2):594-642. [pmid: 9024315].
58 Eddy D. ACS report on the cancer-related health checkup. CA Cancer J Clin. 1980;30(4):193-240. [pmid: 6774802].
59 Accreditation Association for Ambulatory Health Care (AAAHC) Institute for Quality Improvement. Procedure specific colonoscopy survey [Colonoscopy CPT-45378–45385]. Wilmette (IL): AAAHC Institute for Quality Improvement; 2003.
60 Wexner SD, Litwin D, Cohen J, et al. Principles of privileging and credentialing for endoscopy and colonoscopy. Gastrointest Endosc. 2002;55(2):145-8. [pmid: 11818913].
61 National Committee for Quality Assurance (NCQA). Final List of Colon Cancer Measures Based on Domain Expert Review. Measures developed by Kaiser Permanente, Internountain Health Care and NCQA. Electronically delivered February 8, 2005.
62 O'Connell JB, Maggard MA, Ko CY. Colon cancer survival rates with the new American Joint Committee on Cancer sixth edition staging. J Natl Cancer Inst. 2004;96(19):1420-5. [pmid: 15467030].
63 Bast RC. Cancer medicine. 5th ed. Hamilton, Ontario: B. C. Decker, Inc.; 2000. Section 29, Neoplasms of the alimentary canal.
64 Erlichman C, Fine S, Wong A, et al. A randomized trial of fluorouracil and folinic acid in patients with metastatic colorectal carcinoma. J Clin Oncol. 1988;6(3):469-75. [pmid: 3280741].
65 Prandi M, Lionetto R, Bini A, et al. Prognostic evaluation of stage B colon cancer patients is improved by an adequate lymphadenectomy: results of a secondary analysis of a large scale adjuvant trial. Ann Surg. 2002;235(4):458-63. [pmid: 11923600]. [pmcid: 1422459].
66 Wong JH, Severino R, Honnebier MB, et al. Number of nodes examined and staging accuracy in colorectal carcinoma. J Clin Oncol. 1999;17(9):2896-900. [pmid: 10561368].
67 Compton CC. Pathologic staging of colorectal cancer: an advanced users' guide. Pathology Case Reviews. 2004;9(4):150-62.
68 Baxter N, Virnig D, Rothenberger D, et al. Lymph Node Evaluation in Colorectal Cancer Patients: A Population Based Study. Jl Natl Cancer Inst. 2005;97(3):219-25.
69 Galvis CO, Raab SS, D'Amico F, et al. Pathologists' assistants practice: a measurement of performance. Am J Clin Pathol. 2001;116(6):816-22. [pmid: 11764069].
70 Chiaverini L, Fulton JP, Darcy DM. Progress in the control of colorectal cancer in Rhode Island, 1987-2000. Med Health R I. 2002;85(7):226-8. [pmid: 12182097].
71 Steele G. National Cancer Database: Annual review of patient care, 1994. Atlanta, Ga. American Cancer Society. 1994;24–42.
72 Goldstein N. Lymph node recoveries from 2427 pT3 colorectal resection specimen spanning 45 years: recommendations for a minimum number of recovered lymph nodes based on predictive probabilities. Am J SurgPathol 26(2):179–89.
73 Caplin S, Cerottini JP, Bosman FT, et al. For patients with Dukes' B (TNM Stage II) colorectal carcinoma, examination of six or fewer lymph nodes is related to poor prognosis. Cancer. 1998;83(4):666-72. [pmid: 9708929].
74 Cianchi F, Palomba A, Boddi V, et al. Lymph node recovery from colorectal tumor specimens: recommendation for a minimum number of lymph nodes to be examined. World J Surg. 2002;26(3):384-9. [pmid: 11865379].
75 Goldstein NS, Sanford W, Coffey M, et al. Lymph node recovery from colorectal resection specimens removed for adenocarcinoma. Trends over time and a recommendation for a minimum number of lymph nodes to be recovered. Am J Clin Pathol. 1996;106(2):209-16. [pmid: 8712176].
76 Cserni G, Vinh-Hung V, Burzykowski T. Is there a minimum number of lymph nodes that should be histologically assessed for a reliable nodal staging of T3N0M0 colorectal carcinomas?. J Surg Oncol. 2002;81(2):63-9. [pmid: 12355405].
77 Pocard M, Panis Y, Malassagne B, et al. Assessing the effectiveness of mesorectal excision in rectal cancer: prognostic value of the number of lymph nodes found in resected specimens. Dis Colon Rectum. 1998;41(7):839-45. [pmid: 9678368].
78 Martling A, Singnomklao T, Holm T, et al. Prognostic significance of both surgical and pathological assessment of curative resection for rectal cancer. Br J Surg. 2004;91(8):1040-5. [pmid: 15286968].
79 Seitz U, Bohnacker S, Seewald S, et al. Is endoscopic polypectomy an adequate therapy for malignant colorectal adenomas? Presentation of 114 patients and review of the literature. Dis Colon Rectum. 2004;47(11):1789-96. ; discussion 1796–7. [pmid: 15622570].
80 Rothenberger DA, Akbari R, Baxter NN. Are we overtreating some patients with rectal cancer?. Oncology (Huntingt). 1799;18(14):1789-96. ; discussion 1796. [pmid: 15700627].
81 National Cancer Institute. Rectal Cancer (PDQ®): Treatment. Available at http://www.nci.nih.gov/cancertopics/pdq/treatment/rectal/healthprofessional. Accessed July 1, 2005.
82 Heald RJ, Husband DM, Ryall RD. The mesorectum in rectal cancer surgery - the clue to pelvic recurrence?. Br J Surg. 1982;69(10):613-6. [pmid: 6751457].
83 Autschbach F. The pathological assessment of total mesorectal excision: what are the relevant resection margins?. Recent Results Cancer Res. 2005;165:30-9. [pmid: 15865018].
84 Phillips RK, Hittinger R, Blesovsky L, et al. Local recurrence following ‘curative’ surgery for large bowel cancer: I. The overall picture. Br J Surg. 1984;71(1):12-6. [pmid: 6689962].
85 World Health Organization, International Agency for Research on Cancer, European Commission. Survival of cancer patients in Europe: the Euro Study. Lyon, France: IARC Scientific Publications; 1995.
86 Newcomb PA, Carbone PP. Cancer treatment and age: patient perspectives. J Natl Cancer Inst. 1993;85(19):1580-4. [pmid: 8411231].
87 Demissie K, Oluwole OO, Balasubramanian BA, et al. Racial differences in the treatment of colorectal cancer: a comparison of surgical and radiation therapy between Whites and Blacks. Ann Epidemiol. 2004;14(3):215-21. [pmid: 15036226].
88 Dominitz JA, Samsa GP, Landsman P, et al. Race, treatment, and survival among colorectal carcinoma patients in an equal-access medical system. Cancer. 1998;82(12):2312-20. [pmid: 9635522].
89 Weaver P, Harrison B, Eskander G, et al. Colon cancer in blacks: a disease with a worsening prognosis. J Natl Med Assoc. 1991;83(2):133-6. [pmid: 2005649]. [pmcid: 2627026].
90 Rogers SO, Ray WA, Smalley WE. A population-based study of survival among elderly persons diagnosed with colorectal cancer: does race matter if all are insured? (United States). Cancer Causes Control. 2004;15(2):193-9. [pmid: 15017132].
91 Merrill RM, Brown ML, Potosky AL, et al. Survival and treatment for colorectal cancer Medicare patients in two group/staff health maintenance organizations and the fee-for-service setting. Med Care Res Rev. 1999;56(2):177-96. [pmid: 10373723].
92 Vernon SW, Hughes JI, Heckel VM, et al. Quality of care for colorectal cancer in a fee-for-service and health maintenance organization practice. [erratum appears in Cancer 1994 Dec 15;74(12):3249]. Cancer. 1992;69(10):2418-25. [pmid: 1568165].
93 Cooper GS, Yuan Z, Landefeld CS, et al. Surgery for colorectal cancer: Race-related differences in rates and survival among Medicare beneficiaries. Am J Public Health. 1996;86(4):582-6. [pmid: 8604797]. [pmcid: 1380567].
94 Roetzheim RG, Pal N, Gonzalez EC, et al. Effects of health insurance and race on colorectal cancer treatments and outcomes. Am J Public Health. 2000;90(11):1746-54. [pmid: 11076244]. [pmcid: 1446414].
95 Temple LK, Hsieh L, Wong WD, et al. Use of surgery among elderly patients with stage IV colorectal cancer. J Clin Oncol. 2004;22(17):3475-84. [pmid: 15337795].
96 O'Connell JB, Maggard MA, Liu JH, et al. Do young colon cancer patients have worse outcomes?. World J Surg. 2004;28(6):558-62. [pmid: 15366745].
97 Virnig BA, Warren JL, Cooper GS, et al. Studying radiation therapy using SEER-Medicare-linked data. Med Care 2002;40(8 Suppl):IV–49–54.
98 O'Connell JB, Maggard MA, Liu JH, et al. Are survival rates different for young and older patients with rectal cancer?. Dis Colon Rectum. 2004;47(12):2064-9. [pmid: 15657655].
99 Hyman N, Labow SB, Vermont Chapter of the American College of Surgeons. The Vermont colorectal cancer project: self-portrait. Arch Surg 2002;137(4):413–6.
100 Wudel LJ Jr, Chapman WC, Shyr Y, et al. Disparate outcomes in patients with colorectal cancer: effect of race on long-term survival. Arch Surg. 2002;137(5):550-4. ; discussion 554–6. [pmid: 11982467].
101 Tropman S, Hatzell T, Paskett E, et al. Colon cancer treatment in rural North and South Carolina. Cancer Detect Prev. 1999;23(5):428-34. [pmid: 10468896].
102 Govindarajan R, Shah RV, Erkman LG, et al. Racial differences in the outcome of patients with colorectal carcinoma. Cancer. 2003;97(2):493-8. [pmid: 12518374].
103 Schrag D, Panageas KS, Riedel E, et al. Surgeon volume compared to hospital volume as a predictor of outcome following primary colon cancer resection. J Surg Oncol. 2003;83(2):68-78. ; discussion 78–9. [pmid: 12772198].
104 Hodgson DC, Zhang W, Zaslavsky AM, et al. Relation of hospital volume to colostomy rates and survival for patients with rectal cancer. J Natl Cancer Inst. 2003;95(10):708-16. [pmid: 12759388].
105 Morris AM, Billingsley KG, Baxter NN, et al. Racial disparities in rectal cancer treatment: a population-based analysis. Arch Surg. 2004;139(2):151-5. ; discussion 156. [pmid: 14769572].
106 Simons AJ, Ker R, Groshen S, et al. Variations in treatment of rectal cancer: the influence of hospital type and caseload. Dis Colon Rectum. 1997;40(6):641-6. [pmid: 9194456].
107 Purves H, Pietrobon R, Hervey S, et al. Relationship between surgeon caseload and sphincter preservation in patients with rectal cancer. Dis Colon Rectum. 2005;48(2):195-202. ; discussion 202–4. [pmid: 15812583].
108 Schrag D, Panageas KS, Riedel E, et al. Hospital and surgeon procedure volume as predictors of outcome following rectal cancer resection. Ann Surg. 2002;236(5):583-92. [pmid: 12409664]. [pmcid: 1422616].
109 Read TE, Myerson RJ, Fleshman JW, et al. Surgeon specialty is associated with outcome in rectal cancer treatment. Dis Colon Rectum. 2002;45(7):904-14. [pmid: 12130879].
110 Coburn MC, Pricolo VE, Soderberg CH. Factors affecting prognosis and management of carcinoma of the colon and rectum in patients more than eighty years of age. J Am Coll Surg. 1994;179(1):65-9. [pmid: 8019727].
111 Rabeneck L, Davila JA, Thompson M, et al. Outcomes in elderly patients following surgery for colorectal cancer in the veterans affairs health care system. Aliment Pharmacol Ther. 2004;20(10):1115-24. [pmid: 15569114].
112 Schrag D, Cramer LD, Bach PB, et al. Influence of hospital procedure volume on outcomes following surgery for colon cancer. JAMA. 2000;284(23):3028-35. [pmid: 11122590].
113 Whittle J, Steinberg EP, Anderson GF, et al. Results of colectomy in elderly patients with colon cancer, based on Medicare claims data. Am J Surg. 1992;163(6):572-6. [pmid: 1308654].
114 Agarwal N, Leighton L, Mandile MA, et al. Outcomes of surgery for colorectal cancer in patients age 80 years and older. Am J Gastroenterol. 1990;85(9):1096-101. [pmid: 2389721].
115 Dimick JB, Cowan JA Jr, Upchurch GR Jr, et al. Hospital volume and surgical outcomes for elderly patients with colorectal cancer in the United States. J Surg Res. 2003;114(1):50-6. [pmid: 13678698].
116 Harmon J, Tang D, Gordon T, et al. Hospital Volume Can Serve as a Surrogate for Surgeon Volume for Achieving Excellent Outcomes in Colorectal Resection. Ann Surg. 1999;230(3):404-13. [pmid: 10493487]. [pmcid: 1420885].
117 Ko CY, Chang JT, Chaudhry S, et al. Are high-volume surgeons and hospitals the most important predictors of in-hospital outcome for colon cancer resection?. Surgery. 2002;132(2):268-73. [pmid: 12219022].
118 Marijnen CA, van de Velde CJ, Putter H, et al. Impact of short term preoperative radiotherapy on health related quality of life and sexual functioning in primary rectal cancer: report of a multicenter randomized trial. J Clin Oncol. 2005;23(9):1847-58. [pmid: 15774778].
119 Havenga K, Maas CP, DeRuiter MC, et al. Avoiding long term distrubance to bladder and sexual function in pelvic surgery, particularly with rectal cancer. Sem in Surg Oncol. 2000;18(3):235-43.
120 Lindsey I, George B, Kettlewell M. Randomized double blind placebo controlled trial of sildenafil (Viagra) for erectile dysfunction after rectal excision for cancer and inflammatory bowel disease. Dis Colon Rectum. 2002;45:727-32. [pmid: 12072621].
121 Temple LK, Wonng WD, Minsky B. The impact of radiation on functional outcomes in patients with rectal cancer and sphincter preservation. Semin Radiat Oncol. 2003;13:(469-77). [pmid: 14586835].
122 Hendren SK, O'Connor BI, Liu M, et al. Prvalence of male and female sexual dysfunction is high following surgery for rectal cancer. Ann of Surg. 2005;242(2):212-23. [pmid: 16041212]. [pmcid: 1357727].
123 Gunderson LL, Sargent DJ, Tepper JE, et al. Impact of T and N stage and treatment on survival and relapse in adjuvant rectal cancer: a pooled analysis. J Clin Oncol. 2004;22(10):1785-96. [pmid: 15067027].
124 Coia L, Wizenberg M, Hanlon A, et al. Evaluation and treatment of patients receiving radiation for cancer of the rectum or sigmoid colon in the United States: results of the 1988-1989 Patterns of Care Study process survey. J Clin Oncol. 1994;12(5):954-9. [pmid: 8164047].
125 Potosky AL, Harlan LC, Kaplan RS, et al. Age, sex, and racial differences in the use of standard adjuvant therapy for colorectal cancer. J Clin Oncol. 2002;20(5):1192-202. [pmid: 11870160].
126 Mahoney T, Kuo YH, Topilow A, et al. Stage III colon cancers: why adjuvant chemotherapy is not offered to elderly patients. Arch Surg. 2000;135(2):182-5. [pmid: 10668878].
127 Ayanian JZ, Zaslavsky AM, Fuchs CS, et al. Use of adjuvant chemotherapy and radiation therapy for colorectal cancer in a population-based cohort. J Clin Oncol. 2003;21(7):1293-300. [pmid: 12663717].
128 Schrag D, Cramer LD, Bach PB, et al. Age and adjuvant chemotherapy use after surgery for stage III colon cancer. J Natl Cancer Inst. 2001;93(11):850-7. [pmid: 11390534].
129 Sundararajan V, Grann VR, Jacobson JS, et al. Variations in the use of adjuvant chemotherapy for node-positive colon cancer in the elderly: a population-based study. Cancer J. 2001;7(3):213-8. [pmid: 11419029].
130 Keating N, Landrum M, Meara E, et al. Do Increases in the Market Share of Managed Care Influence Quality of Care in the Fee-For-Service Sector?. J Natl Cancer Inst. 2005;97(4):257-64. [pmid: 15713960].
131 Steele GD Jr. The National Cancer Data Base report on colorectal cancer. Cancer. 1994;74(7):1979-89. [pmid: 8082105].
132 Schrag D, Gelfand SE, Bach PB, et al. Who gets adjuvant treatment for stage II and III rectal cancer? Insight from surveillance, epidemiology, and end results--Medicare. J Clin Oncol. 2001;19(17):3712-8. [pmid: 11533092].
133 Neugut AI, Fleischauer AT, Sundararajan V, et al. Use of adjuvant chemotherapy and radiation therapy for rectal cancer among the elderly: a population-based study. J Clin Oncol. 2002;20(11):2643-50. [pmid: 12039925].
134 Steele G, Jessup J. National Cancer Database: Annual review of patient care, 1995. Atlanta, Ga. American Cancer Society. 1995;66–83.
135 Jessup JM, McGinnis LS, Steele GD Jr, et al. The National Cancer Data Base. Report on colon cancer. Cancer. 1996;78(4):918-26. [pmid: 8756390].
136 Retchin SM, Brown B. Management of colorectal cancer in Medicare health maintenance organizations. J Gen Intern Med. 1990;5(2):110-4. [pmid: 2179490].
137 Oliveria SA, Yood MU, Campbell UB, et al. Treatment and referral patterns for colorectal cancer. Med Care. 2004;42(9):901-6. [pmid: 15319616].
138 Wolmark N, Fisher B, Rockette H, et al. Postoperative adjuvant chemotherapy or BCG for colon cancer: results from NSABP protocol C-01. J Natl Cancer Inst. 1988;80(1):30-6. [pmid: 3276901].
139 Laurie JA, Moertel CG, Fleming TR, et al. Surgical adjuvant therapy of large-bowel carcinoma: an evaluation of levamisole and the combination of levamisole and fluorouracil. The North Central Cancer Treatment Group and the Mayo Clinic. J Clin Oncol. 1989;7(10):1447-56. [pmid: 2778478].
140 Moertel CG, Fleming TR, Macdonald JS, et al. Levamisole and fluorouracil for adjuvant therapy of resected colon carcinoma. N Engl J Med. 1990;322(6):352-8. [pmid: 2300087].
141 Gastrointestinal Tumor Study Group. Prolongation of the disease-free interval in surgically treated rectal carcinoma. N Engl J Med. 1985;312(23):1465-72. [pmid: 2859523].
142 Krook JE, Moertel CG, Gunderson LL, et al. Effective surgical adjuvant therapy for high-risk rectal carcinoma. N Engl J Med. 1991;324(11):709-15. [pmid: 1997835].
143 Sauer R, Becker H, Hohenberger W, et al. Preoperative versus postoperative chemoradiotherapy for rectal cancer. N Engl J Med. 2004;351(17):1731-40. [pmid: 15496622].
144 Kapiteijn E, Marijnen CA, Nagtegaal ID, et al. Preoperative radiotherapy combined with total mesorectal excision for resectable rectal cancer. N Engl J Med. 2001;345(9):638-46. [pmid: 11547717].
145 Baxter NN, Rothenberger DA, Morris AM, et al. Adjuvant radiation for rectal cancer: do we measure up to the standard of care? An epidemiologic analysis of trends over 25 years in the United States. Dis Colon Rectum. 2005;48(1):9-15. [pmid: 15690651].
146 Kline RW, Smith AR, Coia LR, et al. Treatment planning for adenocarcinoma of the rectum and sigmoid: a patterns of care study. PCS Committee. Int J Radiat Oncol Biol Phys. 1997;37(2):305-11. [pmid: 9069301].
147 Minsky BD, Coia L, Haller DG, et al. Radiation therapy for rectosigmoid and rectal cancer: results of the 1992-1994 Patterns of Care process survey. J Clin Oncol. 1998;16(7):2542-7. [pmid: 9667276].
148 Patterns of Care Study (PCS) Consensus Committee. PCS Consensus Committee: 1996 decision trees and management guidelines. Sem Radiat Oncol. 1997;7:163-81.
149 Citarda F, Tomaselli G, Capocaccia R, et al. Efficacy in standard clinical practice of colonoscopic polypectomy in reducing colorectal cancer incidence. [see comment]. Gut. 2001;48(6):812-5. [pmid: 11358901]. [pmcid: 1728339].
150 Winawer SJ, Zauber AG, Ho MN, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329(27):1977-81. [pmid: 8247072].
151 American Cancer Society. Cancer reference information. Detailed guide: colon and rectum cancer. Can colorectal polyps and cancer be found early? 2005. Available at: http://www.cancer.org/docroot/CRI/content/CRI_2_4_3x_Can_Colon_and_rectum_cancer_be_found_early.asp. Accessed July 8, 2005.
152 Anthony T, Simmang C, Hyman N, et al. Practice parameters for the surveillance and follow-up of patients with colon and rectal cancer. Dis Colon Rectum. 2004;47(6):807-17. [pmid: 15108028].
153 Benson A, Desch C, Flynn P, et al. 2000 Update of American Cancer Society of Clinical Oncology Colorectal Cancer Surveillance Guidelines. J Clin Oncol. 2000;18(20):3586-8. [pmid: 11032600].
154 Anonymous. Guidelines for colorectal cancer screening and surveillance. Gastrointest Endosc 2000;51(6):777–82.
155 Knopf KB, Warren JL, Feuer EJ, et al. Bowel surveillance patterns after a diagnosis of colorectal cancer in Medicare beneficiaries. Gastrointest Endosc. 2001;54(5):563-71. [pmid: 11677471].
156 Ellison GL, Warren JL, Knopf KB, et al. Racial differences in the receipt of bowel surveillance following potentially curative colorectal cancer surgery. Health Serv Res. 2003;38(6 Pt 2):1885-903. [pmid: 14727802]. [pmcid: 1360978].
157 Rulyak SJ, Mandelson MT, Brentnall TA, et al. Clinical and sociodemographic factors associated with colon surveillance among patients with a history of colorectal cancer. Gastrointest Endosc. 2004;59(2):239-47. [pmid: 14745398].
158 Cooper GS, Yuan Z, Chak A, et al. Patterns of endoscopic follow-up after surgery for nonmetastatic colorectal cancer. Gastrointest Endosc. 2000;52(1):33-8. [pmid: 10882959].
159 Cooper GS, Yuan Z, Chak A, et al. Geographic and patient variation among Medicare beneficiaries in the use of follow-up testing after surgery for nonmetastatic colorectal carcinoma. Cancer. 1999;85(10):2124-31. [pmid: 10326689].
160 Byers T, Levin B, Rothenberger D, et al. American Cancer Society guidelines for screening and surveillance for early detection of colorectal polyps and cancer: update 1997. American Cancer Society Detection and Treatment Advisory Group on Colorectal Cancer. CA Cancer J Clin. 1997;47(3):154-60. [pmid: 9152173].
161 American Society of Colon and Rectal Surgeons. Practice parameters for the detection of colorectal neoplasms. Dis Colon Rectum. 1992;35(4):389-90. [pmid: 1582363].
162 LaFata EJ, Johnson C, Ben-Menachem T, et al. Sociodemographic differences in the receipt of colorectal cancer surveillance care following treatment with curative intent. Med Care. 2001;39(4):361-72. [pmid: 11329523].
163 Desch C, Benson A, Smith T, et al. Recommended Colorectal Cancer Surveillance Guidelines by the American Society of Clinical Oncology. J Clin Oncol. 1999;17(4):1312-21. [pmid: 10561194].
164 Engstrom PF, Benson AB 3rd, Cohen A, et al. NCCN Colorectal Cancer Practice Guidelines. The National Comprehensive Cancer Network. Oncology (Huntingt). 1996;10(11 Suppl):140-75. [pmid: 8953601].
165 Wei JT, Miller EA, Woosley JT, et al. Quality of colon carcinoma pathology reporting: a process of care study. Cancer. 2004;100(6):1262-7. [pmid: 15022295].
166 Association of Directors of Anatomic and Surgical Pathology. Final diagnosis checklist: colon carcinoma. Ver. 1.1, November 2003. Available at: http://www.adasp.org. Accessed July 8, 2005.
167 Compton CC, College of American Pathologists Cancer Committee. Cancer protocol: colon and rectum. January 2005. Available at: http://www.cap.org/apps/docs/cancer_protocols/protocols_index.html. Accessed July 8, 2005.
168 Compton CC, Henson DE, Hutter RV, et al. Updated protocol for the examination of specimens removed from patients with colorectal carcinoma. A basis for checklists. Arch Pathol Lab Med. 1997;121(12):1247-54. [pmid: 9431313].