# Acknowledgments

The authors gratefully acknowledge Robert Sandler, M.D., M.P.H., Morris Weinberger, Ph.D., and Christopher Willett, M.D., for methodological and clinical advice, and for comments on drafts of material included in this report, and Udita Patel, M.S.P.H., for assistance in drafting parts of the report.