# Conclusions

This section summarizes the overall conclusions about the quality measures identified in our literature review. More detailed conclusions about individual measures are included in the text of Chapter 3, under Questions 1–4.

Our approach to the classification of measures used as its organizing principle the distinction between structure, process, and outcome. Structural measures tended to be linked with the outcomes of complication rates and survival. An example of a typical application is the comparison of hospitals with different volumes of surgery according to the outcome of major complications associated with colorectal cancer (CRC)-related surgery. In these applications the structural variables tended to be generic (and not specific to CRC as such); for example, hospital volume and hospital type (e.g., urban vs. rural, academic vs. other). One application that used a structural measure that was more specific to CRC was the proportion of colonoscopies performed by physicians with formal endoscopy training.

Most applications were quite typical of the literature on structural variables and unremarkable for the purpose of identifying quality measures specific to CRC. The usual caveats to interpretation apply; most particularly, that crucial elements of the pathway between structure and outcome might be missing or incompletely specified. These elements include patient characteristics (e.g., comorbidities, preference for type of treatment, and sometimes even more critical information about stage of disease) and process of care.

Whether part of applications that linked structure to outcome, process to outcome, or focused on outcome alone, outcome variables were of three types: (a) complication rates; (b) survival; and (c) quality of life. Complication rates (e.g., complications of CRC surgery, complications of diagnostic colonoscopy) were straightforwardly defined in the same fashion as the process measures, i.e., as a ratio using a denominator counting the number of eligible patients and a numerator counting the number of such patients with the event of interest; here, a complication of treatment. The points of emphasis were the precise specification of the population at risk in the denominator and the precise specification of the events of interest in the numerator. For example, some outcome measures would most reasonably focus on any complications, whereas others would limit their focus to major complications only.

Survival-related outcome measures were of two types, proportion surviving at a specific point in time (e.g., 30-day mortality rates), and time until event. The former measures can be treated as traditional ratio measures, the main challenge being to select the time period that is most appropriate to the question at hand. For example, mortality rates associated with CRC surgery might reasonably be defined as either in-hospital mortality or 30-day mortality, 30-day mortality being a bit more pertinent but also inducing somewhat more stringent data requirements, as a mechanism for following patients that are discharged before 30 days post-surgery would be required. Time-to-event measures can be, and were, analyzed using traditional techniques of survival analysis such as Kaplan-Meier curves, and Cox models with hazard ratio estimators. Neither version of a survival-related outcome measure involves methodological issues that are unique to CRC.

The final type of outcome measure pertains to quality of life. While quality of life is of immense importance to patients with CRC, it was seldom used in the context of quality improvement, perhaps because of the large number of steps between the leverage points on which an intervention can be performed and the outcome of quality of life (and also because of the large number of other things, besides quality of care, that can affect CRC-related quality of life). Quality-of-life measures are also unique in that they are usually most naturally presented as continuous variables rather than on a ratio scale. A brief discussion of quality-of-life measures is provided in an Appendix A^*^

Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/colocanqm/colocanqm.pdf

The primary focus of this report was on measures of CRC-related processes of care. Here, the main distinction is between those measures that are general versus technical.

The formula for creating a general process measure is to take the sequence of steps describing the optimal pattern of care for patients with CRC (i.e., as graphically summarized in Figures 1 and 2 in Chapter 1, or as described in more detail throughout the document), identify each of these steps as both a leverage point and a potential quality measure, and then define such a measure. For example, one of the earliest steps in the process involves the proper diagnosis of patients with a suspicion of CRC. A well-developed and well-tested measure associated with this step is percentage of patients who underwent appropriate evaluation for a positive fecal occult blood test (FOBT). As with all ratio-based measures, it is critical to carefully define both the numerator and denominator of the measure. Here, the numerator can be based on a guideline and involves colonoscopy with complete visualization of the colon, although the literature did discuss various nuances, such as the precise definition of what complete visualization entails, how soon the colonoscopy should be performed after the positive FOBT, and so forth. The numerators of some general process measures will have a stronger evidence base than others, with those that are based on guidelines (especially those guidelines that are consistent across professional societies, when multiple such guidelines have been proffered) having the strongest evidence base, and those that are derived from basic first principles supported by some research findings being relatively weaker, but often quite sufficient for the task at hand.

Regarding the denominator, “patients with positive FOBT” comprise only a subset of those patients of ultimate interest, namely, “all patients with sufficiently high clinical suspicion of CRC to require followup testing.” These patients would include those with positive tests according to other modalities (e.g., barium enema, flexible sigmoidoscopy), and also those who come to the provider's attention because of symptoms such as bleeding. Often, a clinically precise statement of the denominator involved deleting various patients; for example, those that would be ineligible because of comorbid conditions or other clinical issues, patients that refuse a form of therapy such as chemotherapy, and so forth.

A consistent source of tension is the distinction between the clinically derived fine-tuning of the definition of the denominator of a quality measure and the limitations of available data sources (which often do not contain sufficient information to act on such distinctions). Our approach here has been to encourage the definition of denominators that are as precise as possible, even if the available data sources might not meet all their requirements. In practice, it is crucially important to assess both the strengths and weaknesses of available data sources. Formal validation efforts are encouraged, but are not always strictly necessary. The assessment of data sources should include the differential impact of data quality on patient subgroups. For example, older patients tend to have more comorbidity and might thus be less likely to tolerate adjuvant chemoradiation therapy; an analysis that does not take this tendency into account could incorrectly lead to the conclusion that an age-related bias exists in the provision of such therapy. A similar caveat applies to analyses comparing patients by race and ethnicity, hospitals according to type, and so forth.

Overall, the coverage of general process measures (i.e., across the various leverage points in the sequence of care) is extensive. At least some process measures are available for the steps involving diagnostic imaging, staging, surgical therapy, adjuvant chemotherapy, adjuvant radiation therapy, and colonoscopic surveillance. Additional general process measures might be developed for polyp assessment and removal, although it must be recognized that the proper clinical course of action when presented with a malignant polyp is not always clear. While the above formula could be followed to generate even more general process measures within the above categories, perhaps the task of greater importance is to continue to refine those measures that already exist. The continued expansion of the evidence base, and the continued updating of guidelines, should assist this process. Moreover, the basic structure of general process measures facilitates such updating. For example, if future research suggests that the optimal interval for colonoscopic surveillance should be changed, then the structure of the existing quality measures related to surveillance need not be changed; all that would require change is the replacement of one recommended interval with another.

General process measures were used in both formal quality improvement applications as well as more general research applications, the distinction being that these latter applications did not tend to specify information such as the users and uses of the measure (i.e., the quality improvement context), as well as various other details about databases and other procedures that reflect the specificity required for quality improvement. Chapter 3 did not always explicitly maintain the distinction between these types of application, the main and quite encouraging reason being that it appeared that many of those measures that were used outside the quality improvement context could be rather straightforwardly modified to fit into this context. Overall, the general state of the science regarding general process measures was encouraging.

In contrast to general process measures, as might be anticipated, technical measures tended to be used in a quality improvement context. Although some excellent technical measures were found, the overall development of technical measures seems somewhat less advanced than that of the general process measures. In particular, for some elements of the care pathway, such as operative reports and chemotherapy reports, no technical measures were found. Various technical measures for quality of colonoscopy were found (e.g., cecal intubation rate). These were guideline-based, well developed, but less well tested, and the linkage between the technical measures and patient outcomes, although intuitive, was not always explicitly provided. To the extent that complication rates of colonoscopy can be considered a technical measure, this area of inquiry is relatively well developed. Adequate lymph node retrieval and evaluation is an excellent technical measure related to disease staging, although residual areas requiring clarification remain (e.g., optimal number of lymph nodes to examine, consideration that the optimal number of lymph node depends to some extent on patient characteristics). Technical measures associated with surgery are underdeveloped. Chemoradiation therapy has a number of potential and well-justified technical measures; here, the challenge is to identify and focus on those measures having the most impact on patient outcomes. Regarding reporting, technical measures for pathology reporting are well developed, reflecting among other things the areas of emphasis among the relevant professional societies. As noted above, no such technical process measures were identified for operative reports or chemotherapy reports, although it can quite reasonably presumed that with sufficient attention from professional societies and other stakeholders such measures could be developed.

Perhaps the most important areas for future development of technical measures are (a) developing such measures in those areas for which they are lacking; and (b) in areas where such measures exist, identifying and focusing on those measures having the greatest impact on outcome. As with the general measures, clarifying and otherwise fine-tuning the technical measures is a process that should be ongoing.