# Future Research

In brief, we have identified the following gaps in our knowledge, or equivalently, areas of emphasis for future research:

- Developing the two general process measures pertaining to the treatment of polyps (particularly, those polyps with evidence of malignancy) identified in this report.
- Expanding technical process measures for those topics with too few or no such measures; these include operative reports, chemotherapy reports, the treatment of polyps, and surgery.
- For those areas in which technical measures are well developed, identifying and focusing on those measures having the greatest impact on patient outcomes.
- Improving the evidence base on which all quality measures for colorectal cancer (CRC) are based.
- Clarifying and otherwise fine-tuning both the numerator and denominator of various measures (while at the same time addressing the trade-off between increased information requirements and data sources).
- Providing more explicit directions regarding risk-adjustment.
- Capturing data regarding patient preferences.
- Addressing quality of life (which is of immense importance to patients) within the context of quality improvement for CRC.

More detailed discussion regarding these gaps and future research required to fill them is provided under Questions 1 to 4, above.

The progress to date, as reflected by the existing quality measures, lends confidence that such future research will be fruitful.