# Methods

## Topic Assessment and Refinement

Five key questions are addressed by this report. The Duke research team clarified and refined the overall research objectives and key questions by first consulting with the study sponsors, and then convening a panel of national experts to serve as advisors to the project. These experts were selected to represent relevant specialties including colorectal surgery, medical and radiation oncology, internal medicine, clinical pathology, and gastroenterology, as well as representatives of the National Cancer Institute (NCI) and the National Quality Forum (NQF). The eight members of the technical expert panel were:

John Z. Ayanian, M.D., M.P.P., Harvard Medical School Steven Boyd Clauser, Ph.D., National Cancer Institute Rodger Jeffrey Winn, M.D., National Quality Forum Richard M. Goldberg, M.D., University of North Carolina at Chapel Hill Marcia R. Gottfried, M.D., Duke University Medical Center Michael P. Pignone, M.D., University of North Carolina at Chapel Hill Dawn T. Provenzale, M.D., Duke University Medical Center Kirk A. Ludwig, M.D., Duke University Medical Center

Six key questions were originally proposed by the report's sponsors:

Question 1: What quality-of-care measures are available and what evidence is available for these measures to assess the quality of diagnosis of colon cancer, including: (a) appropriate use of colon imaging, endoscopic visualization, and biopsy; and (b) availability and accuracy of pathologic staging?

Question 2: As appropriate to specific stages of colorectal cancer, what quality-of-care measures are available and what evidence is available for measures of quality of care of treatment of colorectal cancer, including: (a) polypectomy for malignant polyps, including evaluation of surgical margins; (b) surgical therapy specifically for rectal cancers; (c) appropriate use of adjuvant chemotherapy; and (d) appropriate use of radiation therapy for either curative or palliative therapy, specifically for rectal cancers?

Question 3: What quality-of-care measures are available and what evidence is available for measures of colonoscopic surveillance for colorectal cancer?

Question 4: What measures are available and what evidence is available for measures to assess the adequacy and completeness of documentation of pathology, operative, and chemotherapy reports?

Question 5: For questions 1–4 above: (a) in what patient populations and for what purposes have these quality-of-care measures been used; and (b) does evidence support the use of any of these measures to assess differences in quality of care across patients' age, race/ethnicity, and/or socioeconomic status?

Question 6: For questions 1–4 above, what gaps in our knowledge of measurement of quality of care are evident from the currently available evidence, either for the population of colon cancer patients as a whole, or for specific subpopulations?

As a result of conference calls with the technical experts and the report's sponsors, and in response to comments on the peer review draft, the Duke research team modified these questions. Question 6 was eliminated as a separate question, and information on gaps in our knowledge was incorporated into the responses to Questions 1–4 in Chapter 3 and into Chapter 4. The refined key questions were as follows (changes from the initial versions are italicized):

Question 1: What quality-of-care measures are available and what evidence is available for these measures to assess the quality of diagnosis of colorectal cancer, including: (a) appropriate use of colon imaging, endoscopic visualization, and biopsy; and (b) availability and accuracy of pathologic staging?

Question 2: As appropriate to specific stages of colorectal cancer, what quality-of-care measures are available and what evidence is available for measures of quality of care of treatment of colorectal cancer, including: (a) polypectomy for malignant polyps, including evaluation of surgical margins; (b) surgical therapy for colon and rectal cancers; (c) appropriate use of adjuvant chemotherapy and adjuvant radiation therapy, including for patients with metastatic but potentially curable (hepatic/pulmonary-resectable) disease; and (d) appropriate use of radiation therapy for either curative or palliative therapy, specifically for rectal cancers?

Question 3: What quality-of-care measures are available and what evidence is available for measures of colonoscopic surveillance for colorectal cancer?

Question 4: What measures are available and what evidence is available for measures to assess the adequacy and completeness of documentation of pathology, operative, and chemotherapy reports?

Question 5: For questions 1–4 above: (a) in what patient populations and for what purposes have these quality-of-care measures been used; and (b) does evidence support the use of any of these measures to assess differences in quality of care across patients' age, race/ethnicity, and/or socioeconomic status?

## Analytic Framework

Based on the original proposal and discussions with our technical expert panel, we developed the analytical framework represented by Figures 1 and 2 (in Chapter 1). Briefly, these figures describe the various steps in the diagnosis of colorectal cancer (CRC), the treatment of CRC, and the post-treatment surveillance for recurrence of CRC. Each step describes a potential leverage point for improving the quality of care and thus represents the opportunity for defining a process measure. The ultimate goal is to improve patient outcomes, in particular both survival and quality of life.

As noted in the introduction, the quality of CRC-related care has been assessed at both the level of process and of outcome. Outcome measures most directly reflect what is ultimately of interest, but the connection with process of care might be weak (e.g., a good process of care might nevertheless result in poor outcomes), especially if (a) there are a number of links between the process of care and outcome; and/or (b) the outcome might be caused by many factors other than the process of care. With this in mind, we have separated the presentation of outcome measures from those pertaining to process. In particular, in the literature we observed outcome measures of two types: survival and quality of life. Survival measures (e.g., percentage of patients surviving 5 years) are discussed within the main body of the text (e.g., under Question 5, we describe differences in survival by age). Quality-of-life measures, which were relatively uncommon in the literature, are discussed in Appendix A^*^

Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/colocanqm/colocanqm.pdf

While recognizing the ultimate importance of outcomes, the main focus of the text is on measures of process. These process measures have been applied in a number of different contexts. When applied within the context of clinical epidemiology, a process measure might simply be defined as, for example, “the number of patients with stage III colon cancer receiving adjuvant chemotherapy.” On the other hand, when applied within a quality improvement context, process measures generally require not just this basic descriptive component, but also additional information such as a list of data elements that are necessary to construct and/or report the measure, detailed specifications regarding the population on whom the measure is constructed, the source of the data, how the data elements are to be collected, the timing of data collection and reporting, the analytic models used to construct the measure, and the format in which the results will be presented. Measures may also include thresholds, standards, or other benchmarks of performance.

In summary, the application of a process measure in a quality improvement setting includes not just the measure itself, but also various critical details as illustrated above. Such details need not necessarily be specified when applying the same process measure in a more general research setting. Nevertheless, some process measures that have been applied outside the setting of quality improvement might be excellent candidates for the quality improvement setting, (conditional on the specification of the various additional details as noted above); accordingly, we interpreted our task as finding both the former (actual quality improvement process measures) and the latter (potential quality improvement process measures).

One of the implications of the above was the need to extend the criteria for assessing quality measures. In particular, the assessment criteria provided by the NQF are most naturally intended for the circumstance where a ratio-based process measure is applied within a quality improvement application. For such measures we applied the NQF assessment criteria as provided. For other measures, we developed criteria intended to be consistent with the principles underlying the NQF's assessment criteria, as applied to this somewhat different circumstance. Additional details are provided in the section on “Quality Assessment Criteria,” below.

## Literature Search and Review

### Sources

The primary sources of literature were MEDLINE^®^ (1966-January 2005) and the Cochrane Database of Systematic Reviews. Searches of these databases were supplemented by reviews of reference lists contained in seed articles, all included articles, relevant review articles, and meta-analyses. We made special attempts to retrieve grey literature, loosely defined as institutional or government reports, professional society documents, research papers, fact sheets, and other literature, in print or electronic format, that is not controlled by commercial publishing interests. Sources for grey literature included professional organization websites and the Internet.

### Search Strategies

The basic search strategy used the National Library of Medicine's Medical Subject Headings (MeSH) key word nomenclature developed for MEDLINE^®^ and was adapted for use in the other databases. The searches were limited to the English language. The text of the major search strategy is given in Appendix B^*^, as well as a history of search terms considered.

The final search, conducted in January 2005, yielded 5450 citations. When limited to publication date since 1990 and English language, this totaled 3,771 citations. These records were maintained in a ProCite (Thompson ISI ResearchSoft, Berkeley, CA) database.

### Abstract and Full-Text Screening

Paired content experts from the Duke research team independently reviewed a set of abstracts and classified each as “include” or “exclude.” An abstract was retained at this stage if at least one of the paired reviewers recommended that it be included, and abstractors were instructed to apply the inclusion criteria liberally. Inter-rater reliability for include/exclude decisions was tested by having five pairs of readers review a subset of abstracts (n = 765). Agreement ranged from a kappa of 0.23 to 0.46. Samples of abstracts for which abstractors disagreed were reviewed, and it was noted that most disagreements occurred for marginal articles and reflected the abstractors' attempts to be as inclusive as possible during this preliminary screening stage. A total of 874 abstracts were included for the further “full-text review” stage.

At the full-text review stage, the paired researchers independently reviewed a set of the articles, and indicated a decision to “include” or “exclude” the article for the data abstraction stage. Detailed inclusion and exclusion screening criteria were developed for this purpose (see “Full-text Screening Criteria,” below). When a pair of reviewers arrived at a different opinion about whether to include an article, they were asked to reconcile the difference. Detailed inclusion and exclusion screening criteria were developed and are listed below.

### Full-Text Screening Criteria

The full-text screening criteria were as follows:

Include if:

- The study population pertains to adults undergoing diagnostic evaluation for, or in treatment for, colon or rectal cancer, and at least one of the following apply:
  - Asymptomatic patients who have been screened AND have a positive finding suspicious for colon or rectal cancer (e.g., polyps).
  - Patients being diagnosed through the use of colon imaging, endoscopic visualization, or biopsy (Question 1a).
  - Diagnosed patients undergoing pathology staging (Question 1b).
  - Patients undergoing polypectomy for malignant colonic polyps (Question 2a).
  - Patients treated with surgical therapy for either rectal cancer or colon cancer (Question 2b).
  - Patients with metastatic, but potentially curable (hepatic/pulmonary-resectable) disease, when a majority of the study population has CRC (Question 2c).
  - Patients treated with adjuvant chemotherapy or radiation therapy (Questions 2c and 2d).
  - Patients treated with palliative chemotherapy or radiotherapy (Questions 2c and 2d).
  - Patients undergoing colonoscopic surveillance (no other form of surveillance) for CRC (Question 3).
- AND
- The study refers to at least one of the following:
  - An explicit quality measure (process, structure, or outcome).
  - A measure that assesses the adequacy and completeness of documentation of pathology, operative, or chemotherapy reports (operative procedures will include reports for colonoscopy and radiation therapy) (Question 4).
  - The testing of a quality measure's validity or reliability.
  - A data source (e.g., registry) used for measuring quality, but may not specify the quality measure itself.
- Exclude if one or more of the following apply:
- The study uses non-U.S. data.
- The study was published prior to 1990.
- The report is in a non-English language.
- The study population involves any of the following:
  - The screening of asymptomatic patients.
  - Patients with familial polyposis syndrome.
  - Patients undergoing polypectomy for hereditary polyposis.
  - Patients with hereditary non-polyposis colorectal cancer.
  - Patients with multiple metastases, BUT the majority of the patients ARE NOT CRC patients.

Summaries of the results of the abstract screening and full-text review are provided in Tables 1 and 2. A list of excluded articles by reason for exclusion is found in Appendix C^*^

Table 1 Results of abstract screening and full-text review

Articles identified | 3,771
Abstracts reviewed | 3,771
Included | 948
Excluded | 2,823
Full-text articles reviewed | 947*
Included | 74
Excluded | 873

* We were unable to obtain in full-text form 1 article included at the abstract screening stage.

Table 2 Included full-text articles by research question

Question 1a: | 15
Question 1b: | 7
Question 2a: | 0
Question 2b: | 33
Question 2c: | 31
Question 2d: | 22
Question 3: | 8
Question 4: | 3
Question 5: | 30
Total number of included articles | 74*

* Total of table does not equal total number of included articles because some articles were included for more than one question.

## Data Abstraction and Development of Evidence Tables

The Duke research team developed and piloted evidence table formats for abstracting the quality measures and related data to answer each of the six research questions (see Appendix D^*^). A pair of researchers was assigned to each research question based on clinical expertise and was instructed to abstract the quality measures and related data from the eligible articles. One of the paired researchers abstracted the quality measures and related data into the evidence tables, and the second researcher over-read the article and accompanying evidence table to check for accuracy and completeness. The completed evidence tables are provided in Appendix E.

## Quality Assessment Criteria

At the data abstraction stage, the abstractor was asked to evaluate each article for factors affecting external and internal validity. External validity was primarily addressed by the items on the data abstraction form pertaining to the study population.

As an assessment of internal validity, our original charge recommended that we assess the quality measures retrieved during our literature search using a set of criteria that had previously been applied by the NQF with success. These criteria are listed below.

Importance: A measure is considered important if one or more audiences find the information produced from a measure useful for some purpose. Measures can be important because:

a. There is considerable variation in the quality of care provided.
b. Quality is substandard.
c. They relate to one of the established national goals.
d. They represent a significant leverage point for achieving the goal.
e. The information produced is usable by a stakeholder in the system.

It is not necessary for all conditions to apply. However, criteria a or b must be present and be associated with c, d, or e for the measure to be considered important.

Usability: An intended audience must be able to understand the results of the measure and find them useful for decisionmaking. For a measure to be useful:

a. It must contain information that is compelling within the decisionmaking framework of the user.
b. It must assess differences that are subjected to statistical testing, e.g., between groups, over time.
c. Differences must be practically meaningful.
d. Analysis should be done appropriately.
e. It must present results that are effective and consistent with intended use.

Scientific Acceptability: A measure is scientifically acceptable if it produces consistent and credible results when implemented. There are five criteria on which to evaluate each quality measure (in a given study) to determine if it is scientifically acceptable:

[underlined: Precise specifications] - a specification of a measure should include its format, and a standard reference source for defining key terms (clinical conditions, procedures, etc.) that is consistent with current requirements.

[underlined: Reliability] - a measure is reliable when it produces the same result a high proportion of the time when assessed on the same population using the same data source.

[underlined: Validity] - the validity of a measure is the extent to which it accurately represents the concept being evaluated. A measure is considered valid if (1) the scores that are produced from the measure distinguish between good and bad quality, and (2) the construction of the measure adequately represents the concept of interest.

[underlined: Adaptability] - a measure is adaptable if it is appropriate for use in a variety of contexts and settings. Three dimensions of adaptability important to quality measurement are: (1) the ability to take into account patient preferences, (2) the flexibility to account for different clinical scenarios and (3) the applicability of the measure in different settings.

[underlined: Adequacy of risk-adjustment] - when there is a clear clinical rationale, a quality measure should be adjusted for risk differences when making comparisons among health plans or physicians. It is less important to risk-adjust a quality measure when using the measure to track progress toward a health goal, for example, or when measuring changes over time within a single health care setting.

Each of the above elements was scored on a 1–5 scale, with 1 denoting “poor” and 5 denoting “ideal.” The evidence tables report assessments for measures as reported in individual studies.

In order to encourage reliability between abstractors, we held a “calibration” meeting where each investigator scored the same five quality measures (picked randomly, one for each task order question), discussed the scores and the differences in individual scoring, and re-scored them. The abstractors agreed on the scores 83 percent of the time. Subsequent to this calibration meeting, at least three investigators scored every measure, and a mean score was determined and finally allocated to each criterion.

Note that at this stage there could be several scores attached to the same quality measure, and that a single study could produce more than one measure. The evidence tables include scores for every study assessing a given measure in that study.

Another purpose of the calibration meeting was to identify and resolve any questions that the abstractors might have about how to fill in the abstraction form. During this meeting it was noted that, while the above scoring system tended to perform excellently for those “actual” quality measures that were used in quality improvement applications, it performed less well for those “potential” quality measures that were reported from other research studies. For these latter measures, abstractors were instructed to fill out the abstraction form as originally designed and (a) for those elements that were not applicable, either code the measure as “poor” or “not applicable”, as indicated; and (b) when feasible, to envision an application where the measure is used in a quality improvement context, and then to score the measure according to that application. For example, for applications in which the quality measure in question was not risk-adjusted, the abstractor might nevertheless be able to express an informed opinion about whether such risk-adjustment was possible. As another example, the review criteria for usability assume that a decisionmaker and decisionmaking context has already been specified (as would be the case in a quality improvement application); in this case as well, the abstractor might nevertheless be able to envision a typical user and proceed.

Recognizing that the ultimate use of the quality measures included in our evidence report was to inform the sponsors regarding the extent to which they were ready to be applied in the field, at this final stage we rated each quality measure across studies using three criteria: importance and usability, scientific acceptability, and extent of testing. For assigning these rates, we considered all studies that had utilized the particular measure. Details of the method we used to assign these ratings are provided in Appendix F^*^ Each measure was given an “I-S-T” rating, where:

“I” describes the extent to which a measure is important and usable. This rating was determined by examining all the studies that utilized the measure and considering the best application.

“S” describes the extent to which the measure is scientifically acceptable, that is, the extent to which the measure is precisely defined, valid, reliable, adaptable, and risk-adjusted. This rating was also determined by examining all the studies that utilized the measure and considering the best application. For example, if a measure was successfully risk-adjusted in one study but not in another, we rated the measure as one in which risk-adjustment had successfully been applied.

“T” describes the extent to which the measure is tested. This rating was determined by examining all the studies that utilized the measure and considered two aspects of the measure: (a) the number of studies that utilized the measure, and (b) the extent to which these studies were scientifically acceptable (i.e., the “S” rating).

Each of the above criteria was rated on a scale of 1–5, with 1 denoting “poor” and 5 denoting “ideal.” For example, if a quality measure has been assigned a rating of I_5_S_3_T_1_, the measure has high importance and moderate scientific acceptability, but has not been tested.

This final scoring and rate assignment were done exclusively by the writer of each section (the writer was an investigator trained in that content area of the report). Although we had provided objective criteria for rating the quality measures, in order to encourage maximum flexibility (especially for “potential” quality measures), the writer was instructed to adapt the basic scoring and rating rules to the quality measure using their subjective judgment. Most of our recommendations follow directly from this assignment of ratings.

For some measures that we retrieved from professional society websites or from personal communications (i.e., not from peer-reviewed literature) we did not attempt to retrieve any information regarding their testing. Therefore those measures may not have a “T” rating, although it is possible that they have undergone testing.

At the end of each section in Chapter 3, a table with the structure illustrated below (Table 3) summarizes the I-S-T ratings assigned to the quality measures considered. The text in the “Recommendations” column of each table synthesizes the information in the corresponding “Future Research” section of the text. One use of this report will be to assist the NQF technical panel in identifying gaps in measurement that could be the basis for a future research agenda. Such research might include pilot testing or assessment of the measure's appropriateness for populations other than that for which it was designed; evaluation of the appropriateness of the measure for use in routine clinical practice, quality improvement, or accountability; or data collection about the care of specific populations.

Table 3 Sample quality measure ratings table

Quality measure | Quality measure rating (range 1–5, where 1 = poor and 5 = ideal) | | | Recommendations for the measure
| Important and usable (I) | Scientifically acceptable (S) | Well tested (T)

Note: Investigators used their judgment to determine the quality measure rating for each measure across all studies that utilized the measure. See Appendix F* for details.

To comment, inclusion of potential in addition to actual quality measures necessitated the above relatively modest modifications of the quality assessment process. However, since many of the potential quality measures that we identified were excellent (and since our initial consultation with NQF suggested that our charge in identifying quality measures should be defined broadly rather than narrowly), we nevertheless felt that the benefits of including these potential measures outweighed their limitations. For any particular measure, the distinction between actual and potential quality measures should be clear from the context, so those readers who wish to limit their focus to measures that have been developed and tested in quality improvement applications should be able to do so.

## Additional Analyses

There were no additional analyses beyond those described here.

## Peer Review Process

We employed internal and external quality-monitoring checks through every phase of the study to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include: three progressively stricter screening opportunities for each article (abstract screening, full-text article review, data abstraction review); involvement of three individuals (two clinicians and copy editor) in each data abstraction; agreement of at least two clinicians on all included studies.

Our principal external quality-monitoring device was the peer review process. Nominations for peer reviewers were solicited from several sources, including our technical expert panel and interested federal agencies. The list of nominees was forwarded to AHRQ for vetting and approval.