# Introduction

## General Background

The National Cancer Policy Board (NCBP) of the Institute of Medicine (IOM) has concluded that “for many Americans with cancer, there is a wide gulf between what could be construed as the ideal and the reality of their experience with cancer care.”^1^ Concerns about the nation's system of cancer care prompted the NCPB to undertake a comprehensive review of the evidence on the effectiveness of cancer services and delivery systems in the U.S., the adequacy of quality assurance mechanisms, and barriers that impede access to cancer care. As a part of these efforts, the IOM released three reports entitled Ensuring Quality Cancer Care, Enhancing Data Systems to Improve the Quality of Cancer Care, and Improving Palliative Care for Cancer, which summarized the state of knowledge in quality cancer care and identified efforts to improve it.^1^–^3^ A key recommendation was for further development and monitoring of measures of the quality of cancer-related health care. The focus of this evidence report is measures of the quality of care provided to patients with colorectal cancer (CRC).

The present report was sponsored by the Agency for Healthcare Research and Quality (AHRQ), the National Cancer Institute (NCI), the Centers for Medicare & Medicaid Services (CMS), and the Centers for Disease Control and Prevention (CDC). Information from the report will be used by technical panels convened by the National Quality Forum (NQF). One mission of the NQF is to encourage the development and application of validated measures of the quality of care for patients with various medical conditions. This report will provide part of the evidence base from which the NQF will make recommendations about quality measures for patients with CRC. For this report, the NQF, in conjunction with representatives of AHRQ, NCI, CMS, and CDC, provided a set of research questions of interest, a list of review criteria that have been successfully applied to quality measures in other fields, and general expertise in quality measurement, which was made available to us on an as-needed basis.

The focus of this evidence report combines two basic ideas: (a) care provided to patients with CRC; and (b) quality measures. The remainder of this Chapter provides non-technical descriptions of each. That is, it describes in basic terms what care should be expected for patients with CRC and provides an operational definition of a quality measure. More detailed discussion of these issues is provided in subsequent sections of this report.

## Care of Patients With Colorectal Cancer

### Burden of Disease

The burden of illness from CRC is substantial. In 2003, it is estimated that there were 145,290 new cases and 56,290 deaths attributable to CRC in the U.S. CRC is the second leading cause of cancer death in the U.S.^4^

### Conceptual Model

Our conceptual model of the process of care for colon and rectal cancer patients in the U.S. is depicted in Figures 1 and 2. The next sections discuss the various elements of care represented within these figures.

Figure 1. Diagnosis and management of colon cancer

Figure 2. Diagnosis and management of rectal cancer

### Diagnosis of CRC

The preferred method of CRC detection is through screening of asymptomatic patients. The clinical rationale for screening is that CRC is a cancer that is usually slow growing, and if the cancer is caught at an early stage (ideally, at the polyp stage), then it is more likely to be cured. However, in spite of demonstrated benefit and published clinical guidelines, CRC screening tests are underutilized.^5^ In part due to this underutilization, some patients will be diagnosed with CRC because of symptoms.

Quality measures related to CRC screening have been evaluated elsewhere. At the request of the NQF, we restricted our analysis to: (a) the additional pattern of tests used to diagnose CRC in patients for whom either a screening test result or the presence of symptoms suggests an increased risk of CRC; and (b) screening for recurrence of disease following surgery for CRC, this latter application being termed “surveillance.” The preferred test in both applications is a colonoscopy.

Colonoscopy is the most sensitive test for detection of colorectal neoplasia and the only method that allows both examination of the entire large bowel and the opportunity to biopsy or even remove suspected lesions.^6^ Various screening tests such as double contrast barium enema, flexible sigmoidoscopy, and fecal occult blood test may have preceded the colonoscopy. However, these modalities are no longer recommended as followup tests.^6^ Computed tomographic (CT) colonography (“virtual colonoscopy”) is an emerging technology with the potential to screen for CRC, but it is not currently endorsed for screening or diagnostic evaluation.^6^–^10^

### Staging

Surgical resection remains the most effective therapy for colorectal carcinoma. Clinical staging involves evaluating the primary tumor and the presence of nodal and distant metastases; clinical staging begins with evaluation of signs and symptoms, radiographic, and laboratory tests, and includes findings from direct visualization via endoscopy or surgery. For rectal cancer, clinical staging also includes endoscopic ultrasound or Phased Array MRI preoperatively to determine the depth of penetration and the possibility of regional nodal disease, which cannot be accurately assessed by pelvic CT scanning.

Pathologic staging is performed after surgical resection of the primary tumor, and accurate staging is critical for appropriate patient management and also for comparability of data across research studies.^11^

The prognosis of patients with colon cancer is clearly related to the degree of penetration of the tumor through the bowel wall, the presence or absence of nodal involvement, and the presence or absence of distant metastases. These three characteristics form the basis for all staging systems developed for this disease. Bowel obstruction and bowel perforation are additional indicators of poor prognosis.^12^

Although the microscopic appearance of adenocarcinoma of the colon and rectum tends to be straightforward, a detailed pathology review is essential for diagnosis, characterization, and staging. Pathologic stage combines the clinical staging information with surgical findings, incorporating data from the pathologic examination of resected primary and regional lymph nodes.^13^ The pathology report is a critical step in the process of pathologic staging. Information on pathology reports should be sufficient to stage the patient using the Tumor, Node, Metastasis Staging System (TNM).^14^ Other key factors include the grade of the tumor and the surgical margin status.

The assessment of nodal metastases at the time of surgical treatment is particularly crucial for patients with apparently localized carcinoma of the colon and rectum, since the presence of nodal metastases is currently the most important factor in determining whether an individual is a candidate for adjuvant therapy.^15^ Moreover, stage of disease is the single most important factor in predicting survival.^16^–^18^ The small size of many mesenteric nodes, including some with micrometastatic carcinoma, increases the risk of missing metastases. Recent studies have demonstrated that 10 to 15 lymph nodes are needed for reliable staging.^19^–^21^

### Management: Surgery

Standard treatment for patients with stages I–III colon cancer has been open surgical resection of the primary tumor and regional lymph nodes for localized disease. Polypectomy for malignant polyps is adequate for polyps that have not invaded the submucosa, because these tumors do not metastasize. For polyps that reveal submucosal, lymphovascular, or neural invasion, a bowel resection should be performed. Although surgery is usually reserved for patients with non-metastatic disease, palliative surgery or diverting colostomy is sometimes performed in patients with metastatic disease and bowel obstruction. Some patients who have developed metastases in the liver are also candidates for surgery. Improved surgical techniques and advances in preoperative imaging have allowed for better patient selection for resection.

Localized rectal cancer is treated by surgical resection of the primary tumor and regional lymph nodes. Although previously patients underwent surgery and then postoperative chemoradiotherapy, currently patients with clinical stage T1,2 disease proceed to surgical resection, while most patients with clinical stage T3 or T4 or N+ tumors now receive preoperative chemotherapy and radiotherapy. Most rectal cancers that are located 5 cm or more from the anal verge can be removed while preserving the anal sphincter. For small rectal cancers with favorable pathologic features, local full-thickness excisions may be adequate. The resective technique of total mesorectal excision has led to reduction in local recurrences and improvement in overall survival.^22^

### Management: Chemotherapy

Because their cancers have spread beyond the colon and rectum, patients with stage III colon cancer without medical or psychosocial contraindications to treatment are recommended to have systemic adjuvant chemotherapy following surgical resection.^15^ Patients with stage II and III rectal cancer also benefit from chemotherapy.^15,23^ Palliative multiagent chemotherapy also increases survival for those with stage IV disease, although it is not curative.^24,25^

The steps in the process of receiving appropriate adjuvant chemotherapy are that patients with CRC must be staged appropriately, be referred to an oncologist, receive an adequate performance status evaluation, and be ascertained to be free of major postoperative complications. Chemotherapy must then be offered and administered at an appropriate dosage for an appropriate length of time.^26^ Finally, adequate reporting must be provided, this requirement applying equally to surgical therapy, chemotherapy, and radiation therapy.

### Management: Radiation Therapy

Because the pattern of recurrence following surgical excision is more often local in patients with rectal cancer than in those with colon cancer, the potential impact of radiation therapy is greater in patients with rectal cancer than in patients with colon cancer.^27^ Both preoperative and postoperative radiation therapy decrease local failure.^28^–^31^ Patients with stage II or III rectal cancer are at high risk for local and systemic relapse and are thus the best candidates for adjuvant therapy including chemotherapy and/or radiation therapy. However, it is important to follow precise procedures for radiation therapy in order to achieve optimum results.

The role of adjuvant radiation therapy for patients with colon cancer (above the peritoneal reflection) is not well defined and has no current standard role in the management of patients with colon cancer following curative resection.^32^

### Surveillance

Surveillance refers to the ongoing followup of CRC patients after treatment. Colonoscopic surveillance after curative resection of CRC is recommended, but the optimal timing of the surveillance coloscopies after a perioperative “clearing” colonoscopy is yet to be determined. If a preoperative colonoscopy is not possible (e.g., because of an obstructing lesion), it should be performed 6 months after surgery.

Non-endoscopic or combined modality surveillance, such as following tumor markers (carcinoembryonic antigen [CEA]) or abdominal imaging (CT), is controversial. More generally, while there is an overall survival benefit for intensifying the followup of patients after curative surgery for CRC, the optimal combination of clinic visits, laboratory tests and procedures is not currently known.^33^–^35^

## Quality Measures for Patients With Colorectal Cancer

At its most fundamental level, a “quality measure” is something that can be used to measure the quality of care provided to patients. The scope of this definition can be illustrated by example. Consider the following sequence of steps:

In this formulation, structural measures relate to the structural characteristics of providers and hospitals.^36^ Process measures describe the components of the encounter between a physician or another health professional and a patient.^36,37^ Within the category of process measures, technical measures pertain to specific details of a particular test or procedure, whereas general process measures are defined on a broader scale. Outcome measures reflect the net effect of healthcare delivery; that is, they describe what actually happens to the patient.^36,37^

When assessing quality of care, each of the above elements is of potential interest. For example, “volume-outcome” studies describe the relationship between structural characteristics and distal outcomes, recognizing that the more steps that intervene between structure and outcome the less definitive will be the inference. While our scope of work includes both structural characteristics and distal outcomes, our primary interest is in the process measures comprising the middle portion of the above pathway.

To define a process measure, the initial requirement is a statement of what constitutes high-quality clinical care; for example, “adequate bowel preparation” might be operationally defined as “no fecal material obscured a lesion 5 mm in diameter.” This statement might be derived from a clinical guideline that is circulated by a professional society. (Our scope of work does not include assessing the quality of evidence used in generating guidelines, but is limited to recording which quality measures are based on guidelines and which are not). Alternatively, this statement might be based on clinical first principles supported to a greater or lesser degree by formal research findings. All else being equal, guideline-based measures are preferred, one reason being that the guideline provides a standard of care that the user of the quality measure might plausibly anticipate should be followed.

Once this statement of what constitutes high-quality clinical care is generated, the next step is to define the quality measure using a denominator denoting the number of eligible patients and a numerator denoting the number of eligible patients who satisfied the criteria for high-quality clinical care. For example, for the quality measure rate of colonoscopy complications, the denominator is the number of patients undergoing colonoscopy and the numerator is the number of patients undergoing colonoscopy who have at least one complication.

Process measures have been used in both the formal quality improvement context and in more general research settings, the primary difference being that in a quality improvement context various details about the measure tend to be more explicitly specified. For example, some of these details could include the goals of the quality improvement program, the users and uses of the measure, a list of potential data sources along with their advantages and disadvantages, thresholds for action (e.g., take action if the rate of colonoscopy complications exceeds two percent), and so forth. We have defined our scope of work to include both measures that have been used in a formal quality improvement context and measures that have been used in other contexts, the rationale being that many of these latter measures are excellent and could readily be adapted to quality improvement applications. As noted in the next chapter, our methods are general enough to apply not only to process measures that have been used in a quality improvement context, but also to other process measures, structural measures, and outcome measures as well.