# Appendix F: Criteria Used To Assign Ratings to Quality Measures

(1) Assigning the rating for the Importance of a measure:
  We accomplished this in two steps.
  Step 1: We calculated the average of the scores assigned for each of the two criteria, Importance and Usability, for a measure for a given study.
  Step 2: We assigned the highest average score allotted to the measure amongst all the studies that utilized it as the “I” rating for the measure.
(2) Assigning the rating for the Scientific Acceptability of a measure:
  We accomplished this in two steps.
  Step 1: We calculated the average of the scores assigned for each of the five criteria for scientific acceptability (precise specifications, validity, reliability, adaptability, adequacy of risk adjustment) for a measure for a given study.
  Step 2: The highest average score for scientific acceptability, amongst all the studies that utilized it, was assigned as the “S” rating for the measure.
(3) Assigning the rating for the Testing of a measure:
  We accomplished this in a multi-step process. This rating was based on (a) the number of studies that utilized this measure and (b) the extent to which these studies were scientifically acceptable (their “S” rating). Table 1 below summarizes the criteria used to combine the two concepts.

Table 1 Assigning the “T” rating

Considering all the studies utilizing the quality measure, if: | Then the assigned T rating was:
The highest average scientific acceptability score of the measure in all the studies was 1 or 2 | 1
The highest average scientific acceptability score of the measure was 3, and there was only one study with that score | 2
The highest average scientific acceptability score of the measure in two or more studies was 3 | 3
The highest average scientific acceptability score of the measure was 4, and there was only one study with that score | 4
The highest average scientific acceptability score of the measure was 4, and there were two or more studies with that score, OR the highest scientific acceptability score of the measure in at least one study was 5 | 5

In the following example, the quality measure “percentage of patients with stage III colon cancer receiving chemotherapy”, was assigned a hypothetical quality rating of I_5_S_4_T_4_ because of the scores attached to the measure in the two studies that the measure was abstracted from (Table 2):

Table 2 Example of Quality Measure Rating Algorithm^*^

Percentage of patients with stage III colon cancer receiving chemotherapy | important | usable | Importance rating or “I” average | precise specs | reliable | valid | adaptable | risk adjusted | Scientific acceptability or “S” rating average
Study 1 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 1 | 4
Study 2 | 4 | 4 | 4 | 4 | 4 | 3 | 3 | 3 | 3

* The data in this table are for illustrative purposes only and do not reflect actual ratings.

In this example, the overall Importance rating for "percent of patients with stage III colon cancer receiving chemotherapy, or “I” rating, would be a “5” because “5” represents the highest average score for the measure across both studies (studies 1 and 2) involved. The rating for Scientific Acceptability for this measure, or the “S” rating, would be a “4” because, again, this represents the highest average score across both studies involved.

The Testing, or “T” rating, would be a “4” because “4” was the highest average Scientific Acceptability score, and there was only one study that attained a Scientific Acceptability score of “4” (the other study had a Scientific Acceptability rating of “3”).