# Appendix E: Evidence Tables

Evidence Table 1 - Question 1a (Published Literature): What quality-of-care measures are available and what evidence is available for these measures to assess the quality of diagnosis of colorectal cancer, including appropriate use of colon imaging, endoscopic visualization, and biopsy?

Study | Characteristics of Quality Measure | Testing of Quality Measure | | | | | Comments/Quality Scoring
Baig, Myers, Turner, et al., 2003 | Quality measure (QM): Percentage of patients with a positive fecal occult blood test (+FOBT) who under-went a complete diagnostic evaluation (colonoscopy or double contrast barium enema [DCBE]) | Study population: | | | | | General comments:
#33210 | Basis of QM: Clinical practice guideline; not cited, but appears to be Multi-Society Task Force (Winawer et al., Gastroenterology 1997, updated 2003; maybe also U.S. Preventive Services Task Force (Pignone et al., Ann Intern Med ~2002) | HMO patients; primary care practices | | | | | Measure has face validity because follow up of +FOBT with colonoscopy (or DCBE) is supported by practice guidelines, which themselves are supported by large well-designed RCTs with (disease-specific) mortality as the end point.
| Type of QM: | N: 544 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 1
| (a) Process | Age: ≥ 50
| (b) General | Race: NR
| Outcome to which the QM is linked: Mortality in prior trials - no link within this particular paper | Sex: NR
| Intent of QM: Not specified (aim of the study was to determine reasons for non-performance of a complete diagnostic evaluation) | Tumor stage: NA
| Definition of denominator/numerator: | Geographic location: Greater Philadelphia, PA
| Denominator: | Dates: FOBT result, Aug-Nov 1998; follow up at 60 days
| Number of Aetna Health (an HMO in greater Philadelphia, PA) participants aged 50 and older who had a +FOBT from Aug-Nov 1998 | Healthcare setting: HMO primary care practices
| Numerator: | Results:
| Number above subjects who had a colonoscopy or DCBE at 60 days from the +FOBT, as indicated by mailed survey and claims data | Of the 544 +FOBT patients, 46% did not receive colonoscopy or DCBE.
| Data sources: Provider survey, MCO claims data
| Recommended frequency of data collection: No recommendation
Beart, Steele Jr., Menck, et al., 1995 | Quality measure (QM): Percentage of patients with colon (or rectal) cancer undergoing colonoscopy as part of their initial evaluation | Study population: | | | | | General comments:
#990 | Basis of QM: None | N: 39,502 (29,209 colon; 10,293 rectal) | | | | | The data for this study were generated prior to 1990 so it may not reflect more modern recommendations for management.
| Type of QM: | | Colon | | Rectum | | This study reports the frequency of use for a number of diagnostic tests (chest x-ray, colonoscopy, biopsy of primary site, barium enema, preoperative CEA, LFTs, CT scan of primary site or liver, IVP, chest CT, etc.) that were performed for patients with colon and rectal cancer, but it is never stated which ones should have been considered components of quality care. Therefore, it is not possible to determine which are quality measures, and none of these are reported in this abstraction except colonoscopy, which seems to have face validity as a quality measure.
| (a) Process | | 1983 | 1988 | 1983 | 1988 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 2
| (b) General | Cases | 12,682 | 16,527 | 4,597 | 5,696
| Outcome to which the QM is linked: None is specified, but presumably it would be the finding of synchronous lesions that should be dealt with during surgery as well as the primary tumor | < 50 yrs | 5.6 | 5.3 | 6.1 | 6.1
| Intent of QM: Not specified (aim of the study was to identify current trends in the management of patients with carcinoma of the colon or rectum and to identify changes in patterns of care and survival) | 50–69 | 39.4 | 37.4 | 46.1 | 46.0
| Definition of denominator/numerator: | 70–79 | 33.4 | 33.9 | 31.5 | 31.2
| Denominator: | 80+ | 2106 | 23.4 | 16.2 | 16.7
| Number of cases of colon and rectal cancer (up to 25 per program or facility) reported by over 1,200 approved cancer programs and 800 other facilities on the Commission on Cancer mailing list that were invited to participate. | Male % | 47.8 | 49.3 | 55.9 | 57.2
| Numerator: | Tumor Stage
| Number of above cases having colonoscopy as part of their initial evaluation. | 0 | 3.7 | 5.5 | 5.6 | 6.1
| Data sources: Hospitals sent in up to 25 consecutive cases from their medical records | I | 21.2 | 22.9 | 27.4 | 28.3
| Recommended frequency of data collection: No recommendation | II | 29.9 | 28.6 | 22.7 | 21.6
| | III | 22.4 | 22.1 | 21.9 | 22.0
| | IV | 20.1 | 17.7 | 17.0 | 16.7
| | Unkown | 2.7 | 3.3 | 5.4 | 5.4
| | Non-hispanic white | | 86.1 | | 87.0
| | Hispanic | | 2.7 | | 3.5
| | AA | | 9.1 | | 6.5
| | Asian | | 1.1 | | 1.6
| | Performance status: NR
| | Geographic location: Entire U.S.
| | Dates: Calendar years 1983 and 1988
| | Healthcare setting: Hospitals
| | Results:
| | 44% of colon cancer patients in 1983 and 63.8 in 1988 underwent colonoscopy.
| | 30.1% of rectal cancer patients in 1983 and 54.6% in 1988 underwent colonoscopy.
Harewood, Sharma, and de Garmo, 2003 | Quality measure (QM): Percentage of patients with adequate preparation of bowel prior to colonoscopy | Study population: | | | | | General comments:
#33050 | Basis of QM: None | N: 93,004 | | | | | The ability to achieve adequate colonoscopic preparation is predominantly patient-dependent.
| Type of QM: | Age: NR | | | | | This paper also does not exclusively deal with colon cancer and does not discuss the reasons the colonoscopy was performed.
| (a) Process | Race: NR | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 2; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: NA
| (b) Technical | Sex: NR
| Outcome to which the QM is linked: Detection of colonic lesions | Tumor stage: NR; most cases were not colorectal cancer
| Intent of QM: Not specified (aim of the study was to characterize the impact of bowel preparation adequacy on detection of colonic lesions) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: 88 sites in 24 states
| Denominator: | Dates: Jan 1, 2000 to Dec 31, 2001
| Number of colonoscopies performed from January 1, 2000, to December 31, 2001, that were completed and had complete documentation of age, sex, preparation quality, and endoscopic findings. | Healthcare setting: Varied (community, academic, and VA institutions)
| Numerator: | Results:
| Number of above colonoscopies for which bowel preparation was rated as adequate. | 76.9% of colonoscopies with complete data were rated as having an adequate preparation.
| Data sources: Clinical Outcomes Research Initiative (CORI) database, which collects data from endoscopic procedures from a consortium of 580 specialists in GI diseases at 88 sites in 24 states | Regarding the relationship of adequacy of bowel preparation to ability to detect colonic polyps/cancers: Suspected neoplasia was detected in 29.1% of colonoscopies with adequate preparation and 26.4% with inadequate preparation (P < 0.0001).
| Recommended frequency of data collection: No recommendation | Polyps > 9 mm were identified with equal frequency (7.3%) regardless of adequacy of preparation. Polyps ≤ 9mm were identified in 21.8% of colonoscopies with adequate preparation and 19.0% with inadequate preparation (P < 0.0001).
| | After adjusting for age and sex, adequate preparation was predictive of detection of suspected neoplasia.
Haseman, Lemmel, Rahmani, et al., 1997 | Quality measure (QM): Percentage of colon cancers not detected by colonoscopy in symptomatic patients. (Only 7% of the patients in this study had routine screening colonoscopies.) | Study population: | | | | | General comments:
#35910 | Basis of QM: None | N: 941 | | | | | Data for this study were collected from hospitals that “agreed to participate,” which raises concern about whether bias may occur. Only hospitals with low “miss” rates might want to participate; others might not to avoid “bad publicity.”
| Type of QM: | Age: 69.8 | | | | | Cecal intubation rates were not calculated, but would be relevant because failure to reach the cancer is a factor in failed detection.
| (a) Process | Race: NR | | | | | Data on size of tumors were not collected.
| (b) Technical | Sex: NR | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 3
| Outcome to which the QM is linked: Not stated but presumably linked to stage of colon cancer that a patient is ultimately diagnosed with | Tumor stage: Various
| Intent of QM: Not specified, but presumably to help with future quality improvement projects (aim of the study was to understand the reasons for colonoscopic failures to detect colon cancer and polyps) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Hospitals in central Indiana
| Denominator: | Dates: 1988-1993
| Number of cases of colorectal cancer in which colonoscopy was used within 3 years of diagnosis. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of above cases of colon cancer that were missed by the colonoscopy. | Failure to detect colorectal cancer by colonoscopy occurred in 5%. All undetected tumors were “missed” rather than not reached.
| Data sources: Data were collected from 20 hospitals that agreed to participate in this project
| Recommended frequency of data collection: No recommendation
Levin, Hess, and Johnson, 1997 | Quality measure (QM): Number of participants undergoing adequate diagnostic follow up of positive fecal occult blood test (+FOBT) | Study population: | | | | | General comments:
#11880 | Basis of QM: Clinical practice guideline (ACS guidelines [ref 16]) | N: 934 | | | | | The purpose of this paper was to compare three different hemoccult tests for detecting fecal occult blood, but it also obtained information on whether diagnostic followup was obtained.
| Type of QM: | Age: 50–94 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Race: 90% white, 4.8% black, 2.9% Hispanic, 1.4% Asian, < 1% American Indian
| (b) General | Sex: 43.3% male, 56.7% female
| Outcome to which the QM is linked: Detection of colonic neoplasms | Tumor stage: NR
| Intent of QM: Not specified (aim of the study was to compare three FOBTs and assess patient and physician compliance with ACS guidelines on recommended diagnostic workup of participants with a +FOBT) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Houston, TX
| Denominator: | Dates: 4-week period in October 1993
| Number of participants with +FOBT tests for whom followup information was available. | Healthcare setting: Not stated; all were outpatients when participating in the study
| Numerator: | Results:
| Number of above participants undergoing adequate diagnostic follow up (colonoscopy or double-contrast barium enema with flexible sigmoidoscopy) | Rate of adequate diagnostic followup was 59% overall and varied depending on specialty of the physician who was consulted:
| Data sources: Telephone calls to participants; questionnaires sent to physicians | Family physician: 45%
| Recommended frequency of data collection: No recommendation | Other physician: 55%
| | Gastroenterologist: 85%
| | Neoplasia was discovered in 56/553 (10%) participants who received adequate diagnostic follow up regardless of physician type, but in only 4/553 (1%) participants who did not get adequate followup care. This difference was statistically significant (p < 0.001).
Mandel, Church, Bond, et al., 2000 | Quality measure (QM): Percentage of patients who have a followup evaluation of a positive fecal occult blood test (+FOBT) | Study population: | | | | | General comments:
#16070 | Basis of QM: Clinical practice guideline | | Annual Screening | | Biennial Screening | | The purpose of this paper was to present data on the cumulative incidence of colorectal cancer in the individual groups who were screened by annual, biennial, or usual care. It does report the percentage of patients who had follow up of a positive FOBT.
| Type of QM: | Male | 7,474 | | 7,430 | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance:; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 5; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Female | 8,058 | | 8,120
| (b) General | Total | 15,532 | | 15,550
| Outcome to which the QM is linked: Positive diagnosis of colorectal cancer | Average age: 50–80 years old
| Intent of QM: Quality improvement, research | Geographic location: Minnesota
| Definition of denominator/numerator: | Dates: 1976-1992
| Denominator: | Healthcare setting: Randomized trial
| Number of patients with a +FOBT. | Results:
| Numerator: | 83% of patients in the annual-screening group and 84% of patients in the biennial-screening group underwent diagnostic followup, including a complete examination of the large bowel by colonoscopy or the combination of double-contrast enema and flexible sigmoidoscopy. In each group about 11% of the subjects with positive screening tests underwent flexible sigmoidoscopy or barium enema or underwent another FOBT. Five percent of the subjects with positive tests declined to consult a physician.
| Number of above patients who had appropriate diagnostic evaluation.
| Data sources: Database of the Minnesota Colon Cancer Control study
| Recommended frequency of data collection: No recommendation
Marble, Banerjee, and Greenwald, 1992 | Quality measure (QM): Time from patient presentation to physician diagnosis | Study population: | | | | | General comments:
#4910 | Basis of QM: None | N: 50/50 | | | | | A small study of limited use in quality measurement.
| Type of QM: | Age: ≤ 40/ > 40 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 3; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 1; - Validity: 1; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Race: 94% white/98% white
| (b) General | Sex: 58% female/52% female
| Outcome to which the QM is linked: More rapid diagnosis presumed to be linked to earlier stage at diagnosis and hence improved cure rates. (Unlikely that there are data to support this idea over the typical range of time between presentation and diagnosis.) | Tumor stage: NR
| Intent of QM: Not specified (aim of the study was to determine whether younger patients with colorectal cancer had a poorer prognosis than their older counterparts, and if they did, the reasons underlying this) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Hartford, CT
| Denominator: | Dates: 1935-1988
| Numerator: | Healthcare setting: Hospital
| Data sources: Saint Francis Hospital and Medical Center Tumor Registry | Results:
| Recommended frequency of data collection: No recommendation | There was no difference in the interval from presentation to diagnosis in older vs. younger patients (the appropriate diagnosis was made in < 1 week in > 90% of the patients in both groups).
Myers, Turner, Weinberg, et al., 2004 | Quality measure (QM): Percentage of patients receiving complete diagnostic evaluation (CDE) for positive fecal occult blood test (+FOBT), defined as colonoscopy or barium enema + flexible sigmoidoscopy (BEFS) | Study population: | | | | | General comments: None
#30300 | Basis of QM: Clinical practice guideline (Winawer et al., Gastroenterology, 2003) | N: 2,992 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 1
| Type of QM: | Age: ≥ 50
| (a) Process | Geographic location: Southern PA and NJ
| (b) General | Dates: 1994-2000, 3 study periods
| Outcome to which the QM is linked: Reduced colorectal cancer-related mortality | Healthcare setting: Aetna U.S. Healthcare and various MCO-based cancer screening sites
| Intent of QM: Not specified (aim of the study was to evaluate the impact of a guideline on CDE performance rates in primary care practices) | Results:
| Definition of denominator/numerator: | | Intervention group | | Control group
| Denominator: | CDE recommendation rate | 79.6 | | 67.3
| Number of +FOBT patients eligible for CDE recommendation and performance. Exclusion criteria: CDE procedures completed within 3 years prior to +FOBT result; patient had a medical condition that contraindicated CDE; patient deceased; patient unknown to practice and patient left practice before CDE could be recommended. | CDE performance rate | 63.3 | | 53.7
| Numerator: | For study period 3 (5/99 to 2/00), the differences in CDE recommendation and performance rates between the intervention group and control group was statistically significant. Use of a physician-oriented intervention substantially and significantly increased CDE recommendation and performance in intervention group practice as compared to control group practices. Targeting PCPs for delivery of a combined CDE reminder feedback and educational outreach intervention can have a meaningful impact on physician behavior and patient followup in colorectal cancer screening.
| Number of above patients whose physicians had recommended CDE; number of patients who underwent CDE within 180 days after the +FOBT result. Results were coded as dichotomous variables, yes or no (recommendation was made or treatment was provided).
| Data sources: ICA forms; MCO administrative claims data
| Recommended frequency of data collection: No recommendation
Nelson, McQuaid, Bond, et al., 2002 | Quality measure (QM): Postprocedural complication rate | Study population: n = 3,196 | | | | | General comments: None
#45970 | Basis of QM: Not specified | Mean age | | | 63.0 | | Rating of quality measure as presented in this study(scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 3; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 4
| Type of QM: | % male | | | 96.8
| (a) Outcome | % white | | | 83.5
| (b) Technical | Comorbidities:
| Intent of QM: Not specified (aim of the study was to report and identify predictive variable for procedural success and complication rates of screening colonoscopy in a large asymptomatic cohort) | Coronary heart disease | | | 21.1%
| Definition of denominator/numerator: | CVA/TIA | | | 8.2%
| Denominator: | Diabetes | | | 20.8%
| Number of asymptomatic patients between 50 and 75 years undergoing a screening colonoscopy at 13 VAMCs between 2/1994-1/1997. | COPD | | | 8.5%
| Exclusion criteria: Patients were excluded if they reported symptoms of lower GI tract disease, including rectal bleeding on more than one occasion in the prior 6 months, significant change in bowel habits or lower abdominal pain that would require evaluation. Also excluded were those with prior colonic disease; prior colon examination within 10 years; significant medical problems that would increase risk of colonoscopy, or a medical condition that would preclude benefit from screening; need for special precautions for colonoscopy; women with childbearing potential. | Geographic location: 13 VAMCs across U.S.
| Numerator: | Dates: 1994-1997
| Number of above cases where postprocedural complications within 30 days occurred, including perforation, GI bleeding with hospitalization, new arrhythmia, MI/CVA, death within 30 days. | Healthcare setting: General medicine clinics
| Data sources: Medical chart | Results:
| Recommended frequency of data collection: No recommendation | No statistically significant complications occurred.
Nelson, McQuaid, Bond, et al., 2002 | Quality measure (QM): Percent of patients with “adequate” or better bowel preparation | Study population: n = 3,196 | | | | | General comments: None
#45970 | Basis of QM: Not specified | Mean age | | | 63.0 | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 3; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 4
| Type of QM: | % male | | | 96.8
| (a) Outcome | % white | | | 83.5
| (b) Technical | Comorbidities:
| Outcome to which the QM is linked: | Coronary heart disease | | | 21.1%
| Intent of QM: Not specified (aim of the study was to report and identify predictive variable for procedural success and complication rates of screening colonoscopy in a large asymptomatic cohort) | CVA/TIA | | | 8.2%
| Definition of denominator/numerator: | Diabetes | | | 20.8%
| Denominator: | COPD | | | 8.5%
| Number of asymptomatic patients between 50 and 75 years undergoing a screening colonoscopy at 13 VAMCs between 2/1994-1/1997. | Geographic location: 13 VAMCs across U.S.
| Exclusion criteria: Patients were excluded if they reported symptoms of lower GI tract disease, including rectal bleeding on more than one occasion in the prior 6 months, significant change in bowel habits or lower abdominal pain that would require evaluation. Also excluded were those with prior colonic disease; prior colon examination within 10 years; significant medical problems that would increase risk of colonoscopy, or a medical condition that would preclude benefit from screening; need for special precautions for colonoscopy; women with childbearing potential. | Dates: 1994-1997
| Numerator: | Healthcare setting: General medicine clinics
| Number of above cases where bowel preparation was rated by the endoscopist as “good” (mucosa well seen throughout), “fair” (liquid, contents; exam adequate); or ”poor” (solid contents, exam compromised). | Results:
| Data sources: Medical chart | By using a polyethylene glycol-based electrolyte solution, the bowel preparation was described as good in 81.4%, fair in 15.8% and poor in 2.7% of patients.
| Recommended frequency of data collection: No recommendation.
Nelson, McQuaid, Bond, et al., 2002 | Quality measure (QM): Percent of patients with a colonoscopy with successful cecal intubation | Study population: n = 3,196 | | | | | General comments: None
#45970 | Basis of QM: Not specified | Mean age | | | 63.0 | | Rating of quality measure as presented in this study(scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 3; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 4; - Validity: 4; - Adaptability:; - Adequacy of risk adjustment: 4
| Type of QM: | % male | | | 96.8
| (a) Process | % white | | | 83.5
| (b) Technical | Comorbidities:
| Outcome to which the QM is linked: | Coronary heart disease | | | 21.1%
| Intent of QM: Not specified (aim of the study was to report and identify predictive variable for procedural success and complication rates of screening colonoscopy in a large asymptomatic cohort) | CVA/TIA | | | 8.2%
| Definition of denominator/numerator: | Diabetes | | | 20.8%
| Denominator: | COPD | | | 8.5%
| Number of asymptomatic patients between 50 and 75 years undergoing a screening colonoscopy at 13 VAMCs between 2/1994-1/1997. | Geographic location: 13 VAMCs across U.S.
| Exclusion criteria: Patients were excluded if they reported symptoms of lower GI tract disease, including rectal bleeding on more than one occasion in the prior 6 months, significant change in bowel habits or lower abdominal pain that would require evaluation. Also excluded were those with prior colonic disease; prior colon examination within 10 years; significant medical problems that would increase risk of colonoscopy, or a medical condition that would preclude benefit from screening; need for special precautions for colonoscopy; women with childbearing potential. | Dates: 1994-1997
| Numerator: | Healthcare setting: General medicine clinics
| Number of above cases where colonoscopy with procedure was successful; that is, confirmation of cecal intubation. | Results:
| Data sources: Medical chart | Colonoscopy with cecal intubation was successful on the first attempt in 97.2% of the cases. This includes 69 cases in which the quality of the preparation was felt to be inadequate to visualize the entire colonic mucosa. 53.8% of these cases had at lest 1 polyp resected.
| Recommended frequency of data collection: No recommendation.
Shehadeh, Rebala, Kumar, et al., 2002 | Quality measure (QM): Miss rate for followup colonoscopy after polypectomy | Study population: | | | | | General comments:
#18520 | Basis of QM: None | N: 122 | | | | | Because fellows in training performed most of the colonoscopies (albeit with gastroenterologist supervision), the results may not be reflective of routine clinical practice.
| Type of QM: | Age: NR | | | | | Miss rates could be used for internal quality improvement purposes (as was done in this case).
| (a) Process | Race: NR | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 3; - Validity: 5; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (b) Technical | Sex: 100% male
| Outcome to which the QM is linked: Presumably, improved survival via earlier detection of malignancy | Tumor stage: NA
| Intent of QM: Not specified (aim of the study was to evalute the miss rates of advanced adenomas) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Dayton, Ohio
| Denominator: | Dates: 1992-1999
| Number of patients who had polypectomy on initial colonoscopy and who had at least one followup colonoscopy from July 1, 1992 to June 30, 1999 at the Dayton VAMC. Colonoscopy had to be complete and bowel prep had to be satisfactory. | Healthcare setting: Veteran's Affairs Medical Center (VAMC)
| Numerator: | Results:
| Number of patients with missed advanced adenomas (≥10 mm) found on repeat colonoscopy. | 122 patients had 338 colonoscopies. Miss rates were calculated as in the National Polyp Study. Missed adenomas were defined as adenomas (especially big ones) found on repeat colonoscopy. 122 patients had 2 colonoscopies and 60 patients had a third colonoscopy.
| Data sources: Computerized database and paper charts at VAMC | The calculated miss rate of advanced adenomas for the second colonoscopy was 2.5% (4/122); for the third colonoscopy, it was 3.3 %(2/60).
| Recommended frequency of data collection: No recommendation
Shields, Weiner, Henry, et al., 2001 | Quality measure (QM): Percentage of patients aged 40 or older participating in a mass screening program who had an “adequate evaluation” (colonoscopy or barium enema + flexible sigmoidoscopy [BEFS]) for a positive fecal occult blood test (+FOBT; Hemeoccult II) | Study population: N: 940 | | | | | General comments: None
#23040 | Basis of QM: Clinical practice guideline (American Cancer Society [ref 14, 15 1980 CA, 1996 JAMA]) | | | | percent | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 1
| Type of QM: | 40–49 yrs | | | 11
| (a) Process | 50–59 yrs | | | 18
| (b) General | 60–69 yrs | | | 37
| Outcome to which the QM is linked: Reduced mortality from colorectal cancer | 70–79 yrs | | | 28
| Intent of QM: Not specified (aim of the study was to determine whether factors like age, sex, and family history [among others] influence adequate evaluation of a +FOBT) | 80+ yrs | | | 6
| Definition of denominator/numerator: | male | | | 48
| Denominator: | female | | | 47
| Number of patients who participated in a 1986 mass screening program with FOBT (pharmacy-based, processed at Beth Israel Hospital (Boston MA), who returned their cards, had at least 1 positive window (out of 6) and who provided (or their physician provided) followup data (90%). | unspecified | | | 5
| Numerator: | Race: NR
| Number of the above subjects who in addition had an “adequate evaluation” (colonoscopy or barium enema + flexible sigmoidoscopy [BEFS]) | Geographic location: Boston area, MA
| Data sources: Physician survey “checklist,” patient or physician phone call (if survey/checklist not returned), pathology reports, patient survey at 3 years | Dates: 1986-1988
| Recommended frequency of data collection: No recommendation | Healthcare setting: Variety
| | Results:
| | 59% of patients with a +FOBT were adequately evaluated. 11.2% of adequately evaluated patients had new colon cancers discovered.
| | The effects of age and sex on the adequacy of follow up were considered, but no significant differences were found by age group or between men and women.
Ure, Dehghan, Vernava 3 ^ rd ^ , et al., 1995 | Quality measure (QM): Complication rate of colonoscopy in the elderly and non-elderly | Study population: | | | | | General comments:
#960 | Basis of QM: None | Eldlerly/Non-elderly | | | | | This paper reports the rate of the following quality measures of the performance of colonoscopy: colonoscopy completion, rate of perforations, and postpolypectomy bleeding, but some patients were undergoing colonoscopy for screening (16%).
| Type of QM: | N: 354/302 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 5; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Outcome | Age: ≥ 70 / 50–70
| (b) Technical | Race: NR
| Intent of QM: Not specified (aim of the study was to evaluate the utility, morbidity, and patient tolerance of colonoscopy in elderly patients as compared to a similar group of younger patients) | Sex: NR
| Definition of denominator/numerator: | Tumor stage: NA
| Denominator: | Performance status: NR
| Number of elderly/non-elderly patients undergoing colonoscopy. | Geographic location: St. Louis area
| Numerator: | Dates: “A recent 48-month period”
| Number of the above patients with resulting complications. | Healthcare setting: University Hospital
| Data sources: Not specified | Results:
| Recommended frequency of data collection: No recommendation | Overall morbidity was similar in elderly and non-elderly patients (24% vs. 16%, p = NS). Elderly patients were significantly more likely to require termination of the procedure because of inadequate bowel preparation or pain (17% vs. 1%, p < 0.05).
| | Colonoscopy was successful to the cecum or ileocolic anastomosis in 85% (555/656). No patient had a perforation; 2% postprocedure hemorrhage in those undergoing polypectomy.

Evidence Table 2 - Question 1a (Grey Literature):What quality-of-care measures are available and what evidence is available for these measures to assess the quality of diagnosis of colorectal cancer, including appropriate use of colon imaging, endoscopic visualization, and biopsy?

Study | Characteristics of Quality Measure | Comments/Quality Scoring
Colon Cancer Workgroup, 2003 | Quality measure (QM): Colonoscopy to the ileocecal valve is performed prior to surgical resection of colorectal cancer | General comments:It should be noted that colonoscopy will not be performed prior to surgery for cases of obstructing or perforated carcinoma.
#36650 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Type of QM:
| (a) Process
| (b) Technical
| Outcome to which the QM is linked: Better surgical outcome
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients having colon cancer surgery.
| Numerator:
| Number of above patients with documentation of colonoscopy of the entire colon to the ileocecal valve before surgery except in cases of obstructing carcinoma or perforation.
| Data sources: Medical records (operative report, history and physical, or other preoperative testing documentation)
| Recommended frequency of data collection: No recommendation
Minnesota Gastro-enterology PA, 2004 | Quality measure (QM): Percentage of colonoscopy cases performed by physicians completing residency/fellowship training in gastroenterology, colorectal surgery, general surgery or pediatric surgery | General comments: None
#36590 | Basis of QM: Practice guideline (ASGE recommendation) | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Type of QM:
| (a) Structure
| (b) General
| Outcome to which the QM is linked: Improved health status
| Intent of QM: Quality improvement, accountability
| Definition of denominator/numerator:
| Denominator:
| Number of patients undergoing endoscopy.
| Numerator:
| Number of above patients undergoing endoscopy by a physician having completed residency or fellowship training in gastroenterology, colorectal surgery, general surgery or pediatric surgery and who have specific proctored training in endoscopy.
| Reference (Feb 2002, ASGE Policy and Procedure Manual)
| Data sources: Physician credentials, endoscopy notes
| Recommended frequency of data collection: No recommendation
| Quality measure (QM): Unplanned reversal of sedation medication
| Basis of QM: Internal quality assurance committee
| Type of QM:
| (a) Process
| (b) Technical
| Outcome to which the QM is linked: Survival
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of endoscopies performed.
| Numerator:
| Number of above cases where sedation medication was reversed.
| Data sources: Medical chart
| Recommended frequency of data collection: Continually
| Quality measure (QM): Postendoscopic procedure complication rates
| Basis of QM: Internal quality assurance committee
| Type of QM
| (a) Outcome
| (b) Technical
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of endoscopies performed.
| Numerator:
| Number of above cases where postendoscopic procedure complications occurred, including death within 30 days, perforation, bleeding with transfusion, cardiopulmonary arrest, unplanned surgery.
| Data sources: Medical chart
| Recommended frequency of data collection: Continually
| Quality measure (QM): Effectiveness of bowel prep prior to colonoscopy
| Basis of QM: Internal quality assurance committee
| Type of QM:
| (a) Process
| (b) General
| Outcome to which the QM is linked: High-quality exam
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of endoscopies performed.
| Numerator:
| Number of above cases where no fecal material obscured a lesion 5 mm or more in diameter and a high quality exam takes place.
| Data sources: Electronic chart
| Recommended frequency of data collection: Continually
| Quality measure (QM): Percent of examinations complete to the end of colon (cecal intubation rate)
| Basis of QM: Internal quality assurance committee (goal is less than > 90 percent)
| Type of QM:
| (a) Process
| (b) Technical
| Outcome to which the QM is linked: Improved health outcomes
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of endoscopies performed,
| Numerator:
| Number of above cases where end of colon was reached.
| Data sources: Medical chart
| Recommended frequency of data collection: Continually
| Quality measure (QM): Rate of adenomas removed for patients > 50 years of age
| Basis of QM: Clinical practice guideline (Multi-Society Task Force on Colon Cancer); goal: men > 50, 25%; women > 50, 15%
| Type of QM:
| (a) Process
| (b) Technical
| Outcome to which the QM is linked: Survival
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of endoscopies performed.
| Numerator:
| Number of above cases where one or more adenomas (polyps > 1 cm or with advanced histology) were removed.
| Data sources: Medical chart
| Recommended frequency of data collection: Continually
| Quality measure (QM): Acceptable cycle time for colonoscopic examination
| Basis of QM: No national, internal goals
| Type of QM:
| (a) Process
| (b) General
| Outcome to which the QM is linked: Quality improvement
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of endoscopies performed.
| Numerator:
| Number of above cases where exam was completed in a timely fashion acceptable to patient and referring physician according to internal practice standards.
| Data sources: Medical chart
| Recommended frequency of data collection: Continually
National Quality Measures Clearinghouse (measure proposed by Accreditation Association for Ambulatory Health Care Institute for Quality Improvement), 2003 | Quality measure (QM): Intraprocedure colonoscopy complication rate (percentage of patients who developed one or more intraprocedure complications) | General comments: Patients could be undergoing colonoscopy for screening or postoperative surveillance.
#36640 | Basis of QM: None | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Type of QM:
| (a) Outcome
| (b) Technical
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients undergoing colonoscopy procedure (CPT codes 45378–45385) at the ambulatory health care organization.
| Numerator:
| Number of above patients who developed one or more intraprocedure complications (including arrhythmia, bleeding requiring treatment, extended recovery, hospital transfer, hypotension, hypoxia, noted perforations, respiratory arrest).
| Data sources: Patient survey
| Recommended frequency of data collection: No recommendation
| Quality measure (QM): Patient understanding of colonoscopy procedure (percentage of patients answering “yes” to the postprocedure telephone interview question, “Did you have an adequate understanding of your procedure?”)
| Basis of QM: None
| Type of QM:
| (a) Outcome
| (b) General
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients undergoing colonoscopy procedure (CPT codes 45378–45385) at the ambulatory health care organization who were reached for the telephone survey and who responded to the question “Did you have an adequate understanding of your procedure?”
| Numerator:
| Number of above patients answering “yes” to the postprocedure telephone interview question “Did you have an adequate understanding of your procedure?”
| Data sources: Patient survey
| Recommended frequency of data collection: No recommendation

Evidence Table 3 - Question 1b (Published Literature): What quality-of-care measures are available and what evidence is available for these measures to assess the quality of diagnosis of colorectal cancer, including availability and accuracy of pathologic staging?

Study | Characteristics of Quality Measure | Testing of Quality Measure | | | | | Comments/Quality Scoring
Baxter, Virnig, Rothenberger, et al., 2005 | Quality measure (QM): Adequate lymph node evaluation | Study population: | | | | | General comments: None
#35800 | Basis of QM: Clinical practice guideline (American Joint Committee on Cancer, International Union against Cancer) | N: 116,995 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 3
| Type of QM: | | | Anatomic site of tumor
| (a) Process | Characteristics | All pts (N = 116,995) | Right colon (49,613) | Left colon (50,536) | Rectum (16,846)
| (b) General | Median age (yr) | 71 | 74 | 69 | 68
| Outcome to which the QM is linked: Recurrence | Males | 50% | 44% | 53% | 58%
| Intent of QM: Not specified (aim of the study was to determine the proportion of colorectal cancer patients in the U.S. who receive adequate lymph node evaluation) | Race/ ethnicity
| Definition of denominator/numerator: | White | 83% | 84% | 82% | 84%
| Denominator: | Non-white | 17% | 16% | 18% | 16%
| Number of patients ≥ 18 yr, diagnosed with localized invasive adenocarcinoma of colon or rectum from Jan 1988-Dec 2001. | Tumor stage
| Exclusion criteria: Patients with cancer colon not otherwise localized, patients who underwent radical surgical resection, and postoperative radiation. | Stage I | 25% | 19.50% | 27% | 33%
| Numerator: | Stage II | 40% | 45.50% | 39% | 29%
| Number of above patients with adequate lymph node evaluation (adequate = at least 12 nodes examined) | Stage III | 35% | 35% | 34% | 38%
| Data sources: NCI's SEER registry | Tumor Grade
| Recommended frequency of data collection: No recommendation | Well or mod diff. | 82% | 76% | 87% | 83%
| | Poorly diff. | 18% | 24% | 13% | 17%
| | Node No. (Median) | 9 | 11 | 7 | 8
| | Geographic location: U.S.
| | Dates: Jan 1988-Dec 2001
| | Healthcare setting: Multiple
| | Results:
| | No lymph nodes were examined in 6.5% patients.
| | Characteristic | % of all pts | Rates among pts with stage I disease (N = 27,323) | Rates among pts with stage II disease (N = 44,771) | Rates among pts with stage III disease (N = 38,660)
| | Overall rates | 37% | 25% | 41% | 46%
| | Patient age (yr)
| | ≤ 50 | 51% | 35% | 56% | 57%
| | 51–60 | 40% | 27% | 46% | 48%
| | 61–70 | 36% | 23% | 41% | 45%
| | ≥ 71 | 35% | 25% | 37% | 43%
| | Year of diagnosis
| | 1988-90 | 33% | 22% | 37% | 40%
| | 1991-3 | 35% | 23% | 38% | 44%
| | 1994-6 | 36% | 24% | 40% | 45%
| | 1997-9 | 40% | 26% | 43% | 49%
| | 2000-1 | 43% | 31% | 45% | 52%
Chiaverini, Fulton, and Darcy, 2002 | Quality measure (QM): Percentage of newly diagnosed CRC cases that were staged using the AJCC system | Study population: | | | | | General comments: None
#17720 | Basis of QM: Clinical practice guideline (implicit that AJCC staging system would follow the American Joint Committee on Cancer guidelines but these are not actually cited in the article. The authors do mention the rules and regulations of the Rhode Island Cancer Registry and the Rhode Island Cancer Control Plan [ref 4]). | N: NR | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 4
| Type of QM: | Age: NR
| (a) Structure | Race: NR
| (b) Process and technical | Sex: NR
| Outcome to which the QM is linked: No outcome linked, but measure is said to be important for choosing appropriate treatments | Tumor stage: NR
| Intent of QM: NA (aim of the study was to describe progress in the control of colorectal cancer in Rhode Island, 1987-2000) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Rhode Island
| Denominator: | Dates: 1989-2000
| Number of Rhode Island men and women newly diagnosed with colorectal cancer in 1989-1999 compared to 2000. | Healthcare setting: Multiple
| Numerator: | Results:
| Number of above patients who were staged using the AJCC system. | The proportion of cases staged with AJCC staging methodology increased from 65% in 1989 to 92% in 2000 for men, and from 65% in 1989 to 90% in 2000 for women.
| Data sources: Rhode Island Cancer Registry
| Recommended frequency of data collection: No recommendation
Galvis, Raab, D'Amico, et al., 2001 | Quality measure (QM): Lymph node retrieval rate | Study population: | | | | | General comments: None
#20330 | Basis of QM: None (but see refs 1–10) | N: 176 specimens | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 1; - Reliability: 2; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 3
| Type of QM | Geographic location: PA
| (a) Process | Dates: Dec 1997-Nov 1999
| (b) Technical | Healthcare setting: University hospital
| Outcome to which the QM is linked: Recurrence | Results:
| Intent of QM: Not specified (aim of the study was to measure the quality of pathologists' assistants' surgical gross examination [vs. that of pathology residents]) | Examiner | Total number of cases | Mean # of lymph nodes
| Definition of denominator/numerator: | | | Retrieved per specimen | Positive per specimen
| Denominator: | Pathologist's assistant | 50 | 31.3 | 1.1
| Number of colorectal specimens submitted for tumor from Dec 1997-Nov 1999 (all cases for which 5 or more cassettes of tissue were initially submitted for histologic examination). | Pathology resident | 126 | 18.7 | 2.2
| Numerator:
| Number of positive lymph nodes retrieved from above specimens.
| Data sources: Retrospective review of surgical pathology reports
| Recommended frequency of data collection: No recommendation
Steele, 1994, | Quality measure: Percentage of newly diagnosed CRC cases who were staged using the AJCC system | Study population: | | | | | General comments: None
#35840 | Basis of QM: Clinical practice guideline (implicit that the AHCC guidelines be followed but these are not actually cited) | | Colon | | Rectal | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 3; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| Type of QM: | | 1985-86 | 1991 | 1985-86 | 1991
| (a) Process | cases | 40384 | 39751 | 18418 | 17348
| (b) Technical | Age
| Outcome to which the QM is linked: No outcome is exactly linked to the above but is said to be a marker of appropriate cancer diagnosis and treatment. No citation is provided for this statement. | ≤54 | 10.6 | 11.2 | 13.5 | 14.8
| Intent of QM: Not specified (aim of the study was to assess cancer patient care and outcomes on a national basis) | 55–64 | 19.8 | 17.2 | 23.8 | 21.6
| Definition of denominator/numerator: | 65–74 | 32.3 | 21.9 | 33.9 | 32.9
| Denominator: | ≥75 | 37.3 | 39.7 | 28.8 | 30.7
| Number of patients in the National Cancer Data Base (NCDB) with a new diagnosis of colon cancer or rectal cancer (rectosigmoid junction, rectum and anal canal) in the years 1985-1986 or 1991. | %male | 48.7 | 49.6 | 55.3 | 55.7
| Numerator: | race
| Number of the above patients who were staged using the AJCC system. | White | 86.9 | 85.9 | 88.0 | 86.9
| Data sources: National Cancer Data Base (NCDB) | hispanic | 1.1 | 1.8 | 1.6 | 2.3
| Recommended frequency of data collection: No recommendation | AA | 6.6 | 8.1 | 4.7 | 6.3
| | Asian | 0.9 | 1.5 | 1.2 | 2.2
| | Unk. | 4.5 | 2.7 | 4.5 | 2.3
| | Tumor Stage
| | 0 | 3.7 | 6.5 | 5.8 | 5.0
| | 1 | 14.4 | 19.3 | 15.2 | 18.6
| | 2 | 13.8 | 26.2 | 10.5 | 17.4
| | 3 | 12.9 | 20.3 | 12.2 | 20.0
| | 4 | 9.2 | 15.8 | 5.0 | 7.8
| | Unk. | 46.0 | 11.9 | 51.3 | 31.2
| | Geographic location: National sample; note that the sample is not probabilistic and represented different hospitals in different years
| | Dates: 1991 and outcomes for 1985-86
| | Healthcare setting: 464 hospital in 1985, 474 hospitals in 1986, 937 hospitals in 1991
| | Results: The percent of cases reported as having an “unknown stage” decreased from 46% to 11.9% and 51.3% to 31.2% for colon and rectal cancer cases respectively, between 1985-86 and 1991.

Evidence Table 4 - Question 1b (Grey Literature): What quality-of-care measures are available and what evidence is available for these measures to assess the quality of diagnosis of colorectal cancer, including availability and accuracy of pathologic staging?

Study | Characteristics of Quality Measure | Comments/Quality Scoring
Colon Cancer Workgroup, 2003 | Quality measure (QM): Surgical resection includes at least 8 lymph nodes | General comments:
#36650 | Basis of QM: Clinical practice guideline (CAP, National Comprehensive Cancer Network [NCCN] guidelines, NCI guidelines) | Measure notes that some patients would have fewer than 8 lymph nodes.
| Type of QM: | Measure mentions only “surgical resection,” but the entire description implies that “number of lymph nodes positive” is important for staging, and that pathology data are important for staging.
| (a) Process | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (b) Technical | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Outcome to which the QM is linked: Improved staging and subsequent treatment planning
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients having colon cancer surgery.
| Numerator:
| Number of above patients in whom 8 or more lymph nodes were resected.
| Data sources: Pathology, surgery reports
| Recommended frequency of data collection: No recommendation
Institute of Medicine, 2005 | Quality measure (QM): Appropriate histological assessment of colorectal cancer | General comments:
#36680 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Numerous studies reveal that surgical and pathology reporting practices are of variable quality. Information on margins and the number and status of nodes is often missing.
| NCCN recommends that a minimum of 14 regional lymph nodes be removed during surgical resection. CAP recommends removal of at least 12 nodes and urges that additional techniques (i.e., visual enhancement) be considered if fewer than 12 nodes are found. | Key references cited:
| Type of QM: | Compton (CAP), 2004
| (a) Process | Compton, 2003
| (b) General | LeVoyer et al., 2003
| Outcome to which the QM is linked: Staging | NCCN, 2004
| Intent of QM: Quality improvement | Stocchi et al., 2001
| Definition of denominator/numerator: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Denominator: | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Number of colorectal cancer surgery patients.
| Numerator:
| Number of above patients with a surgical resection that included at least 12 lymph nodes.
| Data sources: Surveillance, Epidemiology and End results Program (SEER)- GCCR, baseline studies of pathology reports and medical records
| Recommended frequency of data collection: No recommendation
National Committee for Quality Assurance, 2005 | Quality measure (QM): Percent of colon cancer patients receiving surgical treatment that had at least 14 lymph nodes examined | General comments:
#36580 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Not all data may be available.
| Type of QM: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| (b) Technical
| Outcome to which the QM is linked: Improved health status
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients with colon cancer surgery over a 12-month period.
| Numerator:
| Number of above patients who had 14 or more lymph nodes examined at the time of surgery.
| Data sources: Cancer registry, claims data
| Recommended frequency of data collection: No recommendation

Evidence Table 5 - Question 2b (Published Literature): As appropriate to specific stages of colorectal cancer, what quality-of-care measures are available and what evidence is available for measures of quality of care of treatment of colorectal cancer, including surgical therapy for colon and rectal cancers?

Study | Characteristics of Quality Measure | Testing of Quality Measure | | | | | Comments/Quality Scoring
Agarwal, Leighton, Mandile, et al., 1990 | Quality measure (QM): 30-day operative mortality rate | Study population: | | | | | General comments: None
#7530 | Basis of QM: None | N: 271 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 3
| Type of QM: | | 30-day mortality n = 29 (%) | P value
| (a) Outcome | Age | | < 0.001
| (b) General | < 80 | 6
| Intent of QM: Quality improvement (aim of the study was to determine the relationship between age and 5-year survival, taking into consideration the site, stage, and type of surgical treatment rendered) | ≥ 80 | 25
| Definition of denominator/numerator: | Tumor stage | | < 0.05
| Denominator: | I | 5
| Number of patients treated for colorectal cancer during 1975-1980 with histologically confirmed adenocarcinoma. | II | 8
| Exclusion criteria: Carcinoma in situ. | III | 4
| Numerator: | IV | 19
| Number of above patients who died within 30 days following operation. | Treatment | | < 0.01
| Data sources: Tumor registry | Colectomy | 9
| Recommended frequency of data collection: No recommendation | Low anterior | 2
| | Abdominoperineal | 0
| | Colostomy | 24
| | Miscellaneious | 23
| | Geographic location: New York
| | Dates: 1975-1980
| | Healthcare setting: Medical center
| | Results:
| | 30-day mortality was related significantly to stage and treatment but not to site of cancer. An increased proportion of patients who had stage IV cancers or who received colostomy and miscellaneous treatment died within 1 month. Patients ≥ 80 yr had a significantly higher 30-day mortality compared with patients < 80 yr (p < 0.0010).
Coburn, Pricolo, and Soderbert, 1994 | Quality measure (QM): Anastomotic leak rate | Study population: | | | | | General comments:
#2920 | Basis of QM: None | N: 800 | | | | | Data collected between 1961 and 1987.
| Type of QM: | | < 80 yr | > 80 yr | | | Other factors that affect mortality rates in the elderly include: more aggressive biologic behavior of cancer of the colon and rectum in the elderly, with aggressive local disease and less tendency towards distant dissemination, greater tendency of cancer of the colon to be right-sided, rarity of adjuvant therapy administered to older patients, higher complication rate in elderly patients due to comorbid conditions and greater frequency of obstructing and perforated lesions.
| (a) Outcome | N | 177 | 623 | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 2
| (b) Technical | Sex (%F/M) | 48/52 | 56/44
| Intent of QM: Not specified (aim of the study was to perform univariate and multivariate analyses of poor indicators in the elderly undergoing colorectal operation, and to compare clinical, pathologic, and therapeutic factors in patients younger than and older than 80 years of age) | Rectal lesions | 36 | 23
| Definition of denominator/numerator: | Duke stage
| Denominator: | A | 9.0 | 6.0
| Number of subjects who had received operative treatment for colon and rectal cancer between 1961 and 1987. | B1 | 16.7 | 12.8
| Numerator: | B2 | 31.2 | 42.7
| Number of above subjects that had an anastomotic leak after surgery (within a unspecified period). | C1 | 4.5 | 0
| Comparisons were made between patients under and over 80 years. | C2 | 21.5 | 21.8
| Data sources: Inpatient, outpatient, and office records | D | 17.1 | 16.7
| Recommended frequency of data collection: No recommendation | Geographic location: Rhode Island, U.S.
| | Dates: 1961 and 1987
| | Healthcare setting: Academic institute
| | Results:
| | Postanastomotic leak rate was 6% for patients > 80 yr and 3% for patients < 80 yr.
| | Long-term survival (at 5 and 8 yrs) and rate of recurrence after curative therapy used to validate the measure.
| | There was a statistically significant difference in survival rates: 48% for patients < 80 vs. 32% for patients > 80.
| | There was no statistically significant difference between the groups with regard to recurrence after curative therapy.
| Quality measure (QM): 30-day mortality | Study population:
| Basis of QM: None | N: 800
| Type of QM: | | < 80 yr | > 80 yr
| (a) Outcome | N | 177 | 623
| (b) General | Sex (%F/M) | 48/52 | 56/44
| Outcome to which the QM is linked: Mortality | Obstruction/Perforation | 12 | 22
| Intent of QM: Not specified (aim of the study was to perform univariate and multivariate analyses of poor indicators in the elderly undergoing colorectal operation, and to compare clinical, pathologic, and therapeutic factors in patients younger than and older than 80 years of age) | Normal CEA at diagnosis | 77 | 68
| Definition of denominator/numerator: | Rectal lesions | 36 | 23
| Denominator: | Duke stage
| Number of subjects who had received operative treatment for colon and rectal cancer between 1961 and 1987. | A | 9.0 | 6.0
| Numerator: | B1 | 16.7 | 12.8
| Number of above subjects that died within 30 days of operation | B2 | 31.2 | 42.7
| Comparisons were made between patients under and over 80 years. | C1 | 4.5 | 0
| Data sources: Inpatient, outpatient, and office records | C2 | 21.5 | 21.8
| Recommended frequency of data collection: No recommendation | D | 17.1 | 16.7
| | Geographic location: Rhode Island, U.S.
| | Dates: 1961 and 1987
| | Healthcare setting: Academic institute
| | Results:
| | 30-day mortality rate was:
| | 6.2% for patients > 80 yr and 2.4% for patients < 80 yr
| | Long-term survival (at 5 and 8 yrs) and rate of recurrence after curative therapy used to validate the measure.
| | There was a statistically significant difference in survival rates: 48% for patients < 80 vs. 32% for patients > 80.
| | There was no statistically significant difference between the groups with regard to recurrence after curative therapy.
| Quality measure (QM): Surgical complication rate | Study population: | | | | | General comments:
| Basis of QM: None | N: 800 | | | | | Data collected between 1961 and 1987.
| Type of QM: | | < 80 yrs | > 80 yrs | | | Long-term survival (at 5 and 8 yrs) and rate of recurrence after curative therapy used to validate the three measures.
| (a) Outcome | N | 177 | 623 | | | Other factors that affect mortality rates in the elderly include: more aggressive biologic behavior of cancer of the colon and rectum in the elderly, with aggressive local disease and less tendency towards distant dissemination, greater tendency of cancer of the colon to be right-sided, rarity of adjuvant therapy administered to older patients, higher complication rate in elderly patients due to comorbid conditions and greater frequency of obstructing and perforated lesions.
| (b) General | Sex (%F/M) | 48/52 | 56/44 | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 2
| Intent of QM: Not specified (aim of the study was to perform univariate and multivariate analyses of poor indicators in the elderly undergoing colorectal operation, and to compare clinical, pathologic, and therapeutic factors in patients younger than and older than 80 years of age) | Obstruction/ Perforation | 12 | 22
| Definition of denominator/numerator: | Normal CEA at diagnosis | 77 | 68
| Denominator: | Rectal lesions | 36 | 23
| Number of subjects who had received operative treatment for colon and rectal cancer between 1961 and 1987. | Right sided lesions | 9 | 19
| Numerator: | Mucin producing tumors | 13 | 23
| Number of above subjects that had postsurgical complications (within a unspecified period) received adjuvant therapy (chemo- or radiotherapy). | Invasion adjacent organs | 13 | 23
| Comparisons were made between patients under and over 80 years. | Single liver metastasis | 20 | 38
| Data sources: Inpatient, outpatient, and office records | Duke stage
| Recommended frequency of data collection: No recommendation | A | 9.0 | 6.0
| | B1 | 16.7 | 12.8
| | B2 | 31.2 | 42.7
| | C1 | 4.5 | 0
| | C2 | 21.5 | 21.8
| | D | 17.1 | 16.7
| | Geographic location: Rhode Island, U.S.
| | Dates: 1961 and 1987
| | Healthcare setting: Academic institute
| | Results:
| | Complication rate was 55% for patients > 80 yr and 35% for patients < 80 yr.
| | There was a statistically significant difference in survival rates: 48% for patients < 80 vs. 32% for patients > 80.
| | There was no statistically significant difference between the groups with regard to recurrence after curative therapy.
Cooper, Yuan, Landefeld, et al., 1996 | Quality measure (QM): 30-day mortality | Study population: | | | | | General comments:
#14030 | Basis of QM: None | | % White patients (n = 75,865) | % Black patients (n = 5714) | % Total (n = 81,579) | | Race-related differences in patient preferences for management of colon cancer including adjuvant therapy and surveillance procedures may have contributed to the observed differences. The observed survival differences may also be related to peri- and postoperative care.
| Type of QM: | Age, y | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 3
| (a) Outcome | 65–69 | 20.9 | 24.0 | 21.1
| (b) General | 70–74 | 23.0 | 23.0 | 23.0
| Outcome to which the QM is linked: Survival | 75–79 | 22.8 | 22.2 | 22.8
| Intent of QM: Not specified (aim of the study was to determine whether race was associated with differences in two aspects of treatment of colorectal cancer: potentially curative surgical resections and survival after surgery) | 80–84 | 17.6 | 16.2 | 17.5
| Definition of denominator/numerator: | > 85 | 15.7 | 14.6 | 15.6
| Denominator: | Female | 53.7 | 57.6 | 54.0
| Number of Medicare beneficiaries with a first documented discharge diagnosis of colon or rectal cancer. | Male | 46.3 | 42.4 | 46.0
| Exclusion criteria: Patients less than 65 yr of age enrolled in Medicare for ESRD or chronic disability, or whose race was not specified, and those with ulcerative colitis, hospital identifier not matching an Americal Hospital Association number and preexisting colorectal malignancy according to the 1984 through 1987 files. | Geographic location: Nationwide
| Numerator: | Dates: 1984-1987
| Number of above patients with deaths within 30 days postadmission. | Healthcare setting: Mixed
| Data sources: 1987 Medicare provider analysis and review files | Results:
| Recommended frequency of data collection: No recommendation | Death rates at 30 days were higher for black patients (6.1% vs. 4.6% for white patients).
| | Death rates were also higher for black patents at 1 year (26.6%% vs. 21.7% for white patients) and at 2 years (40% vs. 33.5% for white patients). The disparity persisted after controlling for sex, age, number of comorbidities, and extent and location of cancer.
| Quality measure (QM): Surgical resection rate | Study population:
| Basis of QM: None | | % White patients (n = 75,865) | % Black patients (n = 5714) | % Total (n = 81,579)
| Type of QM: | Age, y
| (a) Outcome | 65–69 | 20.9 | 24.0 | 21.1
| (b) General | 70–74 | 23.0 | 23.0 | 23.0
| Outcome to which the QM is linked: Survival | 75–79 | 22.8 | 22.2 | 22.8
| Intent of QM: Not specified (aim of the study was to determine whether race was associated with differences in two aspects of treatment of colorectal cancer: potentially curative surgical resections and survival after surgery) | 80–84 | 17.6 | 16.2 | 17.5
| Definition of denominator/numerator: | >-85 | 15.7 | 14.6 | 15.6
| Denominator: | Gender
| Number of Medicare beneficiaries with a first documented discharge diagnosis of colon or rectal cancer. | Female | 53.7 | 57.6 | 54.0
| Exclusion criteria: Patients less than 65 yr of age enrolled in Medicare for ESRD or chronic disability, or whose race was not specified, and those with ulcerative colitis, hospital identifier not matching an Americal Hospital Association number and preexisting colorectal malignancy according to the 1984 through 1987 files. | Male | 46.3 | 42.4 | 46.0
| Numerator: | Geographic location: Nationwide
| Number of above patients who underwent surgical resection. | Dates: 1984-1987
| Data sources: 1987 Medicare provider analysis and review files | Healthcare setting: Mixed
| Recommended frequency of data collection: No recommendation | Results:
| | Surgical resection of colon cancer was performed less often in black patients (68%) than in white patients (78%). After controlling for sex, age, number of comorbidities, and extent and location of cancer, black patients were less likely to undergo surgical resection.
| | Surgical resection was performed less often for black patients than white patients in teaching hospitals, non-teaching hospitals, private hospitals and public hospitals.
| | Death rates were also higher for black patents at 1 year (26.6%% vs. 21.7% for white patients) and at 2 years (40% vs. 33.5% for white patients). The disparity persisted after controlling for gender, age, number of comorbidities, and extent and location of cancer.
Demissie, Oluwole, Balasubra-manian, et al., 2004 | Quality measure (QM): Non-receipt of standard surgical treatment | Study population: | | | | | General comments:
#31380 | Basis of QM: Clinical practice guideline (NIH guidelines) | Characteristic | Male | | Female | | Intent-to-treat was considered; therefore all exploratory surgical procedures with and without the actual removal of tumor were considered “standard surgical treatment.” “Standard surgical treatments” for rectal and colon cancer are well defined in the study.
| Type of QM: | | White | Black | White | Black | Report states that higher proportion of non-receipt of standard treatment in blacks could be because of higher treatment refusal.
| (a) Process | n | 49,359 | 4383 | 47,803 | 4832 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 4
| (b) General | < 84 yr | 92.5 | 95.3 | 84 | 92
| Outcome to which the QM is linked: Survival | AJJCC Tumor Stage
| Intent of QM: Not specified (aim of the study was to examine colorectal cancer treatment differences between races with comparable disease at presentation) | II | 26.84 | 23.07 | 24.18 | 20.99
| Definition of denominator/numerator: | II | 29.54 | 26.44 | 32.49 | 28.04
| Denominator: | III | 22.66 | 23.02 | 23.77 | 24.71
| Number of white or black subjects diagnosed with rectal cancer between Jan 1, 1988 and Dec 31, 1997. | IV | 16.76 | 22.36 | 15.70 | 20.88
| Exclusion criteria: Subjects neither white nor black, unknown treatment history, cancer diagnosed at autopsy, in-situ tumor or carcinoid tumor, rare histological types. | Unknown | 4.2 | 5.11 | 3.87 | 5.38
| Numerator: | Geographic location: SEER geographic regions
| Number of above subjects not receiving standard surgical treatment. | Dates: 1988-1997
| Comparisons were made between blacks and whites. | Healthcare setting: Mixed
| Data sources: SEER database | Results:
| Recommended frequency of data collection: No recommendation | The black-to-white disparities in surgical treatment for stage I and IV colon cancer were small, but persisted controlling for age, location of cancer, histologic type, and tumor grade. No significant racial disparities in receipt of surgical treatment were apparent for stage II and III and unstaged colon cancer patients.
| | Odds of non-receipt of surgical treatment were higher for black males compared with white males for stages I, III, and IV rectal cancer. A higher likelihood of non-receipt of surgical treatment was also seen for stage I and II rectal cancer among black females.
| | Black-to-white disparity in non-receipt was more prominent when actual treatment received rather than intent-to-treat was considered.
| | Patients refused cancer-directed surgery: Stage I: 32.8% black and 9.2% white males.19.4% black and 12.8% white females.
Dimick, Cowan, Upchurch, et al., 2003 | Quality measure (QM): In-hospital mortality | Study population: | | | | | General comments:
#33220 | Basis of QM: None | | Volume | | | | Risk-adjustment is essential for drawing accurate conclusions regarding the impact of hospital volume on surgical outcomes.
| Type of QM: | | Low | Medium | High | V high | Study suggests that older patients are an easily identifiable high-risk group that would benefit from referral to high-volume hospitals. Such a selective strategy would realize the most from regionalization, and will not affect low-volume hospitals.
| (a) Structure | No.of hospitals | 536 (64%) | 149 (18%) | 97 (12%) | 60 (7%) | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 1; - Adaptability: 2; - Adequacy of risk adjustment: 4
| (b) General | Bed size
| Outcome to which the QM is linked: Mortality | Small | 271 (51%) | 21 (14%) | 12 (12%) | 2 (3%)
| Intent of QM: Not specified (aim of the study was to determine the impact of hospital volume on mortality for patients of different age groups to determine whether elderly patients would derive more benefit from selective referral policies) | Med. | 190 (35%) | 57 (38%) | 32 (33%) | 11 (18%)
| Definition of denominator/numerator: | Large | 75 (14%) | 69 (46%) | 53 (55%) | 47 (78%)
| Denominator: | Geographic location: U.S.
| Number of patients who underwent colon resection for cancer by hospital volume. | Dates: 1997
| Numerator: | Healthcare setting: Mixed
| Number of above patients who died while in hospital. | Results:
| Comparisons were made across hospitals: | Adjusting for several significant patient covariates, low hospital volume was associated with a 50% (95% CI, 10–100%, p = 0.005) increased risk of in-hospital mortality compared to very high volume hospitals.
| Quartiles of hospitals: Low volume = < 55/yr | In the multivariate analysis adjusting for several significant patient covariates, low hospital volume was associated with increased risk of in-hospital mortality compared to very high volume hospitals. Other significant independent variables in the multivariate analysis included patient age, nature of admission (urgent or emergent), comorbid disease, annual income, and patient sex.
| Medium volume= 55–100/yr
| High volume = 101–150/yr
| Very high volume = > 150/yr
| Data sources: Nationwide Inpatient Sample (NIS)
| Recommended frequency of data collection: No recommendation
Dominitz, Samsa, Landsman, et al., 1998 | Quality measure (QM): Percentage of patients with colorectal cancer undergoing surgery | Study population: | | | | | General comments:
#9380 | Basis of QM: None | N: 2607 whites + 569 blacks | | | | | The article compares rates of surgery, radiotherapy, and chemotherapy among blacks and whites. No attempt is made to compare to a gold standard (e.g., a guideline) to determine whether the rates in blacks or whites are optimal.
| Type of QM: | Age: 67.1 ± 9.1 (whites); 66.4 ± 9.9 (blacks) | | | | | The study is limited because of its use of an administrative database that lacked clinical details and did not allow for adjustment to disease severity.
| (a) Process | Race: See above | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 1; - Adaptability: 1; - Adequacy of risk adjustment: 1
| (b) General | Sex: 100% male
| Outcome to which the QM is linked: Survival | Tumor stage: All stages
| Intent of QM: Not specified (aim of the study was to assess the influence of race on the treatment and survival of patients with colorectal carcinoma) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: VA Medical Centers
| Denominator: | Dates: 1989
| Number of white/black patients with colorectal cancer identified from the VA Patient Treatment File (PTF) who were discharged from VA hospitals with a diagnosis of CRC (ICD-9-CM codes 153.0–153.4, 153.6–154.1) during fiscal year 1989. To exclude prevalent cases, any patient with a diagnosis of CRC (ICD-9-CM codes 153.0–153.4, 153.6–154.1, V10.05–V10.06 ) for hospitalization during FY 1984-1988, or a personal history of CRC (ICD-9-CM codes V10.05–V10.06) during the index hospitalization, was excluded. Male veterans only. No ulcerative colitis or Crohn's disease. | Healthcare setting: VA Hospitals
| Numerator: | Results:
| Number of above white/black patients treated with surgery, as indicated by specific ICD-9-CM codes in the PTF. | No statistically significant differences in rates of surgical resection in blacks vs. whites.
| Data sources: VA PTF | No difference in 5-year relative survival or overall survival in blacks vs. whites.
| Recommended frequency of data collection: No recommendation
Govindarajan, Shah, Erkman, et al., 2003 | Quality measure (QM): Percentage of patients with stage II, III colorectal cancer undergoing surgery | Study population: | | | | | General comments: None
#35310 | Basis of QM: None | N: 617 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 1; - Adaptability: 1; - Adequacy of risk adjustment: 1
| Type of QM: | Colorectal | Caucasian | AA
| (a) Process | N | 427 | 190
| (b) General | Median age | 60.0 | 61.5
| Outcome to which the QM is linked: Not firmly linked to any outcome, but presumably to survival, quality of life, or rates of local recurrence | Male (%) | 47.1 | 39.5
| Intent of QM: Not specified (aim of the study was to analyze disease stage, treatment received, and socioeconomic factors to better understand the factors influencing survival differences between African-Americans and Caucasians with colorectal cancer) | Tumor stage (%)
| Definition of denominator/numerator: | 0–I | 23.4 | 21.6
| Denominator: | II | 20.5 | 15.3
| Number of African-Americans (AAs)/Caucasians, aged 18 older, with CRC treated between 1984 and 1997 at a state-funded University hospital located in Arkansas, identified through the hospital tumor registry using appropriate tumor registry codes. | III | 26.2 | 26.7
| Numerator: | IV | 30.0 | 36.4
| Number of above AAs/Caucasians treated with surgery. | Performance status: NR
| Data sources: Tumor registry at Univ. of Arkansas. | Geographic location: Arkansas
| Recommended frequency of data collection: No recommendation | Dates: 1984-1997
| | Healthcare setting: University hospital
| | Results:
| | Authors show that significantly higher percentages of Caucasians received surgery, compared with AAs, for patients with all stages of CRC, and for patients with only stages II and III disease.
| | Cancer-specific mortality was higher in African-Americans than in Caucasians for all stages.
Harmon, Tang, Gordon, et al, 1999 | Quality measure (QM): In-hospital death rate | Study population: | | | | | General comments:
#35570 | Basis of QM: None | Characteristics | Surgeon Volume Groups | Hospital Volume Groups | | | Hospital case volume can serve as a surrogate for surgeon case volume. Surgeons in medium-volume hospitals had indistinguishable results.
| Type of QM: | | Low/ Med/ High | Low/ Med/High | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 4; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 4
| (a) Outcome | Mean age (years) | 68.7/ 69.2/69.3 | 69.1/ 69.5/ 68.8
| (b) General | Sex (% male) | 47.0/ 48.6/47.2 | 47.8/46.6/48.7
| Outcome to which the QM is linked: Mortality | Race-%white | 74.4/ 83.8/84.1 | 74.9/ 81.7/ 84.7
| Intent of QM: Not specified (aim of the study was to examine the association of surgeon and hospital case volumes with the short-term outcomes in-hospital death, total hospital charges, and length of stay for resection of colorectal carcinoma) | Race-% black | 23.8/ 14.8/13.7 | 23.3/ 16.5/ 13.5
| Definition of denominator/numerator: | Geographic location: Maryland
| Denominator: | Dates: 1992-1996
| Number of patients who underwent colorectal resection (partial colectomy, total colectomy, abdominoperineal resection, other rectal resections including anterior resection). | Healthcare setting: Mixed
| Numerator: | Results:
| Number of above patients who died in hospital. | Characteristics | State Total | Surgeon Volume Groups | Hospital Volume Groups
| Comparisons were made across hospital and surgeon volume. Surgeon case volume groups: low = ≤ 5 cases/yr, medium = 5–10 cases/yr, high =>10 cases/yr. Hospital volume groups: low = <40 cases/yr, medium = 40–70 cases/yr, high =≥ 70 cases/yr. | | | Low/Med/High | Low/Med/High
| Data sources: Health Services Cost Review Commission | Mortality
| Recommended frequency of data collection: No recommendation | Crude % | 3.5 | 4.5/ 3.3/ 2.6 | 4.7/ 3.0/3.0
| | Adjusted relative risk | | 1.00/0.79/0.64 | 1.00/0.79/0.78
| | A positive relation between high surgeon case volume and favorable outcomes was observed.
| | Medium volume surgeons achieved excellent outcomes similar to high-volume surgeons when operating in medium- or high-volume hospitals, but not in low-volume hospitals.
| | Results of low-volume surgeons improved with increasing hospital volume, but never equated those of high-volume surgeons
| | Besides surgeon and hospital volume, other independent variables had a significant impact: an urgent or emergent admission, increased age, presence of organ metastasis, increased comorbidity index, male sex, undergoing a total colectomy or rectal resection and Medicaid payer status were associated with poorer outcomes.
Hodgson, Zhang, Zaslavsky, et al., 2003 | Quality measure (QM): Postoperative (30-day) mortality | Study population: | | | | | General comments:
#34120 | Basis of QM: None | N: 7,257 | | | | | 30-day mortality seems to have face validity as an indicator of quality of surgery although there are a number of factors that may account for this other than hospital volume. The investigators performed multivariate analysis and found hospital volume still remained a significant indicator, but of course, there are some factors that might not be accounted for in the model.
| Type of QM: | Median age | 68.1 | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 2
| (a) Outcome | Male (%) | 55.5
| (b) General | Race (%)
| Intent of QM: Not specified (aim of the study was to assess the association between hospital volume and colostomy rates, postoperative mortality, and overall survival for patients with rectal cancer) | White | 75.0
| Definition of denominator/numerator: | Black | 4.9
| Denominator: | Hispanic | 10.9
| Number of patients diagnosed with rectal cancer or rectosigmoid cancer (ICD for Oncology codes 20.9 and 19.9), stage I-III, in California who underwent a major surgical procedure and had available hospital, demographic, and followup data. | Asian | 8.8
| Numerator: | Tumor stage (%)
| Number of above patients who died within 30 days of the surgical procedure. | I | 34.0
| Data sources: California Cancer Registry | II | 33.3
| Recommended frequency of data collection: No recommendation | III | 32.7
| | Performance status: NR
| | Geographic location: California
| | Dates: January 1, 1994-December 31, 1997
| | Healthcare setting: Hospital
| | Results:
| | The 30-day mortality rate varied from 1.6% at high-volume hospitals to 4.8% at low-volume hospitals.
| Quality measure (QM): Rate of colostomy for patients with rectal and rectosigmoid cancers | Study population: | | | | | General comments:
| Basis of QM: None | N: 7,257 | | | | | The relation of colostomy rate to hospital volume seems to have face validity, but having a colostomy may not indicate poor quality care because some patients have tumors that are so low they cannot be excised with a reanastamosis. In other patients, the colostomy could be temporary to protect the anastomosis. The authors do try to account for temporary colostomies by excluding those with ICD codes for reversal within 1 year (but this could still misplace some patients).
| Type of QM: | Median age | 68.1 | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 2; - Adaptability: 2; - Adequacy of risk adjustment: 2
| (a) Outcome | Male (%) | 55.5
| (b) General | Race (%)
| Intent of QM: Not specified (aim of the study was to assess the association between hospital volume and colostomy rates, postoperative mortality, and overall survival for patients with rectal cancer) | White | 75.0
| Definition of denominator/numerator: | Black | 4.9
| Denominator: | Hispanic | 10.9
| Number of patients diagnosed with rectal cancer or rectosigmoid cancer (ICD for Oncology codes 20.9 and 19.9), stage I-III, in California who underwent a major surgical procedure and had available hospital, demographic, and followup data. | Asian | 8.8
| Numerator: | Tumor stage (%)
| Number of above patients requiring a colostomy. | I | 34.0
| Data sources: California Cancer Registry | II | 33.3
| Recommended frequency of data collection: No recommendation | III | 32.7
| | Performance status: NR
| | Geographic location: California
| | Dates: January 1, 1994-December 31, 1997
| | Healthcare setting: Hospital
| | Results:
| | 33.1% of patients underwent a permanent colostomy, and the rate increased statistically as hospital volume decreased.
Hyman, Labow, and Vermont Chapter of the American College of Surgeons, 2002 | Quality measure (QM): Curative resection rate | Study population: | | | | | General comments:
#18980 | Basis of QM: Not specified | N: 364 (33 surgeons) | | | | | The study was not designed with an explicit intention to compare quality of care among participating surgeons (although it could potentially do so), but for comparison with national benchmarks.
| Type of QM: | Age: Mean 68.7 | | | | | A voluntary registry was used as the source of data.
| (a) Process | Stage of tumor: Stage I = 24%, stage II = 32%, stage II = 28%, stage IV = 16% | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 2; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 3
| (b) General | Operative Procedures Performed in 364 Patients with Colorectal Cancer
| Outcome to which the QM is linked: Mortality | Procedure | Patients, No.
| Intent of QM: Quality improvement (aim of the study was to assess the feasibility of performing a quality study of the surgical management of colorectal cancer using a voluntary registry) | Right hemicolectomy | 125
| Definition of denominator/numerator: | Transverse colectomy | 14
| Denominator: | Left hemicolectomy | 23
| Number of colorectal cancer patients reported to registry. | Sigmoid resection | 55
| Numerator: | Subtotal colectomy | 13
| Number of above patients curatively resected. Curative resection defined as “no residual disease and no unresected metastatic disease.” | Total proctocolectomy | 4
| Data sources: Prospective statewide voluntary registry created by the Vermont chapter of ACS with the Vermont Program for Quality Health Care | Anterior resection | 5
| Recommended frequency of data collection: No recommendation | Coloanal anastomosis | 11
| | Abdominoperineal resection | 15
| | Local excision | 20
| | Diverting stoma only | 13
| | Intestinal bypass | 3
| | Exploratory laparotomy only | 2
| | Other/multiple procedures | 8
| | Total | 364
| | Geographic location: Vermont
| | Dates: April 1 1999 to March 31, 2001
| | Healthcare setting: Mixed
| | Results:
| | 85% patients had a potentially curative resection (no residual local disease and no unresected metastatic disease).
Ko, Chang, Chaudhry, et al., 2002 | Quality measure (QM): In-hospital death by hospital volume | Study population: | | | | | General comments:
#17540 | Basis of QM: None | N: 22,408 | | | | | The analysis suggests that the variables that resulted in the greatest increase in the probability of in-hospital mortality included having liver disease (4.45%), and having an emergency operation (4.35%), each with more than a 3-fold increase over the baseline (1.22%). Female sex, increased hospital procedure volume and increased surgeon volume were associated with a decreased probability of mortality.
| Type of QM: | Average age | 70.4 +/- 12.2 | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 4; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 3
| (a) Structure | male | 51%
| (b) General | Caucasian | 86%
| Outcome to which the QM is linked: In-hospital mortality | black | 8%
| Intent of QM: Not specified (aim of the study was to evaluate the importance of volume variables relative to other factors in an attempt to target specific areas for improving outcomes for colon cancer resections) | Hispanic | 4%
| Definition of denominator/numerator: | Asian | 1%
| Denominator: | Average discharges | 15,437 +/- 11,000
| Number of patients with colon cancer resection. | Colorectal cases | 60 +/- 41
| Numerator: | Surgeon cases | 10.8 +/- 7.8
| Number of above patients who died in hospital. | Geographic location: U.S.
| Comparisons were made by hospital volume. | Dates: 1996
| Data sources: 1996 HCUP nationwide inpatient sample | Healthcare setting: Inpatient hospital setting
| Recommended frequency of data collection: No recommendation | Results:
| | Significant predictors of mortality were age, sex, comorbid disease and volume (both hospital and surgeon). The predicted decrease in mortality by going to a high-volume hospital was 0.13%. Overall, the volume variables, although statistically significant, have a relatively smaller effect on outcome compared with other factors.
| Quality measure (QM): In-hospital death by surgeon volume | Study population: | | | | | General comments:
| Basis of QM: None | N: 22,408 | | | | | The analysis suggests that the variables that resulted in the greatest increase in the probability of in-hospital mortality included having liver disease (4.45%), and having an emergency operation (4.35%), each with more than a 3-fold increase over the baseline (1.22%). Female sex, increased hospital procedure volume and increased surgeon volume were associated with a decreased probability of mortality.
| Type of QM: | Average age | 70.4 +/- 12.2 | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 4; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 3
| (a) Structure | male | 51%
| (b) General | Caucasian | 86%
| Outcome to which the QM is linked: In-hospital mortality | black | 8%
| Intent of QM: Not specified (aim of the study was to evaluate the importance of volume variables relative to other factors in an attempt to target specific areas for improving outcomes for colon cancer resections) | Hispanic | 4%
| Definition of denominator/numerator: | Asian | 1%
| Denominator: | Average discharges | 15,437 +/- 11,000
| Number of patients with colon cancer resection. | Colorectal cases | 60 +/- 41
| Numerator: | Surgeon cases | 10.8 +/- 7.8
| Number of above patients who died in hospital. | Geographic location: U.S.
| Comparisons were made by surgeon volume. | Dates: 1996
| Data sources: 1996 HCUP nationwide inpatient sample | Healthcare setting: Mixed
| Recommended frequency of data collection: No recommendation | Results:
| | Significant predictors of mortality were age, sex, comorbid disease and volume (both hospital and surgeon). The predicted decrease in mortality by going to a high-volume surgeon was 0.17%.
| | Overall, the volume variables, although statistically significant, have a relatively smaller effect on outcome compared with other factors.
Merrill, Brown, Potosky, et al., 1999 | Quality measure (QM): Percentage of CRC patients who had surgical resection | Study population: | | | | | General comments:
#27110 | Basis of QM: None | N: 15,352 total | | | | | A very high-quality study by experienced researchers.
| Type of QM: | Age: ≥ 65 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 4
| (a) Structure | Race: 81.2 to 95.3% white depending on subgroup
| (b) General | Sex: 46.8 to 54.3% male, depending on subgroup
| Outcome to which the QM is linked: Presumably survival | Tumor stage: 0–IV
| Intent of QM: Not specified (aim of the study was to compare treatment utilization and long-term survival in HMO and fee-for-service [FFS] settings for Medicare colorectal cancer cases) | Performance status: NR
| Definition of denominator/numerator: | Comorbidity Index: 0–2+
| Denominator: | Geographic location: San-Francisco-Oakland area, Seattle-Puget Sound area
| Number of CRC patients in each subgroup of the dataset (see Data sources, below). | Dates: 1985-1992
| Numerator: | Healthcare setting: 2 tumor registries participating in the SEER Program augmented with Medicare data along with HMOs KPNC and GHC.
| Number of above patients who had surgical resection. | Results:
| Data sources: | Only statistical difference in rates of surgical resection between HMO and FFS cases was observed for stage I cases, in which the percentage receiving resection was 75% (95% CI 70–79%) for HMO cases and 82% (95% CI 80–84%) for FFS cases. Standardizing to the FFS cases gave an adjusted HMO rate of 74% (95% CI 70–79%), which was no longer statistically different. No differences were seen in the use of surgical resection for rectal cases.
| 1 Two tumor registries on colon and rectum cancer patients diagnosed 1985-92 and followed up through 31 December 1994. Both registries are part of SEER.; 2 Medicare inpatient claims data.; 3 Databases of two HMO plans, Kaiser Permanente of Northern California and Group Health Cooperative of Puget Sound.; 4 1990 U.S. Census | Cancer-specific mortality rates were similar in both settings.
| Recommended frequency of data collection: No recommendation
Morris, Billingsley, Baxter, et al., 2004 | Quality measure (QM): Rate of sphincter-preserving procedures (SSP) | Study population: | | | | | General comments: None
#32200 | Basis of QM: Not specified, but appears to be NIH Consensus conference | N = 52,864 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 3
| Type of QM: | | White | Black
| (a) Process | n | 44,010 | 3,851
| (b) General | Age (%)
| Outcome to which the QM is linked: No explicit outcome link, but presumably to decreased rates of LRR or improved OS | 35–64 | 35 | 49
| Intent of QM: Aim of the study was to investigate racial variation in the performance of sphincter-sparing procedures for patients with stage II and III rectal cancer who underwent surgery, and to study race and delivery of any surgical treatment, neoadjuvant therapy, and radiation therapy to these patients, with implications for quality of care. | 65–79 | 46 | 40
| Definition of denominator/numerator: | 80+ | 20 | 12
| Denominator: | Male (%) | 55 | 52
| Number of blacks/whites diagnosed with rectal cancer and entered into the SEER database 1988-1999. | Tumor stage (%)
| Exclusion criteria: Prior diagnosis of CRC, prior diagnosis of cancer requiring surgery or radiotherapy in the pelvis, or < age 35. | In situ | 9 | 8
| Numerator: | I | 3 | 28
| Number of above patients who received various treatments for CRC including surgery (also type of operation) and radiation (timing of RT also evaluated). | II | 21 | 20
| Data sources: SEER registry | III | 19 | 18
| Recommended frequency of data collection: No recommendation | IV | 14 | 17
| | Unstaged | 8 | 10
| | Geographic location: SEER regions
| | Dates: 1988-1999
| | Healthcare setting: U.S. healthcare facilities
| | Results:
| | N = 15,351 | Rate of operation | | Adjusted OR (95% CI)
| | | Any | None
| | White | 96 | 4 | 1.30 (1.12–1.95)
| | Black | 94 | 6
| | N = 14,405 | SSP | APR | Adjusted OR (95% CI)
| | White | 63 | 37 | 1.42 (1.23–1.65)
| | Black | 57 | 43
Newcomb and Carbone, 1993 | Quality measure (QM): Rate of surgery for colorectal cancer | Study population: | | | | | General comments:
#3760 | Basis of QM: None mentioned, but presumably practice guideline | N: 121 with colorectal | | | | | Relying on recall of patients for whether they received a treatment is open to bias.
| Type of QM: | Age: 20–74 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 3; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 4; - Validity: 4; - Adaptability: 5; - Adequacy of risk adjustment: 1
| (a) Process | Race: NR
| (b) General | Sex: Female
| Outcome to which the QM is linked: Not specified, but presumably survival or rate of bleeding or obstruction | Tumor stage: All stages
| Intent of QM: Not specified (aim of the study was to evaluate the selection of cancer treatment among the elderly) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Wisconsin
| Denominator: | Dates: Sep 1 through Nov 30, 1990
| Number of women residents of Wisconsin aged 20–74 at the time of diagnosis with a new diagnosis of carcinoma of the large bowel during 1989-1991, and who had a listed telephone number and spoke English, and whose physician consented to their participation, and who agreed to a telephone interview, and were among the 628 consecutive participants interviewed September 1, 1990 through November 30, 1990. | Healthcare setting: None (all participants were outpatients contacted by phone)
| Numerator: | Results:
| Number of above subjects having surgery. | 98% of patients less than 65 and 94% ≥ 65 received surgery.
| Data sources: Registry for staging information and patient interviews (for the treatment information)
| Recommended frequency of data collection: No recommendation
O'Connell, Maggard, Liu, et al., 2004 | Quality measure (QM) | Study population: | | | | | General comments:
#45210 | Cancer-directed surgery (CDS) rate | N = 11,778 | | | | | The SEER registry maintains stringent quality control measures to prevent coding errors and is regarded as one of the best population based databases; however, miscoding and inaccurate data may be present. The registry does not contain all clinically relevant data, such as family history, predisposing factors, etc. A third limitation of the SEER data is that tumor stage or grade was unknown for a number of patients. Another limitation of the study is the substantially smaller sample of young rectal cancer patients compared with the large number of older patients, leading to overestimation of differences.
| Basis of QM: NIH Consensus Conference Guidelines for adjuvant therapy for colorectal cancer | | 20–40 yrs (young) N = 466 | 60–80 yrs (old) N = 11,312 | P-value | | Rating of quality measures as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | Age | 34.1± 4.5 | 70± 5.5 | | | - Importance: 4; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 3
| (a) Process | Male % | 54.9 | 60 | 0.03
| (b) General | Race
| Intent of QM: Not specified (aim of the study was to compare rectal cancer patient outcomes between young and older populations) | White | 62.6 | 82.3 | < 0.001
| Definition of denominator/numerator: | Black | 12.7 | 6.1 | < 0.001
| Denominator: | Hispanic | 8.8 | 3.7 | < 0.001
| Patients in the SEER database diagnosed with rectal cancer between 1991 and 1999. Tumors identified as “rectum” in location were selected. Specific histologies were chosen to include only adenocarcinomas. | Asian | 7.5 | 6.4 | NS
| Exclusion criteria: Patients with tumors identified as rectosigmoid. Mucinous, signet ring cell, carcinoid, sarcoma and lumphoma histologies were excluded, along with those tumors classified as benign or in situ. | other | 8.4 | 1.5 | < 0.001
| Numerator: | AJCC stage
| Number of above patients who received CDS subsequent to diagnosis. | I | 17 | 23.7 | < 0.001
| Data sources: SEER database | II | 15.5 | 17.8 | NS
| Frequency of data collection: No recommendation | III | 27 | 20 | < 0.001
| | IV | 17.4 | 13.6 | 0.02
| | Grade
| | Well | 7.5 | 9.4 | NS
| | Moderate | 50.4 | 61.2 | < 0.001
| | Poorly | 24.3 | 14 | < 0.001
| | Anaplastic | 1.7 | .7 | 0.008
| | unknown | 16.1 | 14.7 | NS
| | Geographic location: U.S.
| | Dates: 1991-1999
| | Healthcare setting: Hospital
| | Results:
| | Young patients overall were as likely to receive CDS as their older counterparts (85.4% vs. 85.5%). Similar findings were seen for stages I, II and III disease (96.2–99.2% received CDS). However, both young and older patients with stage IV disease were less likely to receive CDS (51.9 vs. 51.8; p = NS).
| | Median survival was 24 months for the young group and 27 months for the older group. Univariate analysis revealed overall 5-year survival was similar for the young group compared with the older (63.2 vs. 62.1%; p = NS). Five-year, stage-specific survival also was similar for all stages.
| | Multivariate Cox regression analysis revealed that young, rectal cancer patients had a lower hazard of dying (hazard ratio, 0.693, p = 0.0004) when controlling for tumor stage, patient demographics, tumor characteristics, and stage and treatment.
| Quality measure (QM): Percentage of patients with colon cancer who underwent cancer-directed surgery | Study population: | | | | | General comments:
| Basis of QM: None | N: 47,791 | | | | | The data for other potential QMs (% received surgery) are much weaker, poorly defined and do not necessarily follow guidelines. Data presented for radiation therapy are too inadequate to abstract as a QM (i.e., not stratified by stage) and are not indicated for colon cancer anyway (rectal cancers were excluded from this study).
| Type of QM: | | Young (20–40 yrs) | Older (60–80 yrs) | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance:; - Usability:; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 2; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | N | 1,334 | 46,457
| (b) General | Age | 34.1 | 70.8
| Outcome to which the QM is linked: Mortality | Male (%) | 52.1 | 51.5
| Intent of QM: Not specified (aim of the study was to analyze differences in patient demographics, cancer-related data, and survival between young and older colon cancer patients) | Race (%)
| Definition of denominator/numerator: | White | 64.2 | 81.2
| Denominator: | Black | 16.4 | 9.0
| Number of patients with colon cancer diagnosed between 1991 and 1999 in a SEER database (which included only those patient living in a SEER area at the time of diagnosis) who were either aged 20–40 or aged 60–80. | Hispanic | 6.5 | 3.0
| Exclusion criteria: In situ cancers, rectal cancers. | Asian | 7.4 | 5.6
| Numerator: | Other | 5.5 | 1.2
| Number of the above subjects who also underwent “cancer-directed surgery” (a variable in the SEER database). | AJCC Stage (%)
| Data sources: SEER database | I | 10.6 | 18.6
| Recommended frequency of data collection: No recommendation | II | 23.0 | 29.0
| | III | 31.5 | 22.8
| | IV | 24.5 | 17.3
| | Unstaged | 10.4 | 12.3
| | Geographic location: SEER regions not specifically listed in this publication)
| | Dates: Diagnosis 1991-1999; followed through 2004 (?)
| | Healthcare setting: Variety, Medicare, non-HMO
| | Results:
| | Young patients were as likely to undergo cancer-directed surgical resection as their older counterparts, with 91.4% of young patients and 91.2% of older patients having cancer-directed surgery (p = NS). Similar findings were seen specifically for surgery for stage I, II, and III disease (99.2–99.7% underwent surgery). However, older patients with stage IV disease had surgery significantly less often than young patients (74.6% vs. 83.2%, p < 0.001). Overall 5-year cancer-specific survival for young patients was poorer than for older patients (62% vs. 65%).
Purves, Pietrobon, Hervey, et al. 2005 | Quality measure (QM): Rate of sphincter-sparing procedures (SSP) and abdominoperineal resection (APR) procedures performed among surgeons, by caseload volume | Study population: | | | | | General comments:
#43660 | Basis of QM: Not specified | N = 477 | | | | | Investigators did not have access to information about specific characteristics of each patient's rectal cancer, such as grading, tumor size and height, lymph node metastases and other tumor characteristics important to staging.
| Type of QM: | | SSP | APR | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 3
| (a) Process | n | 259 | 218
| (b) General | Surgeons | 120 | 109
| Outcome to which the QM is linked: No explicit outcome link, but presumably to decreased rates of LRR or improved OS. | Patient Age (%)
| Intent of QM: Not specified (aim of the study was to determine whether the rate of SSP increased among surgeons who performed a larger number of rectal cancer surgeries in one year, while controlling for patient characteristics, including comorbidity) | ≤ 59 | 26.3 | 22.0
| Definition of denominator/numerator: | 60–69 | 26.6 | 29.8
| Denominator: | ≥ 70 | 47.1 | 47.2
| Patients with a diagnostic ICD-9 code of 154.1 (malignant neoplasm of the rectum) as primary diagnosis. | Male (%) | 56 | 60
| Exclusion criteria: Patients with anal cancer (154.2, 154.3); patients with rectum or colon cancer (154.0) or patients with rectal cancer contiguous with the rectosigmoid junction or anus (154.8). Also excluded were patients who were not surgically treated for their rectal cancer during the hospital admission of record. Prior diagnosis of CRC, prior diagnosis of cancer requiring surgery or radiotherapy in the pelvis, or < age 35. | White (%) | 70 | 71.1
| Numerator: | Non-White (%) | 12.6 | 10.1
| Number of above patients who underwent either APR or SSP procedure. | Geographic location: 22 states in U.S.
| Data sources: 1997 National Inpatient Sample (NIS) of the Healthcare Cost and Utilization Project (HCUP) database | Dates: 1997
| Recommended frequency of data collection: No recommendation | Healthcare setting: U.S. community hospitals
| | Results:
| | | SSP | APR
| | Deyo score (%) | | | P<.05
| | 0–7 | 29.8 | 18.2
| | I8–15 | 20.1 | 23.5
| | ≥ 16 | 4.4 | 4.0
| | Surgeon volume (%) | | | P<.05
| | 1–3 | 12.4 | 16.4
| | 4–9 | 9.4 | 7.1
| | ≥ 10 | 9.0 | 2.7
| | Missing | 23.5 | 19.5
| | mean | 1.27 | .73
| | Surgeon case-load volume | Adjusted for age, sex, race, comorbidity, income odds ratio | Reduced adjusted (race only) odds ratio
| | 1–3 | 1.00 | 1.00
| | 4–9 | 1.73 | 2.02
| | ≥ 10 | 5.05 | 4.55
| | SSP accounted for 259 o 54.3 percent of all resections. APR accounted for 45.7%. SSP patients did not differ from those undergoing APR in terms of age, race, sex or income. Patients undergoing SSP, however, had a lower average Deyo comorbidity score than those undergoing APR (6.4 vs. 7.7, p = 0.01).
| | The mean surgeon caseload volume for patients undergoing SSP was significantly more than that for APR patients (7.7 vs. 4.6, p = 0.0002). Rectal cancer patients treated by a high-caseload surgeon (≥ 10 outcome procedures per year) are more likely to receive an SSP than are patients treated by low-caseload surgeons (1–3 outcome procedures per year).
| | In a multivariable analysis, patients undergoing procedures performed by surgeons in the highest volume category were five times more likely to undergo SSP than patients treated by surgeons in the lowest volume category, when analysis was controlled for age, race, sex, and Deyo comorbidity score. In a reduced model, controlling only for race, the odds ratio of SSP for patients treated by surgeons in the highest-volume category compared with lowest-volume category was 4.55.
Rabeneck, Davila, Thompson, et al., 2004 | Quality measure (QM): 30 day operative mortality rate | Study population: | | | | | General comments:
#44670 | Basis of QM: None | N = 22,633 | | | | | Some misclassification of variables may exist because of coding errors. Given that the study population was predominantly male, the results may not be generalized to women with CRC. The quality of ascertainment of chemotherapy and radiotherapy is unknown. Therefore, our adjustment for these variables might be incomplete. Our adjustments for comorbidity may be incomplete because of the use of administrative data, and our adjustment for disease severity may be incomplete. The lack of staging information is an important limitation.
| Type of QM: | Mean age: 68, with two-thirds ≥ 65 | | | | | Rating of quality measures as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 4
| (a) Outcome | Sex: 98% male
| (b) General | Race: 75% white; 17% black, 4% Hispanic
| Intent of QM: Not specified (aim of the study was to compare 30-day and 5-year mortality in elderly vs. younger patients following surgical resection for colorectal cancer) | 57% comorbidity score of 0; 12% had metastatic disease
| Definition of denominator/numerator: | Geographic location: U.S.
| Denominator: | Dates: FY 1991-2000
| Patients admitted to VA hospitals with a new diagnosis of CRC who underwent surgical resection within 6 months from discharge date of first hospitalization between October 1990 and September 2000. | Healthcare setting: 172 VA medical centers
| Exclusion criteria: Patients with previous CRC diagnosis within last 5 years, those with a prior diagnosis of ulcerative colitis or Crohn's disease. | Results:
| Numerator: | Hazard Ratio
| Number of above patients who died within 30 days of surgery. | | Rectal cancer | P-value | Colon cancer | P-value
| Data sources: National VA Patient Treatment File (PTF) | < 65 | 1.00
| Frequency of data collection: No recommendation | ≥ 65 | 2.64 | <.0001 | 2.43 | <.0001
| | Deyo score
| | 0 | 1.00
| | 1–2 | 1.77 | 0.0002 | 1.58 | <.0001
| | 3–4 | 3.33 | <.0001 | 2.51 | <.0001
| | >5 | 5.59 | <.0001 | 2.56 | .0002
| | Results show 30-day postoperative mortality for patients with rectal cancer following surgical resection was more than 2.5 times greater among older patients than among younger when adjusting for sex, race, comorbidity score, marital status, and hospital surgical volume.
| | The analysis was repeated for patients with colon cancer who underwent surgical resection during 1991-2000 and the results were similar (2.5 times greater in elderly).
Read, Myerson, Fleshman, et al., 2002 | Quality measure (QM): Local control rate | Study population: | | | | | General comments: None
#17970 | Basis of QM: Clinical practice guideline (NIH Consensus Statement) | N: 213 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 4; - Validity: 4; - Adaptability: 5; - Adequacy of risk adjustment: 1
| Type of QM: | Age: 64 mean (19–97)
| (a) Structure | Race: NR
| (b) General | Sex: 100% male
| Outcome to which the QM is linked: Local tumor recurrence (not well defined) | Tumor stage: NR
| Intent of QM: Quality improvement (aim of the study was to determine the effect of surgeon specialty on disease-free survival and local control in patients with adenocarcinoma of the rectum) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: U.S. (multi-institutional)
| Denominator: | Dates: 1977-1995
| Number of patients undergoing curative treatment for primary rectal adenocarcinoma with neoadjuvant radiotherapy followed by proctectomy. Patients undergoing endocavitary radiation or transanal local excision were excluded. | Healthcare setting: Hospital
| Numerator: | Results:
| Number of above patients who failed to have local tumor recurrence (not well specified). | Background of the surgeon and the pathologic stage were significantly correlated with local control (and disease- free survival) at 5 years.
| Data sources: Medical records | | No. of cases | % without relapse at 5 yr | % local control at 5 yr
| Recommended frequency of data collection: No recommendation | Surgeon
| | Colorectal specialist | 251 | 77 | 93
| | Other | 133 | 68 | 84
| | P value | | 0.004 | 0.005
| | Histologic stage
| | I | 145 | 83 | 95
| | II | 137 | 75 | 91
| | III | 102 | 57 | 81
| | P value | | < 0.001 | 0.005
Roetzheim, Pal, Gonzalez, et al., 2000 | Quality measure (QM): Percentage of patients with a colon or rectal cancer diagnosis who received cancer-directed surgery (i.e., performed for cure not palliation) | Study population: | | | | | General comments: None
#23910 | Basis of QM: None stated | N: 9,548 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 3; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 4; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 3
| Type of QM: | Patient characteristic | Percent
| (a) Process | Male | 51
| (b) General | Race
| Outcome to which the QM is linked: Mortality | White | 85
| Intent of QM: Not specified (aim of the study was to explore the influence of race/ethnicity and insurance payer on the treatment of and outcomes for colorectal cancer patients in Florida) | Black | 6
| Definition of denominator/numerator: | Hispanic | 8
| Denominator: | Diagnosis stage
| Number of incident cases of colon or rectal cancer occurring in Florida in 1994 as listed in the state tumor registry. | In situ | 6
| Numerator: | Local | 30
| Number of the above patients who also received cancer-directed surgery within 4 months of initiation of therapy. | Regional | 42
| Data sources: Florida state cancer registry (Florida Cancer Data System = FCDS); Florida Agency for Health Care Administration AHCA discharge abstracts (admissions to all nonfederal acute care hospitals and patient visits to ambulatory surgical centers, freestanding radiation therapy centers and diagnostic imaging centers) | Distant | 16
| Recommended frequency of data collection: No recommendation | Unstaged | 6
| | Anatomic site
| | Colon | 84
| | Rectal | 16
| | Comorbidity index
| | 0 | 71
| | 1 | 21
| | ≥ 2 | 8
| | Geographic location: Florida
| | Dates: 1994
| | Healthcare setting: Multiple
| | Results:
| | Used 2 sources for the procedure data: the cancer registry and the state AHCA discharge summaries and in 94.2% there was agreement regarding surgical treatments performed.
| | Treatments received varied according to insurance payer. Patients with CRC who were uninsured or insured by Medicaid or commercial HMO's had higher mortality rates than patients with commercial FFS insurance. Mortality was also higher among non-Hispanic African-American patients even after controlling for stage of disease at diagnosis and treatment modality. Patients who needed co-directed surgery were similar in age to those who did not. There were no differences between races in receipt of definitive surgical treatment. Among Medicare patients, those with HMO insurance were more likely to receive definitive surgical treatment, the differences increased with advancing cancer stage. Among non-Medicare patients those having Medicaid, those were uninsured, and those having other forms of health insurance were less likely to receive surgical treatment than were private FFS patients. Use of definitive surgery was more common in younger patients, those with higher levels of education, and those who were married.
Rogers, Ray, and Smalley, 2004 | Quality measure (QM): Percentage of patients with a diagnosis of colorectal cancer receiving surgery | Study population: | | | | | General comments:
#30130 | Basis of QM: Not stated | N: 969 total (19.3% rectal cancer) | | | | | Study concluded that when there was equal access to care, outcomes were equal in whites and blacks.
| Type of QM: | | White | Black | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 5; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Cases (%) | 72 | 28
| (b) General | Age | 78.9 | 78.9
| Outcome to which the QM is linked: Not stated, but presumably survival or recurrence of colorectal cancer | Male (%) | 26.1 | 27.6
| Intent of QM: Not specified (aim of the study was to examine the effect of race on CRC outcomes in patients who had identical health care coverage) | Tumor stage
| Definition of denominator/numerator: | I | 16.4 | 9.2
| Denominator: | II | 39.7 | 36.0
| Number of patients enrolled in both Tennessee Medicaid and Medicare and hospitalized with a diagnosis of colorectal cancer. | III | 24.4 | 27.9
| Numerator: | IV | 9.8 | 12.9
| Number of above patients who received surgery. | Unknown | 9.8 | 14.0
| Data sources: Medical records, administrative files from the Tennessee Medicaid program, Tennessee death certificates, and the National Death Index | Charlson-Deyo score (%) | 64 | 69
| Recommended frequency of data collection: No recommendation | Geographic location: Tennessee
| | Dates: 1984-1994
| | Healthcare setting: Patients identified from hospitalizations
| | Results:
| | 91% of whites and 86% of blacks had surgery.
Schrag, Cramer, Bach, et al., 2000 | Quality measure (QM): 30-day mortality in low- and high-volume hospitals | Study population: | | | | | General comments: None
#23710 | Basis of QM: Not stated | Overall | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 4
| Type of QM: | | No. or %
| (a) Structure | Total patients | 27,986
| (b) General | Total hospitals | 611
| Outcome to which the QM is linked: Mortality | Sex
| Intent of QM: Quality improvement (aim of the study was to determine whether hospital procedure volume predicts short- and long-term survival following primary colon cancer surgery) | Male | 44.8
| Definition of denominator/numerator: | Female | 55.2
| Denominator: | Age
| Number of patients with stage III tumors who survived 3 months postoperatively, were enrolled in Medicare Part B, were 65 years and older, were diagnosed as having primary adenocarcinoma of the colon in a SEER area, and underwent surgery followed by at least one claim for chemotherapy. | 65–69 | 19.5
| Exclusion criteria: Patients were excluded if diagnoses were exclusively noted on death certificates or at autopsy; month of diagnosis was unknown; or patient was enrolled in an HMO. Also, patients who were operated on exclusively for local resection or creation of an ostomy were excluded. | 70–74 | 23.7
| Numerator: | 75–79 | 23.2
| Number of patients who died within 30 days following surgery. | 80+ | 33.6
| Data sources: SEER for patients 65 and older | Race
| Medicare Claims Part B | White | 84.6
| Recommended frequency of data collection: No recommendation | Black | 7.1
| | Other | 8.3
| | AJCC stage
| | I | 19.2
| | II | 36.2
| | III | 25.6
| | IV | 13.9
| | Unstaged | 5.1
| | Romano Charlson
| | comorbid
| | 0 | 65.2
| | 1 | 24.3
| | 2 | 10.5
| | By hospital volume (figures are numbers or %)
| | | Low | Med | High | Very high
| | Total patients | 6,837 | 7,105 | 6,947 | 7,097
| | Total hospitals | 440 | 89 | 51 | 31
| | Sex
| | Male | 44.9 | 44.9 | 45.6 | 44.0
| | Female | 55.1 | 55.1 | 54.4 | 56.0
| | Age
| | 65–69 | 20.8 | 18.9 | 19.2 | 19.2
| | 70–74 | 23.9 | 24.0 | 23.2 | 23.9
| | 75–79 | 22.1 | 23.3 | 24.1 | 23.3
| | 80+ | 33.2 | 33.8 | 33.6 | 33.7
| | Race
| | White | 80.3 | 83.6 | 86.1 | 88.4
| | Black | 7.1 | 7.2 | 5.5 | 8.6
| | Other | 12.6 | 9.2 | 8.4 | 3.0
| | AJCC stage
| | I | 18.0 | 18.4 | 20.0 | 20.4
| | II | 35.5 | 36.3 | 35.5 | 37.5
| | III | 24.8 | 26.3 | 25.0 | 26.1
| | IV | 13.9 | 13.6 | 14.4 | 13.6
| | Unstaged | 7.8 | 5.3 | 5.0 | 2.5
| | Romano Charlson comorbid
| | 0 | 64.8 | 64.8 | 65.5 | 65.9
| | 1 | 24.4 | 24.6 | 24.3 | 23.8
| | 2 | 10.8 | 10.6 | 10.2 | 10.3
| | Geographic location: U.S.
| | Dates: 1991-1996
| | Healthcare setting: All U.S.
| | Results:
| | Adjusting for age, sex, race, cancer stage, comorbid illness, socioeconomic status, and acuity of hospitalization, very high-volume hospitals had a lower 30-day mortality than low-volume hospitals. A consistent association between higher postoperative mortality and lower surgical volume was evident; this persisted after inclusion of potential confounders. This association was evident for stages I-III, but not for patients with stage IV or unstaged disease (due to smaller sample sizes). The survival curves illustrate a clear association between procedure volume and overall survival.
| | The difference in 5-year mortality for patients operated on at very high- vs. low-volume hospitals was 4.4%.
Schrag, Panageas, Riedel, et al., 2002 | Quality measure (QM): 30-day mortality rate | Study population: | | | | | General comments: None
#17000 | Basis of QM: None | N: 2,815 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 4
| Type of QM: | Stage | %
| (a) Outcome | I | 30
| (b) General | II | 28
| Intent of QM: Research (aim of the study was to compare surgeon and hospital procedure volume as predictors of outcomes for patients with rectal cancer) | III | 29
| Definition of denominator/numerator: | IV | 8
| Denominator: | Unstaged | 5
| Number of Medicare patients undergoing rectal cancer surgery for a primary tumor diagnosed in 1992-1996 in a SEER area. | Age
| Exclusion criteria: Excluded patients with cancers arising in the rectosigmoid; had tumors with a predominant squamous cell component that could have been anal in origin; HMO enrollees; with diagnoses noted exclusively on death certificates or at autopsy; where the month of diagnosis was unknown. | 65–69 | 25
| Numerator: | 70–74 | 27
| Number of above patients who died within 30 days of rectal sphincter-sparing surgery. | 75–79 | 23
| Patient data were case -adjusted based on age, sex, race, disease stage, comorbidity, socioeconomic status and whether surgery was emergent. | 80–84 | 16
| Data sources: SEER, Medicare claims | 85+ | 9
| Recommended frequency of data collection: No recommendation | Male/female | 54/46
| | Race
| | White | 86
| | Black | 4
| | Other | 10
| | Comorbidity
| | 0 | 67
| | 1 | 25
| | 2+ | 8
| | Nonemergent admit | 91
| | Geographic location: U.S.
| | Dates: 1992-1996
| | Healthcare setting: All
| | Results:
| | Hospitals and surgeons were ranked by their volumes as very low, low, medium and high. There was no statistically significant association between 30-day mortality and hospital or surgeon volume.
| | Over the longer term, differences in surgical outcomes emerged 2 years following resection; these differences were significant and persisted after adjusting for differences in baseline patient characteristics. However, hospital procedure volume ceased to become a significant predictor of outcomes once surgeon procedure volume had been considered. Surgeon-specific procedure volume remained important as a predictor of outcome after adjusting for differences in hospital procedure volume.
| | Hospital Procedure volume | 30-day mortality (%)
| | Very low | 3.9
| | Low | 4.0
| | Medium | 2.4
| | High | 3.3
| | P-value | 0.79
| | Surgeon procedure volume
| | Very low | 4.3
| | Low | 3.7
| | Medium | 3.5
| | High | 1.7
| | P-value | 0.20
| Quality measure (QM): Abdominoperineal (APR) resection rate | Study population:
| Basis of QM: None | N: 2,815
| Type of QM: | Stage | %
| (a) Process | I | 30
| (b) General | II | 28
| Outcome to which the QM is linked: Mortality | III | 29
| Intent of QM: Research (aim of the study was to compare surgeon and hospital procedure volume as predictors of outcomes for patients with rectal cancer) | IV | 8
| Definition of denominator/numerator: | Unstaged | 5
| Denominator: | Age
| Number of Medicare patients undergoing rectal cancer surgery for a primary tumor diagnosed in 1992-1996 in a SEER area. | 65–69 | 25
| Exclusion criteria: Excluded patients with cancers arising in the rectosigmoid; had tumors with a predominant squamous cell component that could have been anal in origin; HMO enrollees; with diagnoses noted exclusively on death certificates or at autopsy; where the month of diagnosis was unknown. | 70–74 | 27
| Numerator: | 75–79 | 23
| Number of above patients for whom surgeons performed abdominoperineal surgery. | 80–84 | 16
| Patient data were case -adjusted based on age, sex, race, disease stage, comorbidity, socioeconomic status and whether surgery was emergent. | 85+ | 9
| Data sources: SEER, Medicare claims | Male/female | 54/46
| Recommended frequency of data collection: No recommendation | Race
| | White | 86
| | Black | 4
| | Other | 10
| | Comorbidity
| | 0 | 67
| | 1 | 25
| | 2+ | 8
| | Nonemergent admit | 91
| | Geographic location: U.S.
| | Dates: 1992-1996
| | Healthcare setting: All
| | Results:
| | APR rates were compared by providers with different case volumes. After case-mix adjusting, the association was not significant, and was further attenuated when adjusted for surgeon volume, p = 0.15.
| | Hospital Procedure volume | APR rate (%)
| | Very low | 51
| | Low | 53
| | Medium | 49
| | High | 44
| | P-value | 0.04
| | Surgeon procedure volume
| | Very low | 49
| | Low | 54
| | Medium | 51
| | High | 44
| | P-value | 0.15
Schrag, Panageas, Riedel, et al., 2003 | Quality measure (QM): 30-day mortality rate | Study population: | | | | | General comments:
#34030 | Basis of QM: None stated | N = 24,166 | | | | | 2-year postoperative mortality/survival was also assessed.
| Type of QM: | Characteristic | Percent | | | | Study claims that it cannot explain specific processes of care that can account for differences in mortality rates in the various hospitals.
| (a) Outcome | Male/female | 44.1/55.9 | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 4
| (b) General | Age
| Intent of QM: Quality improvement (aim of the study was to compare surgeon and hospital procedure volume as predictors of outcomes following colon cancer resection) | 65–69 | 18.6
| Definition of denominator/numerator: | 70–74 | 23.6
| Denominator: | 75–79 | 23.6
| Number of Medicare eligible patients aged 65 or older diagnosed in SEER regions with primary colon cancer in 1991-1996. | 80+ | 34.2
| Exclusion criteria: Excluded were patients enrolled in an HMO; operated on exclusively for intestinal bypass; diagnosis noted exclusively on death certificate or at autopsy; month of death was unknown. | Race
| Numerator: | White | 87.1
| Number of above patients who died within 30 days of operation (not clearly defined). | Black | 6.6
| Adjustment was made for sex, race, age, stage of tumor, comorbidity and socioeconomic status, whether hospitalization was emergent and whether obstruction or perforation was present. | other | 6.3
| Data sources: SEER, Medicare claims from HCFA | AJCC stage I | 19.9
| Recommended frequency of data collection: No recommendation | II | 36.9
| | III | 26.1
| | IV | 14.1
| | Unstaged | 3.0
| | Romano comorbidity
| | 0 | 71.3
| | 1 | 23.2
| | 2 | 5.6
| | Obstruction (Y/N) | 9.0/91.0
| | Emergent hospitalization (Y/N) | 19.8/80.2
| | Geographic location: U.S.
| | Dates: 1991-1996
| | Healthcare setting: All
| | Results:
| | After adjusting for surgeon procedure volume, high hospital procedure volume remained a strong predictor of low postoperative mortality. Surgeon-specific procedure volume was also an important predictor of surgical outcomes although this effect was attenuated after adjusting for hospital volume.
| | Hospital procedure volume | 30-day mortality rate%
| | Very low | 5.8
| | Low | 4.6
| | Medium | 4.1
| | High | 3.7
| | P-value | < 0.0001
| | Surgeon procedure volume
| | Very low | 5.7
| | Low | 4.6
| | Medium | 4.2
| | High | 3.7
| | P-value | < 0.0001
| Quality measure (QM): Ostomy rates | Study population:
| Basis of QM: Clinical practice guideline (not specified) | N = 24,166
| Type of QM: | Characteristic | Percent
| (a) Process | Male/female | 44.1/55.9
| (b) General | Age
| Outcome to which the QM is linked: Mortality | 65–69 | 18.6
| Intent of QM: Quality improvement (aim of the study was to compare surgeon and hospital procedure volume as predictors of outcomes following colon cancer resection) | 70–74 | 23.6
| Definition of denominator/numerator: | 75–79 | 23.6
| Denominator: | 80+ | 34.2
| Number of Medicare eligible patients aged 65 or older diagnosed in SEER regions with primary colon cancer in 1991-1996. | Race
| Exclusion criteria: Excluded were patients enrolled in an HMO; operated on exclusively for intestinal bypass; diagnosis noted exclusively on death certificate or at autopsy; month of death was unknown. | White | 87.1
| Numerator: | Black | 6.6
| Number of above patients who had an ostomy. | other | 6.3
| Adjustment was made for sex, race, age, stage of tumor, comorbidity and socioeconomic status, whether hospitalization was emergent and whether obstruction or perforation was present. | AJCC stage I | 19.9
| Data sources: SEER, Medicare claims from HCFA | II | 36.9
| Recommended frequency of data collection: No recommendation | III | 26.1
| | IV | 14.1
| | Unstaged | 3.0
| | Romano comorbidity
| | 0 | 71.3
| | 1 | 23.2
| | 2 | 5.6
| | Obstruction (Y/N) | 9.0/91.0
| | Emergent hospitalization (Y/N) | 19.8/80.2
| | Geographic location: U.S.
| | Dates: 1991-1996
| | Healthcare setting: All
| | Results:
| | Hospital volumes and surgeon volumes were each an important predictor of the ostomy rate.
| | Hospital procedure volume | Ostomy rate (%)
| | Very low | 19.6
| | Low | 18.5
| | Medium | 16.4
| | High | 15.8
| | P-value | < 0.0001
| | Surgeon procedure volume
| | Very low | 19.4
| | Low | 18.4
| | Medium | 17.2
| | high | 15.3
| | P-value | < 0.0001
Simons, Ker, Groshen, et al., 1997 | Quality measure (QM): Rate of sphincter-sparing procedures (SSP) | Study population: | | | | | General comments: None
#11620 | Basis of QM: None | N: 2,006 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 3
| Type of QM: | Age: 68 median age (19–102)
| (a) Process | Race: NR
| (b) General | Sex: 55% male
| Outcome to which the QM is linked: Sphincter preservation | Other: 125 hospitals
| Intent of QM: Research (aim of the study was to examine variation in the surgical treatment of rectal cancer to determine if differences exist in management and survival based on hospital type and surgical caseload) | % patients with localized disease: 52%
| Definition of denominator/numerator: | Geographic location: California
| Denominator: | Dates: 1988-1992
| Number of patients who underwent sphincter-sparing procedures (SSP) or abdominoperineal resection (APR) for rectal adenocarcinoma between 1988 and 1992. | Healthcare setting: inpatient hospital setting
| Numerator: | Results:
| Number of above patients who underwent SSP. | Hospitals treating patients with localized disease that perform > 5 rectal cancer surgeries per year performed SSP more frequently (69% of cases) compared to hospitals performing 5 or fewer rectal cases per year (63% of cases). For regional disease, the difference was not statistically significant.
| Data sources: University of Southern California Cancer Surveillance Program (CSP), a population based cancer registry. This is part of a national SEER. The CSP provided patient age, gender, date of surgery, type of surgery, tumor stage, hospital type, status and date at last follow up. | Survival plots showed that a significantly higher percentage of patients (localized and regional disease) survived 5 years when operated on at a hospital performing > 5 rectal cancer surgeries a year.
| Recommended frequency of data collection: No recommendation
Steele, 1994 | Quality measure: Percentage of stage III colon cancer patients receiving surgery and chemotherapy | Study population: | | | | | General comments:
#35840 | Basis of QM: Clinical practice guideline | Data given as patients (year) | | | | | Some “treatment” data are presented, but these are not stratified by stage or location (colon vs. rectum) and therefore do not provide sufficient information to count as a QM. Only survival would be a potential QM from this paper.
| It is implicit that the AHCC guidelines be followed but these are not actually cited in the article. | N: 40,384 (85/86); 39,751 (91) | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance:; - Usability; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| Type of QM: | Age: Median 71.3 (85/85); 72.0 (91)
| (a) Process | Race:
| (b) General | Non-Hispanic whites 86.9% (85/85); 85.9% (91)
| Outcome to which the QM is linked: No outcome is exactly linked to the above but is said to be a marker of appropriate cancer diagnosis and treatment. No citation is provided for this statement. | Hispanic 1.1/1.8
| Intent of QM: Not specified (aim of the study was assess cancer patient care and outcomes on a national basis) | African-American 6.6/8.1
| Definition of denominator/numerator: | Asian 0.9/1.5
| Denominator: | Unknown 4.5/2.7
| Number of patients in the National Cancer Data Base (NCDB) with a new diagnosis of colon cancer in the years 1985-1986 or 1991. | Sex: Male 48.7% (85/85), 49.6% (91)
| Numerator: | Tumor stage: 85–86/91
| Number of the above with stage III cancer who underwent surgery and received chemotherapy. | 0 3.7/6.5
| Data sources: National Cancer Data Base (NCDB) | 1 14.4/19.3
| Recommended frequency of data collection: No recommendation | 2 13.8/26.2
| | 3 12.9/20.3
| | 4 9.2/15.8
| | Unknown 46.0/11.9
| | Performance status: NR
| | Geographic location: National sample; note that the sample is not probabilistic and represented different hospitals in different years
| | Dates: 1991 and outcomes for 1985-86
| | Healthcare setting: 464 hospital in 1985, 474 hospitals in 1986, 937 hospitals in 1991
| | Results:
| | Treatment trends showed effects of trial data, as a greater percentage of patients were reported as having treatment (including chemotherapy) beyond surgery in 1991 as compared to 1985/86.
Temple, Hsieh, Wong, et al., 2004 | Quality measure (QM): 30-day postoperative mortality rate for stage IV colon cancer | Study population: | | | | | General comments:
#29890 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network; applicable only for stage IV and symptomatic patients) | N: 9,011 | | | | | Patient selection was accomplished in a non-randomized setting. Therefore, results are not valid. Study could not ascertain whether patients were asymptomatic at presentation (elderly patients could present with advanced stage disease.)
| Type of QM: | | Pct. | Primary CDS% | No primary CDS% | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 2; - Adequacy of risk adjustment: 2
| (a) Outcome | Age
| (b) General | 65–69 | 21 | 22 | 18
| Intent of QM: Quality improvement (aim of the study was to evaluate surgical practice patterns for patients 65 years of age and older with stage IV colorectal cancer) | 70–74 | 25 | 26 | 22
| Definition of denominator/numerator: | 75–79 | 23 | 23 | 24
| Denominator: | 80–84 | 18 | 17 | 19
| Number of Medicare-enrolled patients aged 65 and older, initially diagnosed with stage IV colon or rectal cancer in a SEER area during the years 1991-1999. Age, sex, race, ethnicity, comorbidity, year of diagnosis, and socioeconomic status were collected and data were risk-adjusted. | ≥85 | 13 | 12 | 18
| Exclusion criteria: Cohort restricted to those with a histologic diagnosis consistent with adenocarcinoma. Diagnoses exclusively on death certificates or at autopsy were excluded, as were those in which the month of diagnosis was unknown. Patients enrolled in HMOs were excluded. | Male/female | 48/52 | 48/52 | 49/51
| Numerator: | White | 84 | 85 | 81
| Number of above patients who died 30 days following surgery. | Black | 9 | 9 | 12
| Data sources: SEER, Medicare claims | Other | 7 | 7 | 7
| Recommended frequency of data collection: No recommendation | Comorbidity
| | 0 | 90 | 90 | 89
| | 1 | 5 | 5 | 6
| | 2+ | 5 | 4 | 5
| | 1999 | 9 | 9 | 10
| | Geographic location: U.S.
| | Dates: 1991-1999
| | Healthcare setting: Inpatient hospital
| | Results:
| | The 30-day surgical mortality was significantly greater in the no cancer-directed surgery group among patients who underwent a surgical procedure, when compared with the primary cancer-directed surgery group (26% vs 9%; P = 0.001).
| Quality measure (QM): Metastasectomy rate | Study population: | | | | | General comments:
| Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network) | N: 9,011 | | | | | Patient selection was accomplished in a non-randomized setting. Therefore, results are not valid. Study could not ascertain whether patients were asymptomatic at presentation (elderly patients could present with advanced stage disease.)
| Type of QM: | | Pct. | Primary CDS% | No primary CDS% | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 3; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 2; - Adequacy of risk adjustment: 2
| (a) Process | Age
| (b) General | 65–69 | 21 | 22 | 18
| Outcome to which the QM is linked: Practice patterns of patients with stage IV cancer | 70–74 | 25 | 26 | 22
| Intent of QM: Quality improvement (aim of the study was to evaluate surgical practice patterns for patients 65 years of age and older with stage IV colorectal cancer) | 75–79 | 23 | 23 | 24
| Definition of denominator/numerator: | 80–84 | 18 | 17 | 19
| Denominator: | ≥85 | 13 | 12 | 18
| Number of Medicare-enrolled patients aged 65 and older, initially diagnosed with stage IV colon or rectal cancer in a SEER area during the years 1991-1999. Age, sex, race, ethnicity, comorbidity, year of diagnosis, and socioeconomic status were collected and data were risk-adjusted. | Male/female | 48/52 | 48/52 | 49/51
| Exclusion criteria: Cohort restricted to those with a histologic diagnosis consistent with adenocarcinoma. Diagnoses exclusively on death certificates or at autopsy were excluded, as were those in which the month of diagnosis was unknown. Patients enrolled in HMOs were excluded. | White | 84 | 85 | 81
| Numerator: | Black | 9 | 9 | 12
| Number of above patients who received liver resection, pelvic exenteration and pulmonary resection between diagnosis and death. | Other | 7 | 7 | 7
| Data sources: SEER data base, Medicare claims data | Comorbidity
| Recommended frequency of data collection: No recommendation | 0 | 90 | 90 | 89
| | 1 | 5 | 5 | 6
| | 2+ | 5 | 4 | 5
| | 1999 | 9 | 9 | 10
| | Geographic location: U.S.
| | Dates: 1991-1999
| | Healthcare setting: Inpatient hospital
| | Results:
| | Metastasectomy was performed in only 3.9% of the patients in the total cohort of 9,011 having received either synchronous or metachronous pulmonary resection, hepatectomy, or pelvic exenteration. Among those who underwent primary cancer-directed surgery, 5.2% had metastasectomy, the vast majority being liver resections.
| Quality measure (QM): Cancer-directed surgery (CDS) rate | Study population: | | | | | General comments:
| Basis of QM: Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network) | N: 9,011 | | | | | Patient selection was accomplished in a non-randomized setting. Therefore, results are not valid. Study could not ascertain whether patients were asymptomatic at presentation (elderly patients could present with advanced stage disease.)
| Type of QM: | | % | Primary CDS (%) | No primary CDS (%) | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 2; - Adequacy of risk adjustment: 2
| (a) Process | Age
| (b) General | 65–69 | 21 | 22 | 18
| Outcome to which the QM is linked: Reduced mortality | 70–74 | 25 | 26 | 22
| Intent of QM: Quality improvement (aim of the study was to evaluate surgical practice patterns for patients 65 years of age and older with stage IV colorectal cancer) | 75–79 | 23 | 23 | 24
| Definition of denominator/numerator: | 80–84 | 18 | 17 | 19
| Denominator: | ≥85 | 13 | 12 | 18
| Number of Medicare-enrolled patients aged 65 and older, initially diagnosed with stage IV colon or rectal cancer in a SEER area during the years 1991-1999. Age, sex, race, ethnicity, comorbidity, year of diagnosis, and socioeconomic status were collected and data were risk-adjusted. | Male/female | 48/52 | 48/52 | 49/51
| Exclusion criteria: Cohort restricted to those with a histologic diagnosis consistent with adenocarcinoma. Diagnoses exclusively on death certificates or at autopsy were excluded, as were those in which the month of diagnosis was unknown. Patients enrolled in HMOs were excluded. | White | 84 | 85 | 81
| Numerator: | Black | 9 | 9 | 12
| Number of above patients who received CDS subsequent to diagnosis. This included patients having received bowel resection, or evidence of primary tumor resection; surgery of primary sites within the first 4 months of diagnosis. | Other | 7 | 7 | 7
| Data sources: SEER database, Medicare claims data | Comorbidity
| Recommended frequency of data collection: No recommendation | 0 | 90 | 90 | 89
| | 1 | 5 | 5 | 6
| | 2+ | 5 | 4 | 5
| | 1999 | 9 | 9 | 10
| | Geographic location: U.S.
| | Dates: 1991-1999
| | Healthcare setting: Inpatient hospital
| | Results:
| | 72% of cohort received CDS within 4 months of diagnosis. CDS rates declined with age.
| | Median survival of CDS patients was 10 months compared to non-CDS patients (3 months).
Tropman, Hatzell, Paskett, et al., 1999 | Quality measure (QM): Percentage of patients receiving appropriate primary therapy (wide surgical resection and anastomosis) for CRC as defined by the NCI PDQ guidelines | Study population: | | | | | General comments:
#35610 | Basis of QM: Clinical practice guideline (NCI PDQ Guidelines) | N: 230 | | | | | The article compares rates of compliance with NCI PDQ recommendations in two rural geographic regions (one in NC, one in SC) before (1991) and after (1996) an intervention to educate local physicians. The intervention took place in NC. The SC region served as a control.
| Type of QM: | All stages | 1991 | 1996 | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 3
| (a) Process | Male (%) | 55 | 58
| (b) General | White | 76 | 75
| Outcome to which the QM is linked: Locoregional recurrence, overall survival. | AA | 24 | 25
| Intent of QM: Not specified (aim of the study was to determine the degree to which colon cancer treatment in rural North and South Carolina conformed to national treatment recommendations) | Mean age | 75 | 71
| Definition of denominator/numerator: | Tumor stage
| Denominator: | I | 64 | 36
| Number of patients treated for colon cancer in Wayne County, NC, and its six contiguous counties or in Greenwood County, SC, and its four adjacent counties during the years 1991 and 1996. Cases were identified by the North Carolina Central Cancer Registry and by local tumor registrars in SC. | II | 56 | 44
| Numerator: | III | 65 | 35
| Subset of patients above who received primary (surgery) per the NCI PDQ recommendations. | Performance status: NR
| Data sources: Patient medical records and records from physician offices in the geographic regions under study | Geographic location: Wayne County, NC, and its six contiguous counties or in Greenwood County, SC, and its four adjacent counties
| Recommended frequency of data collection: No recommendation | Dates: 1991, 1996
| | Healthcare setting: Rural health care facilities
| | Results:
| | A majority (80–95%) of patients received appropriate primary therapy, with the exception of SC stage I cases, who had lower rates of appropriate primary therapy (73% in 1991 and 50% in 1996).
Vernon, Hughes, Heckel, et al., 1992 | Quality measure (QM): Number of colorectal cancer patients that receive surgery as part of primary treatment of colorectal cancer | Study population: | | | | | General comments:
#5670 | Basis of QM: None stated | FFS/HMO plans | | | | | The purpose of this paper was to compare “the effectiveness” of two types of health plans (FFS and HMO) offered by the same health care provider in the diagnosis and treatment of colon cancer. The two plans were compared for some measures which may be considered quality measures, but which may have other explanations for their frequency. These include: duration of symptoms before diagnosis, training of physicians who diagnosed the tumor, presence of symptoms at diagnosis, time from detection to treatment, number of treatments, Dukes stage at diagnosis, and survival. Some measures would not be quality measures.
| Type of QM: | N: 205/125 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 5; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Structure | Age: < 50 to ≥ 60
| (b) General | Race: NR
| Outcome to which the QM is linked: Presumably to improved survival | Sex: 56% male/61% male
| Intent of QM: Not specified (aim of the study was to compare the quality of cre for two types of health plans - fee-for-service [FFS] with third-party coverage and HMO membership - in the diagnosis and treatment of colorectal cancer) | Tumor stage: NR
| Definition of denominator/numerator: | Performance status: NR
| Denominator: | Geographic location: Texas
| Number of patients with colorectal cancer diagnosed from 1984 through 1989 at the Kelsey-Seybold Clinic in Houston, TX, of whom 205 used a fee-for-service (FFS) plan and 125 were members of an HMO. | Dates: 1984-89
| Numerator: | Healthcare setting: A multispecialty group practice
| Number of above patients who received surgery as part of their primary treatment. | Results:
| Data sources: Medical records of patients | 82% of FFS patients had surgery compared with 81% of HMO patients. Survival was not different for the two groups.
| Recommended frequency of data collection: No recommendation
Weaver, Harrison, Eskander, et al., 1991 | Quality measure (QM): Percentage of patients with CRC who underwent surgical resection | Study population: | | | | | General comments:
#6810 | Basis of QM: None stated | N: 118 | | | | | Mortality was the primary endpoint of the study and the data for other potential QMs (% received surgery) are much weaker, poorly defined, and do not follow guidelines
| Type of QM: | Age: mean 68 (29–93) | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 3
| (a) Process | Race: 100% black
| (b) General | Sex: 62% female
| Outcome to which the QM is linked: Mortality | Tumor stage:
| Intent of QM: Not specified (aim of the study was to determine if demographic observations were similar in an all-black institution with patients from all socioeconomic levels) | I 4
| Definition of denominator/numerator: | Ib 2
| Denominator: | II 22
| Number of patients with a diagnosis of colorectal cancer between 1971 and 1982 in the tumor registry databases at a single institution (Meharry). | III 36
| Numerator: | IV 32
| Number of the above patients who underwent “surgical intervention.” | Missing 22
| Data sources: Hospital tumor registry, hospital medical records | Geographic location: Nashville, TN
| Recommended frequency of data collection: No recommendation | Dates: 1971-1982 (retrospective review) + 5 years of followup (?1987)
| | Healthcare setting: Single predominantly black hospital (with University affiliation)
| | Results:
| | NA
Whittle, Steinberg, Anderson, et al., 1991 | Quality measure (QM): Perioperative mortality rate | Study population: | | | | | General comments:
#5450 | Basis of QM: None | N: 5,586 | | | | | The observed difference between patient age and sex and postoperative outcomes can be explained by factors not considered in the analysis. Differences in age and sex and stage of disease at time of presentation, level of comorbidity, or frequency of emergency presentation, all strongly affect perioperative mortality and postoperative survival rates.
| Type of QM: | Age | % male | % female | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Outcome | 66–69 | 15 | 12
| (b) General | 70–74 | 30 | 25
| Intent of QM: Research (aim of the study was to estimate the perioperative mortality and 1- and 2-year survival rates of elderly Americans undergoing colon resection for colon cancer) | 75–84 | 44 | 46
| Definition of denominator/numerator: | 85+ | 11 | 17
| Denominator: | Geographic location: U.S.
| Number of beneficiaries > 65 yr discharged during 1983-1985 with an ICD-9 code for colon cancer as primary or secondary diagnosis and ICD-9 code for colon resection listed during the same hospitalization. | Dates: 1983-1985
| Exclusion criteria: Beneficiaries who first became eligible for Medicare because of end-stage renal disease or disability, members of an HMO, beneficiaries living overseas, non participants in Part B. | Healthcare setting: All
| Numerator: | Results:
| Number of above patients who died within 30 days of admission, controlling for age, sex. | Age, but not sex, was significantly associated with 1- and 2-year postoperative mortality. Decreases in survival in older age groups remained statistically significant at 1 yr (p < 0.0001) and 2 yr (p = 0.01) after adjusting for differences in life expectancy among age groups.
| Data sources: Medicare Part A claims and enrollment records | Age | % male | % female | Peri-operative mortality
| Recommended frequency of data collection: No recommendation | 66–69 | 15 | 12 | 3.35
| | 70–74 | 30 | 25 | 3.65
| | 75–84 | 44 | 46 | 6.67
| | 85+ | 11 | 17 | 11.1
Wudel Jr., Chapman, Shyr, et al., 2002 | Quality measure (QM): Percentage of patients with colon or rectal cancer who had curative resection | Study population: | | | | | General comments:
#18640 | Basis of QM: None stated | | University hospital | City hospital | | | Mortality was the primary endpoint of the study and the data for other potential QMs (% receiving “curative” surgery, chemo, or radiation therapy) are much weaker, poorly defined, and do not follow guidelines
| Type of QM: | N | 565 | 77 | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 5; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 3
| (a) Process | Black (%) | 10.6 | 53
| (b) General | Male (%) | 53.3 | 62.7
| Outcome to which the QM is linked: Mortality | Median age | 69 | 74
| Intent of QM: Not specified (aim of the study was to determine the outcome of patients with colorectal cancer treated in the same city at 2 nearby medical centers, a university hospital and a city hospital, and to explore disparities in colorectal cancer outcomes between black and white patients) | Tumor stage
| Definition of denominator/numerator: | I | 31.7 | 29.9
| Denominator: | II | 21.9 | 20.8
| Number of patients with a diagnosis of primary colorectal cancer between 1/1/90 and 12/21/99 in the tumor registry databases at each of 2 institutions (university hospital and a city hospital). Excluded patients who were non-white and non-black. | III | 23.7 | 16.9
| Numerator: | IV | 22.7 | 32.5
| Number of the above patients who received “curative surgery “defined as surgery performed in the absence of documented distant spread. | Performance status: NR
| Data sources: Hospital tumor registries | Geographic location: Nashville, TN
| Recommended frequency of data collection: No recommendation | Dates: 1/1/90 and 12/21/99 (retrospective review)
| | Healthcare setting: University hospital, city hospital
| | Results:
| | There was no significant difference in tumor stage at the time of presentation in the two institutions studied or between racial/ethnic groups. There was no difference in the treatment modalities identified between institutions or racial/ethnic groups.
| | There was a significant difference in overall survival between patients treated at the university hospital (median 5.3 years) and those treated at the city hospital (median 2.1 years). Median survival was 5.7 years for white patients and 3.2 years for black patients treated at the university hospital. White patients treated at the city hospital survived 2.1 years vs. 1.4 years for black patients.

Evidence Table 6 - Question 2b (Grey Literature): As appropriate to specific stages of colorectal cancer, what quality-of-care measures are available and what evidence is available for measures of quality of care of treatment of colorectal cancer, including surgical therapy for colon and rectal cancers?

Study | Characteristics of Quality Measure | Comments/Quality Scoring
National Committee for Quality Assurance, 2005 | Quality measure (QM): Percent of rectal cancer cases that received a sphincter preservation procedure at time of surgery | General comments:
#36580 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Not all data may be available.
| Type of QM: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | - Importance: 5; - Usability: 5; - acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| (b) Technical
| Outcome to which the QM is linked: improved QoL
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients with rectal cancer surgery over a 12-month period.
| Numerator:
| Number of above patients who received a sphincter preservation procedure at time of surgery.
| Data sources: Cancer registry, claims data
| Recommended frequency of data collection: No recommendation

Evidence Table 7 - Question 2c (Published Literature): As appropriate to specific stages of colorectal cancer, what quality-of-care measures are available and what evidence is available for measures of quality of care of treatment of colorectal cancer, including appropriate use of adjuvant chemotherapy and adjuvant radiation therapy, including for patients with metastatic but potentially curable (hepatic/pulmonary-resectable) disease?

Study | Characteristics of Quality Measure | Testing of Quality Measure | | | | | Comments/Quality Scoring
Ayanian, Zaslavsky, Fuchs, et al., 2003 | Quality measure (QM): Use of adjuvant chemotherapy in patients with stage III colon cancer or stage II or III rectal cancer | Study population: | | | | | General comments:
#346800 | Basis of QM: Other (adherence to the recommenda-tions of the 1990 NIH Consensus Conference) | Eligible for chemo: | | | | | Article attempts to estimate underreporting of adjuvant therapies in routinely collected registry data by comparing registry data with office records and physician surveys.
| Type of QM: | N: 1,956 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 4
| (a) Process | Age: 18 to > 85
| (b) General | Race: 72.9% white
| Outcome to which the QM is linked: Improved survival and decreased local/regional recurrence | Sex: 50.2% female
| Intent of QM: Not specified (aim of the study was to assess the use of adjuvant chemotherapy and radiation therapy in patients with stage III colon cancer) | Tumor stage: Colon stage III 72.7%, Rectal stage III 12.8%, Rectal stage II 14.5%
| Definition of denominator/numerator: | Performance status: 60.7% comorbidity score 0, 20.1% 1, 19.2% ≥ 2
| Denominator: | Geographic location: San Francisco/Oakland, San Jose/Monterey, and Sacramento, CA areas
| Number of patients identified from registry records (3 regional registries within the California Cancer Registry) who were 18 years of age and older diagnosed during 1996 and 1997 with stage IIII adenocarcinoma of the colon or stage II or III adenocarcinoma of the rectum, using staging criteria of the AJCC. Patients had undergone surgery and survived for at least 30 days. | Dates: 1996-97
| Numerator: | Healthcare setting: Hospitals
| Number of above patients with colon or rectal cancer who received adjuvant chemotherapy. | Results:
| Data sources: | 67% of eligible patients received adjuvant chemotherapy.
| California Cancer Registry | Sensitivity of routinely collected registry data was 87% for chemotherapy. Only 2% of patients had registry data indicating they had received chemo but were reported by their physicians not to have received therapy.
| Physician survey | On MVA, older patients significantly less likely to receive chemo.
| Office records | In hierarchical models including random effects of individual hospitals, use of chemotherapy varied substantially. Relative to the 67% of patients receiving chemotherapy in the full cohort, the adjusted probability of getting chemo was 79% in hospitals, moderately (one SD) above average, and 51% in hospitals, moderately below average.
| Recommended frequency of data collection: No recommendation. | Most common reasons cited for not giving adjuvant therapy: patient refusal, comorbid illness, lack of clinical indication.
Beart, Steele Jr., Menck, et al., 1995 | Quality measure (QM): Percentage of patients with stage III colon cancer receiving postoperative chemotherapy | Study population: | | | | | General comments: The data for this study were generated prior to 1990 so it may not reflect more modern recommendations for management.
#990 | Basis of QM: None mentioned; however, consistent with 1990 NIH consensus conference | N: 39,502 (29,209 with colon cancer; 3599 with stage III) | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 2
| Type of QM: | Age: Median 72 years for colon cancer
| (a) Process | Race: For entire study: African American, 9.1% for colon cancer and 6.5% for rectal cancer; Hispanic, 2.7% for colon cancer and 3.5% for rectal cancer. 1.4% of cases were Asian. The rest were Caucasian.
| (b) General | Sex: Male 49.3% (colon) and 57.2% (rectal)
| Outcome to which the QM is linked: None specified, but presumably survival | Tumor stage: All included (4.7% stage 0, 22.1% stage I, 29.2% stage II, 22.2% stage III, 18.7% stage IV, 3.0% unknown)
| Intent of QM: Not specified (aim of the study was to identify current trends in the management of patients with carcinoma of the colon or rectum and to identify changes in patterns of care and survival) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Entire U.S.
| Denominator: | Dates: Calendar years 1983 and 1988
| Number of stage III colon cancer patients seen in 1988 from amongst cases of colon and rectal cancer (up to 25 per program or facility) reported by over 1200 approved cancer programs and 800 other facilities on the Commission on Cancer mailing list that were invited to participate. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of above patients receiving chemotherapy. | | Colon Cancer | | Rectal Cancer
| Data sources: Hospitals sent in up to 25 consecutive cases from their medical records | | 1983 | 1988 | 1985 | 1988
| Recommended frequency of data collection: No recommendation | Chemotherapy | 10.7 | 11.1 | 5.9 | 5.6
| | Radiation therapy | 2.7 | 10.9 | 15.3 | 13.8
| | Combined chemo and radiation therapy | 1.5 | 1.6 | 5.5 | 10.1
| | Study population:
| | N: 39,502 (10,293 with rectal cancer; 2051 with stage II or III)
| | Age: median 69.3 years for rectal cancer
| | Race: For entire study: African American, 9.1% for colon cancer and 6.5% for rectal cancer; Hispanic 2.7% for colon cancer and 3.5% for rectal cancer. 1.4% of cases were Asian. The rest were Caucasian.
| | Sex: Male 57.2% (rectal)
| | Tumor stage: All included (4.7% stage 0, 22.1% stage I, 29.2% stage II, 22.2% stage III, 18.7% stage IV, 3.0% unknown)
| | Performance status: NR
| | Geographic location: Entire U.S.
| | Dates: Calendar year 1983 and 1988
| | Healthcare setting: Hospitals
| | Results:
| | | Colon Cancer | | Rectal Cancer
| | | 1983 | 1988 | 1985 | 1988
| | Chemotherapy | 10.7 | 11.1 | 5.9 | 5.6
| | Radiation therapy | 2.7 | 10.9 | 15.3 | 13.8
| | Combined chemo and radiation therapy | 1.5 | 1.6 | 5.5 | 10.1
Coburn, Pricolo, and Soderberg, 1994 | Quality measure (QM): Adjuvant therapy rates | Study population: | | | | | General comments:
#2920 | Basis of QM: None | N: 800 | | | | | Data collected between 1961 and 1987.
| Type of QM: | | | | < 80 years | > 80 years | Other factors that affect mortality rates in the elderly: more aggressive biologic behavior of cancer of the colon and rectum in the elderly, with aggressive local disease and less tendency towards distant dissemination, greater tendency of colon cancer to be right-sided, rarity of adjuvant therapy administered to older patients, higher complication rate in elderly patients due to comorbid conditions, and greater frequency of obstructing and perforated lesions.
| (a) Process | N | | | 177 | 623 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 3; - Adaptability: 2; - Adequacy of risk adjustment: 2
| (b) General | Sex (%F/M) | | | 48/52 | 56/44
| Outcome to which the QM is linked: None | Rectal lesions | | | 36 | 23
| Intent of QM: Not specified (aim of the study was to perform univariate and multivariate analyses of poor indicators in the elderly undergoing colorectal operation, and to compare clinical, pathologic, and therapeutic factors in patients younger than and older than 80 years of age) | Duke stage
| Definition of denominator/numerator: | A | | | 9.0 | 6.0
| Denominator: | B1 | | | 16.7 | 12.8
| Number of subjects who had received operative treatment for colon and rectal cancer between 1961 and 1987. | B2 | | | 31.2 | 42.7
| Numerator: | C1 | | | 4.5 | 0
| Number of above subjects who received adjuvant therapy (chemo- or radiotherapy). | C2 | | | 21.5 | 21.8
| Comparisons were made between patients under and over 80 years. | D | | | 17.1 | 16.7
| Data sources: Inpatient, outpatient, and office records | Geographic location: Rhode Island, U.S.
| Recommended frequency of data collection: No recommendation | Dates: 1961 and 1987
| | Healthcare setting: Academic institute
| | Results:
| | Adjuvant therapy rate was 5.1% for patients > 80 yrs and 20% for patients < 80 yrs.
| | Long-term survival (at 5 and 8 yr) and rate of recurrence after curative therapy were used to validate the measure.
| | There was a statistically significant difference in survival rates: 48% for patients < 80 vs. 32% for patients > 80.
| | There was no statistically significant difference between the groups with regard to recurrence after curative therapy.
Coia, Wizenberg, Hanlon, et al., 1994 | Quality measure (QM): Percentage of patients receiving adjuvant radiation therapy who also received adjuvant chemotherapy (either concurrent or non-concurrent) for cancer of the sigmoid colon or rectum | Study population: | | | | | General comments:
#3140 | Basis of QM: Other (1990 NIH consensus guidelines) | N: 408 | | | | | This paper has many potential QMs in addition to the primary QM, which is use of chemotherapy with radiotherapy. Other QMs include: Percentage of those receiving > 40Gy radiation, percentage experiencing prolonged interruption of their radiotherapy, and percentage having chemotherapy scan as part of their evaluation.
| Type of QM: | Age: 64 (median) | | | | | A major limitation of this paper is the fact that the data surveyed were for patients treated in the years before the NIH consensus guidelines on chemoradiotherapy. Therefore, the quality measure is using data from a group which it may be inappropriate to use.
| (a) Process | Race: NR | | | | | Another limitation is that it selects all patients with rectosigmoid cancers who received radiotherapy. This included some patients with stage A, B1 disease who, under usual circumstances, would have no reason to receive radiotherapy. There may have been a reason not captured by the data for these patients to receive radiotherapy.
| (b) General and Technical | Sex: 61% male | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 4; - Adequacy of risk adjustment: 1
| Outcome to which the QM is linked: Overall survival | Tumor stage: A-C3 (Modified Astler-Coller System); A 0.6%, B1 4.4%, B2 23.5%, B3 5.1%, C1 6.9%, C2 30.1%, C3 6.6%, unknown 22.8%
| Intent of QM: Not specified (aim of the study was to determine the national practice standards for the evaluation and treatment of adenocarcinoma of the rectum and sigmoid colon) | Tumor location: Sigmoid 12.5%, rectum 82.8%, unknown 4.7%
| Definition of denominator/numerator: | Performance status: 98% KPS = 80 or higher
| Denominator: | Geographic location: U.S.
| Number of subjects identified from data source who were treated 1998-1999 with radiation therapy for rectal/ and sigmoid adenocarcinoma. | Dates: Patients treated 1988-89
| Numerator: | Healthcare setting: 73 U.S. institutions
| Number of above subjects receiving chemotherapy in addition to radiation therapy for T3N+ disease. | Results:
| Data sources: Random sample of all patients in the U.S. with rectal or sigmoid colon cancer identified in a stratified two-stage cluster sampling procedure. First stage: selection of facilities from all facilities in the U.S. based on census data from a facilities survey. Second stage: select patients from sampled facilities. | General results:
| Recommended frequency of data collection: No recommendation | Only 37% of patients received chemotherapy concurrent with radiation therapy.
| | Only 55% of patients with disease through the bowel wall and/or involving lymph nodes received chemotherapy.
| | Chemotherapy given to 44.3% of patients overall.
| | Technical results:
| | 95% of patients underwent simulation for radiation therapy.
| | Port films were taken in 98% of patients.
Dominitz, Samsa, Landsman, et al., 1998 | Quality measure (QM): Percentage of patients with colorectal cancer receiving chemotherapy | Study population: | | | | | General comments:
#9380 | Basis of QM: None | N: 2,607 whites + 569 blacks | | | | | The article compares rates of surgery, radiotherapy, and chemotherapy among blacks and whites. No attempt is made to compare to a gold standard (e.g., a guideline) to determine whether the rates in blacks or whites are optimal.
| Type of QM: | Age: 67.1 ± 9.1 (whites); 66.4 ± 9.9 (blacks) | | | | | The study is limited because of its use of an administrative database that lacked clinical details and did not allow for adjustment to disease severity.
| (a) Process | Race: See above | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 1; - Adaptability: 1; - Adequacy of risk adjustment: 1
| (b) General | Sex: 100% male
| Outcome to which the QM is linked: Survival | Tumor stage: All stages
| Intent of QM: Not specified (aim of the study was to assess the influence of race on the treatment and survival of patients with colorectal carcinoma) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: VA Medical Centers
| Denominator: | Dates: 1989
| Number of white/black patients with colorectal cancer identified from the VA Patient Treatment File (PTF) who were discharged from VA hospitals with a diagnosis of CRC (ICD-9-CM codes 153.0–153.4, 153.6–154.1) during fiscal year 1989. To exclude prevalent cases, any patient with a diagnosis of CRC (ICD-9-CM codes 153.0–153.4, 153.6–154.1, V10.05–V10.06 ) for hospitalization during FY 1984-1988, or a personal history of CRC (ICD-9-CM codes V10.05–V10.06) during the index hospitalization, was excluded. Male veterans only. No ulcerative colitis or Crohn's disease. | Healthcare setting: VA Hospitals
| Numerator: | Results:
| Number of above white/black patients treated with chemotherapy, as indicated by specific ICD-9-CM codes in the PTF. | No statistically significant differences in rates of chemotherapy in blacks vs. whites.
| Data sources: VA PTF | No difference in 5-year relative survival or overall survival in blacks vs. whites.
| Recommended frequency of data collection: No recommendation
Govindarajan, Shah, Erkman, et al., 2003 | Quality measure (QM): Percentage of patients with stage II, III colorectal cancer receiving chemotherapy | Study population: | | | | | General comments: None
#35310 | Basis of QM: None | N: 617 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 1; - Adaptability: 1; - Adequacy of risk adjustment: 1
| Type of QM: | All figures below for Caucasians/AAs
| (a) Process | Age: 60.0/61.5
| (b) General | Race: 427 Caucasians/190 AAs
| Outcome to which the QM is linked: Not firmly linked to any outcome, but presumably to survival, quality of life, or rates of local recurrence | Sex: 47.1% male/39.5% male
| Intent of QM: Not specified (aim of the study was to analyze disease stage, treatment received, and socioeconomic factors to better understand the factors influencing survival differences between African-Americans and Caucasians with colorectal cancer) | Tumor stage: Stages 0–IV
| Definition of denominator/numerator: | Performance status: NR
| Denominator: | Other:
| Number of African-Americans (AAs)/Caucasians, aged 18 older, with CRC treated between 1984 and 1997 at a state-funded University hospital located in Arkansas, identified through the hospital tumor registry using appropriate tumor registry codes. | - Not high school grad: 45%/60%; - Low income: 45%/64%; - High poverty: 41%/68%
| Numerator: | Geographic location: Arkansas
| Number of above AAs/Caucasians treated with chemotherapy. | Dates: 1984-1997
| Data sources: Tumor registry at Univ. of Arkansas. | Healthcare setting: University hospital
| Recommended frequency of data collection: No recommendation | Results:
| | Authors show that significantly higher percentages of Caucasians received chemotherapy, compared with AAs, for patients with all stages of CRC, and for patients with only stages II and III disease.
| | Cancer-specific mortality was higher in African-Americans than in Caucasians for all stages.
Hyman, Labow, and Vermont Chapter of the American College of Surgeons, 2002 | Quality measure (QM): Adjuvant therapy rate | Study population: | | | | | General comments: The study was not designed with an explicit intention to compare quality of care among participating surgeons (although it could potentially do so), but for comparison with national benchmarks.
#18980 | Basis of QM: NIH consensus conference guidelines | N: 364 (33 surgeons) | | | | | A voluntary registry was used as the source of data.
| Type of QM: | Age: Mean 68.7 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 2; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 3
| (a) Process | Stage of tumor: Stage I = 24%, stage II = 32%, stage II = 28%, stage IV = 16%
| (b) General | Geographic location: Vermont
| Outcome to which the QM is linked: Mortality? | Dates: April 1, 1999 to March 31, 2001
| Intent of QM: Not specified (aim of the study was to assess the feasibility of performing a quality study of the surgical management of colorectal cancer using a voluntary registry) | Healthcare setting: Mixed
| Definition of denominator/numerator: | Results:
| Denominator: | All patients with stage III colon cancer and stages II or III rectal cancer were offered adjuvant therapy.
| Number of colorectal cancer patients reported to registry by 33 surgeons in Vermont
| Numerator:
| Number of patients offered adjuvant therapy
| Data sources: Prospective statewide voluntary registry created by the Vermont chapter of ACS with the Vermont Program for Quality Health Care
| Recommended frequency of data collection: No recommendation
Jessup, McGinnis, Steele Jr., et al., 1996 | Quality measure (QM): Percentage of patients with stage III colon cancer receiving adjuvant chemotherapy | Study population: | | | | | General comments: None
#35360 | Basis of QM: Clinical practice guideline (NCI-NIH Consensus Development conference) | N: 9,509 with stage III colon cancer | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 2; - Adaptability: 4; - Adequacy of risk adjustment: 2
| Type of QM: | Age: All ages included
| (a) Process | Race: All races
| (b) General | Sex: Both sexes
| Outcome to which the QM is linked: Survival | Tumor stage: All stages
| Intent of QM: Not specified (aim of the study was to report time trends in stage of disease, treatment patterns, and survival for patients with selected cancers [including colon cancer]) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: United States
| Denominator: | Dates: 1985-1993
| Number of Cases of stage III colon cancer reported to the National Cancer Database in 1988 and 1993 | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of patients who received adjuvant chemotherapy | 43% of stage III patients received chemotherapy.
| Data sources: National Cancer Database | Overall (not cancer-specific) survival was reported. Those stage II and III patients who received surgery and chemotherapy had a 49% survival rate compared to 44% for those who received surgery alone.
| Recommended frequency of data collection: No recommendation
Keating, Landrum, Meara, et al., 2005 | Quality measure (QM): Rate of adjuvant chemotherapy for patients with stage III colon cancer | Study population: | | | | | General comments: None
#36080 | Basis of QM: Clinical practice guideline (not specified, but likely 1990 NCI Consensus Statement) | N: 48,027 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 4
| Type of QM: | Age: 66–85+
| (a) Structure | Race: 88 white
| (b) General | Sex: 46% male
| Outcome to which the QM is linked: Improved survival is implied | Other: Income, % high school graduates in census tract of residence, comorbidity score, market share of managed care
| Intent of QM: To assess quality of care (aim of the study was to examine associations between increases in managed care market share and changes in the quality of care delivered to cancer patients in the fee-for-service sector) | Geographic location: SEER geographic regions
| Definition of denominator/numerator: | Dates: 1993-1999
| Denominator: | Healthcare setting: Not stated
| Number of patients with a first diagnosis of stage III CRC 1993-1999 in a given SEER county who had undergone surgery, were alive and enrolled in fee-for-service Medicare (parts A and B) through month 4. | Results:
| Numerator: | Increased market share of managed care in a given county resulted in no significant change in rates of adjuvant chemotherapy for stage III colon cancer.
| Number of patients with stage III CRC in a given county who received adjuvant chemotherapy (The specific CPT, ICD-9, HCPCS, and Revenue Center codes used to identify chemotherapy administration are listed in the manuscript).
| Data sources:
| SEER -Medicare dataset
| 1990 U.S. Census
| Recommended frequency of data collection: No recommendation
| Quality measure (QM): Rate of adjuvant chemotherapy and radiation therapy for patients with stage II or III rectal cancer | Study population: | | | | | General comments: None
| Basis of QM: Clinical practice guideline (not specified, but likely 1990 NCI Consensus Statement) | N: 48,027 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 1
| Type of QM: | Age: 66–85+
| (a) Structure | Race: 88% white
| (b) General | Sex: 46% male
| Outcome to which the QM is linked: Generally, improved survival. | Other: Income, % high school graduates in census tract of residence, comorbidity score, market share of managed care
| Intent of QM: To assess quality of care (aim of the study was to examine associations between increases in managed care market share and changes in the quality of care delivered to cancer patients in the fee-for-service sector) | Geographic location: SEER geographic regions
| Definition of denominator/numerator: | Dates: 1993-1999
| Denominator: | Healthcare setting: Not stated
| Number of patients with a first diagnosis of stage II, III rectal cancer in 1993-1999 in a given SEER county who had undergone surgery, were alive and enrolled in fee-for-service Medicare (parts A and B) through month 4. | Results:
| Numerator: | Increased market share of managed care in a given county resulted in significant decrease in % of patients with stage II or III rectal cancer receiving adjuvant chemotherapy and radiotherapy.
| Number of patients with stage II, III rectal cancer in a given county who received adjuvant chemotherapy and radiation therapy.
| Data sources: SEER-Medicare dataset; 1990 U.S. Census
| Recommended frequency of data collection: No recommendation
Mahoney, Kuo, Topilow, et al., 2000 | Quality measure (QM): Percentage of patients with stage III colon cancer receiving adjuvant chemotherapy | Study population: | | | | | General comments: None
#26120 | Basis of QM: Clinical practice guideline (NCI-NIH Consensus Development Conference) | N: 69 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 2; - Adaptability: 2; - Adequacy of risk adjustment: 2
| Type of QM: | Age: 40–97
| (a) Process | Race: Not reported
| (b) General | Sex: 28 men, 41 women
| Outcome to which the QM is linked: Survival | Tumor stage: III
| Intent of QM: Not specified (aim of the study was to assess the use of adjuvant chemotherapy in an aging population from the time when the initial recommendation for chemotherapy was made) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: New Jersey
| Denominator: | Dates: January 1, 1989-December 30, 1996
| Number of patients with stage III colon cancer in the Tumor Registry of Jersey Shore Medical Center. | Healthcare setting: Jersey Shore Medical Center
| Numerator: | Results:
| Number of patients receiving postoperative chemotherapy. | 49% of patients received chemotherapy; men had a 5.8 times greater chance of receiving chemotherapy than women.
| Data sources: Tumor registry
| Recommended frequency of data collection: No recommendation
Neugut, Fleischauer, Sundararajan, et al., 2002 | Quality measure (QM): Use of chemotherapy of combined chemoradiotherapy in stage II and III rectal cancer patients among the elderly | Study population: | | | | | General comments:
#18450 | Basis of QM: Clinical practice guideline (NIH and NCCN) | N: 1,807 | | | | | Impossible from this dataset to ascertain if the frequency of adjuvant chemotherapy or radiotherapy use was “optimal” in the population under study. For example, omission of chemotherapy in an elderly patient with stage III rectal cancer may be a medically sound decision if the patient has significant comorbidities.
| Type of QM: | Age: 65–85+ | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 1
| (a) Process | Race: 1592 non-Hispanic white
| (b) General | Sex: 964 female
| Outcome to which the QM is linked: Survival | Tumor stage: II (983). III (824)
| Intent of QM: Not specified (aim of the study was to investigate the use of treatment with adjuvant 5-FU-based chemotherapy and radiation therapy among patients over 65 years of age with surgically resected stage II or III rectal cancer) | Performance status: NR
| Definition of denominator/numerator: | Charlson-Deyo comorbidity score: 0 (1098), 1 (299), > 1 (410)
| Denominator: | Geographic location: SEER geographic regions
| Number of patients with histologically confirmed primary rectal cancer, diagnosed 1992-1996, stage II-III, age ≥ 65, s/p surgical tumor resection, eligible for Medicare Parts A and B in the 12 mo before diagnosis and 120 days after diagnosis, and had survived more than 4 mo after diagnosis. Excluded members of HMO in the 12 mo before and 4 mo after their diagnosis. | Dates: 1992-96
| Numerator: | Healthcare setting: U.S. facilities
| Number of patients who received both chemotherapy and radiotherapy. | Results:
| Data sources: SEER-Medicare database | 51% received adjuvant chemotherapy and 48% received radiotherapy overall. 38% received surgery alone; 11% received surgery plus radiation therapy, 14% received surgery plus adjuvant chemotherapy and 37% received surgery with radiation plus adjuvant chemotherapy.
| Recommended frequency of data collection: No recommendation | Patients with stage III disease were significantly more likely than patients with stage II disease to receive combined 5-FU chemotherapy and radiotherapy.
| | Age inversely associates with receiving combined chemo-radiotherapy. Among cases with stage III cancer, number of nodes and comorbidity score were also significant predictors of receiving combined therapy.
Newcomb and Carbone, 1993 | Quality measure (QM): Rate of adjuvant chemotherapy for colorectal cancer | Study population: | | | | | General comments:
#3760 | Basis of QM: None mentioned, but presumably practice guideline | N: 121 with colorectal | | | | | Relying on recall of patients for whether they received a treatment is open to bias.
| Type of QM: | Age: 20–74 | | | | | For some of the patients, chemotherapy would not have been appropriate, and these patients should not be included in the denominator. Therefore, the result may not be conclusive.
| (a) Process | Race: NR | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 3; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (b) General | Sex: Female
| Outcome to which the QM is linked: Not specified, but presumably survival | Tumor stage: All stages
| Intent of QM: Not specified (aim of the study was to evaluate the selection of cancer treatment among the elderly) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Wisconsin
| Denominator: | Dates: Sep 1 through Nov 30, 1990
| Number of women residents of Wisconsin aged 20–74 at the time of diagnosis with a new diagnosis of carcinoma of the large bowel during 1989-1991, and who had a listed telephone number and spoke English, and whose physician consented to their participation, and who agreed to a telephone interview, and were among the 628 consecutive participants interviewed September 1, 1990 through November 30, 1990. | Healthcare setting: None (all participants were outpatients contacted by phone)
| Numerator: | Results:
| Number of subjects receiving chemotherapy. | 41% of patients less than 65 and 26% ≥ 65 received chemotherapy.
| Data sources: Registry for staging information and patient interviews (for the treatment information) | Older women were less likely to be referred to medical or radiation oncologists; they were also less likely to be presented with more than one treatment option.
| Recommended frequency of data collection: No recommendation
Oliveria, Yood, Campbell, et al., 2004 | Quality measure (QM): Referral to medical oncologist for consideration of adjuvant chemotherapy | Study population: | | | | | General comments:
#29680 | Basis of QM: Clinical practice guideline (1990 NCI guidelines for stage III and IV disease [refs 9, 18, 19]) | N: 217 | | | | | Authors conclude that both patient and physician factors influence the rate of referral to a medical oncologist.
| Type of QM: | Age: Median age 72.0 years; range, 38 to > 80 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 3
| (a) Process | Race: NR
| (b) General | Sex: 48% male
| Outcome to which the QM is linked: Survival, quality of life | Tumor stage: I-IV
| Intent of QM: Not specified (aim of the study was to describe treatment patterns for patients with colorectal cancer and to examine reasons why patients do not receive chemotherapy) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Massachusetts
| Denominator: | Dates: 1997-99
| Number of members of a Massachusetts HMO who were newly diagnosed with CRC from 1/1/97 to 6/30/99 based on ICD-9 codes for CRC and related CPT-4 procedure codes for resection from the HMO's computerized research database. | Healthcare setting: HMO
| Numerator: | Results:
| Number of patients above who were referred to a medical oncologist. | 66% of patients had a referral to an oncologist or evidence of chemotherapy within 4 months of the index date.
| Data sources: Computerized database of Massachusetts HMO | Stratified by stage at diagnosis, authors report percentage of patients who were referred to a medical oncologist and whether they subsequently received chemotherapy. Among patients who did not get referred to a medical oncologist, authors report the reasons for no referral (patient refusal, not recommended by MD, comorbidities/death, or unknown).
| Recommended frequency of data collection: No recommendation | Multivariable analysis revealed patient age (< 70 vs. ≥ 70) and tumor stage (III vs. I) to be significant predictors of referral.
Potosky, Harlan, Kaplan, et al., 2002 | Quality measure (QM): Percentage of patients with stage II, III rectal cancer receiving adjuvant chemotherapy (with or without radiotherapy) | Study population: | | | | | General comments: None
#19420 | Basis of QM: Clinical practice guideline (NCI-NIH Consensus Development conference) | N: 1,366 stage II, III rectal cancer | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 4
| Type of QM: | Age: All
| (a) Process | Race: 86% white, 7% African American, 5% Hispanic
| (b) General | Sex: 59% male
| Outcome to which the QM is linked: Survival | Tumor stage: II, III
| Intent of QM: Not specified (aim of the study was to assess the dissemination of adjuvant therapies for stages II and III colorectal cancer, and multiple clinical and non-clinical characteristics associated with the use of minimally acceptable adjuvant therapy as a standard of care) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Several cities across U.S.
| Denominator: | Dates: 1990-1991 or 1995
| Number of patients with stage II, III rectal cancer diagnosed in 1990-1991 or 1995 for whom the offer of the receipt of chemotherapy was known. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of patients receiving postoperative chemotherapy with or without radiotherapy. | Because the data are presented by year and by other demographics, it is difficult to determine the overall % of patients who received chemotherapy.
| Data sources: SEER program
| Recommended frequency of data collection: No recommendation
| Quality measure (QM): Percentage of patients with stage III colon cancer receiving adjuvant chemotherapy | Study population: | | | | | General comments: None
| Basis of QM: Clinical practice guideline (NCI-NIH Consensus Development conference) | N: 779 stage III colon cancer | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 4
| Type of QM: | Age: All
| (a) Process | Race: 85% white, 9% African American, 4% hispanic
| (b) General | Sex: 47% male
| Outcome to which the QM is linked: Survival | Tumor stage: Stage III
| Intent of QM: Not specified (aim of the study was to assess the dissemination of adjuvant therapies for stages II and III colorectal cancer, and multiple clinical and non-clinical characteristics associated with the use of minimally acceptable adjuvant therapy as a standard of care) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Several cities across U.S.
| Denominator: | Dates: 1990-1991 or 1995
| Number of patients with stage III colon cancer diagnosed in 1990-1991 or 1995 for whom the offer of the receipt of chemotherapy was known. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of patients receiving postoperative chemotherapy. | Because the data are presented by year and by other demographics, it is difficult to determine the overall % of patients who received chemotherapy.
| Data sources: SEER program
| Recommended frequency of data collection: No recommendation
Retchin and Brown, 1990 | Quality measure (QM): Palliative chemotherapy rates | Study population: | | | | | General comments:
#7970 | Basis of QM: Clinical practice guideline (not cited, but likely standard of care) | | | | FFS n = 180 | HMO n = 150 | Confounding variables were not controlled for, FFS patients may have been sicker. Stage of disease could be another possible confounder.
| Type of QM: | Mean age | | | 70.1 | 72.3 | Pre- or postoperative should be added to analysis.
| (a) Process | % male | | | 49.4 | 58.7 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 1; - Adequacy of risk adjustment: 1
| (b) General | % white | | | 86.7 | 95.2
| Outcome to which the QM is linked: Appropriate pre- and postoperative care | Geographic location: U.S. HMOs were geographically represented
| Intent of QM: Quality improvement (aim of the study was to compare the processes of care for colorectal cancer patients in HMOs with those in fee-for-service [FFS] settings) | Dates: 1983-1986
| Definition of denominator/numerator: | Healthcare setting: Inpatient and outpatient
| Denominator: | Results:
| Number of Medicare patients enrolled in HMO or FFS health plans who were hospitalized for colorectal cancer (based on discharge diagnosis or equivalent symptoms, e.g., cancer or mass or tumor of the rectum, sigmoid, cecum or colon; admission for colectomy, hemicolectomy, polypectomy; rectal or gastrointestinal bleeding and abdominal pain, vomiting, obstruction, dehydration, obstipation or severe constipation). FFS patients included in the study were hospitalized and had discharge diagnoses including malignant neoplasms of the colon, rectum, rectosigmoid junction or anus. Patients with carcinoma in situ of either the colon or rectum were also eligible. FFS patients were selected according to number of patients discharged from 7/83 to 3/31/86. HMO patients with an enrollment date of (1/83 to 5/84) to 3/31/86 were included. | 36% of HMO patients with advanced disease received palliative chemotherapy compared to 18% of FFS patients. These differences were not statistically significant.
| Exclusion criteria: Individuals enrolled in HMOs with fewer than 2000 enrollees were eliminated.
| Numerator:
| Number of patients with advanced disease who received palliative chemotherapy.
| Data sources: Medical records, Medicare claims from Medicare Automated Data Retrieval System
| Recommended frequency of data collection: No recommendation
Roetzheim, Pal, Gonzalez, et al., 2000 | Quality measure (QM): Percentage of patients with a colon or rectal cancer diagnosis who received chemotherapy | Study population: | | | | | General comments:
#23910 | Basis of QM: None stated (see General comments) | N: 9,548 | | | | | Existing guidelines are for stage III colon cancer and stage II or III rectal cancer only, so measuring and reporting data on all chemotherapy for all stages of colon or rectal cancer is not guideline- or evidence-driven.
| Type of QM: | Patient characteristic | | | | Percent | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 2; - Validity: 2; - Adaptability: 2; - Adequacy of risk adjustment: 1
| (a) Process | Male | | | | 51
| (b) General | Race
| Outcome to which the QM is linked: Mortality | White | | | | 85
| Intent of QM: Not specified (aim of the study was to explore the influence of race/ethnicity and insurance payer on the treatment of and outcomes for colorectal cancer patients in Florida) | Black | | | | 6
| Definition of denominator/numerator: | Hispanic | | | | 8
| Denominator: | Diagnosis stage
| Number of incident cases of colon or rectal cancer occurring in Florida in 1994 as listed in the state tumor registry. | In situ | | | | 6
| Numerator: | Local | | | | 30
| Number of the above patients who also received chemotherapy within 4 months of initiation of therapy. | Regional | | | | 42
| Data sources: Florida state cancer registry (Florida Cancer Data System = FCDS); Florida Agency for Health Care Administration AHCA discharge abstracts (admissions to all nonfederal acute care hospitals and patient visits to ambulatory surgical centers, freestanding radiation therapy centers and diagnostic imaging centers) | Distant | | | | 16
| Recommended frequency of data collection: No recommendation | Unstaged | | | | 6
| | Anatomic site
| | Colon | | | | 84
| | Rectal | | | | 16
| | Comorbidity index
| | 0 | | | | 71
| | 1 | | | | 21
| | ≥ 2 | | | | 8
| | Geographic location: Florida
| | Dates: 1994
| | Healthcare setting: Multiple
| | Results:
| | 21% of the patients in the study received chemotherapy, but no validity testing was done for chemotherapy.
| | Hispanics were less likely than non-Hispanic whites to receive chemotherapy among non-Medicare patients. Persons with commercial HMO insurance were less likely than those with commercial FFS insurance to receive chemotherapy. Other factors predictive of receiving chemotherapy were younger age, higher education, being married, having rectal cancer, advanced tumor stage, and lower level of comorbid illness.
| | Among non-Medicare patients, mortality rates were higher in all models for patients with commercial HMOs compared with patients with commercial FFS insurance.
Rogers, Ray, and Smalley, 2004 | Quality measure (QM): Percentage of patients with a diagnosis of stage III colorectal cancer receiving chemotherapy | Study population: | | | | | General comments:
#30130 | Basis of QM: Not stated | N: 969 total | | | | | Study concluded that when there was equal access to care, outcomes were equal in whites and blacks.
| Type of QM: | Age: 78.9 ± 7.5 years | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Race: 272 black (28%), 697 white (72%)
| (b) General | Sex: 73.9% female (whites), 72.4% female (Blacks)
| Outcome to which the QM is linked: Not stated, but presumably survival or recurrence of CRC cancer | Tumor stage: 75.6% (whites) and 72.1% (blacks) had stage III disease
| Intent of QM: Not specified (aim of the study was to examine the effect of race on CRC outcomes in patients who had identical health care coverage) | Performance status: Charlson Deyo score of 0 in 64% (whites) and 69% in Blacks
| Definition of denominator/numerator: | Geographic location: Tennessee
| Denominator: | Dates: 1984-1994
| Number of patients enrolled in both Tennessee Medicaid and Medicare and hospitalized with a diagnosis of colorectal cancer. | Healthcare setting: Patients identified from hospitalizations
| Numerator: | Results:
| Number of above patients who received chemotherapy within 120 days of diagnosis. | 7.8% of whites and 9.4% of blacks had chemotherapy within 120 days of diagnosis. There was no difference in survival between whites and blacks.
| Data sources: Medical records, administrative files from the Tennessee Medicaid program, Tennessee death certificates, and the National Death Index
| Recommended frequency of data collection: No recommendation
Schrag, Cramer, Bach, et al., 2000 | Quality measure (QM): Postoperative chemotherapy rates | Study population: | | | | | General comments: None
#23710 | Basis of QM: Not stated | N: 6,423 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 4
| Type of QM: | Geographic location: U.S.
| (a) Process | Dates: 1991-1996
| (b) General | Healthcare setting: All U.S.
| Outcome to which the QM is linked: Mortality | Results:
| Intent of QM: Quality improvement (aim of the study was to determine whether hospital procedure volume predicts short- and long-term survival following primary colon cancer surgery) | Overall postoperative chemotherapy rate within 3 months of surgery was 54.8%. Differences were marginally significant for hospitals with low (51.2%), medium (56.6%), high (55.6%), and very high (55.5%) volume.
| Definition of denominator/numerator: | The difference in 5-year mortality for patients operated on at very high- vs. low-volume hospitals was 4.4%.
| Denominator:
| Number of patients with stage III tumors who survived 3 months postoperatively, were enrolled in Medicare Part B, were 65 years and older, were diagnosed as having primary adenocarcinoma of the colon in a SEER area, and underwent surgery followed by at least one claim for chemotherapy.
| Exclusion criteria: Patients were excluded if diagnoses were exclusively noted on death certificates or at autopsy; month of diagnosis was unknown; or patient was enrolled in an HMO. Also, patients who were operated on exclusively for local resection or creation of an ostomy were excluded.
| Numerator:
| Number of patients who received postoperative chemotherapy within 3 months of surgery.
| Data sources: SEER for patients 65 and older Medicare Claims Part B
| Recommended frequency of data collection: No recommendation
Schrag, Cramer, Bach, et al., 2001 | Quality measure (QM): Percentage of patients with stage III colon cancer receiving adjuvant chemotherapy | Study population: | | | | | General comments: None
#21910 | Basis of QM: Clinical practice guideline (NCI-NIH Consensus Development Conference) | N: 6,262 patients with stage III colon cancer | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 4
| Type of QM: | Age: > 65
| (a) Process | Race: All races
| (b) General | Sex: Both sexes
| Outcome to which the QM is linked: Survival | Tumor stage: Stage III
| Intent of QM: Not specified (aim of the study was to assess the extent to which adjuvant therapy is used among the elderly) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: 5 states and 6 U.S. metropolitan areas
| Denominator: | Dates: 1991-1996
| Number of patients aged 65 years and older enrolled in Medicare A and B, diagnosed with primary colon adenocarcinoma stage III, in a SEER area during the years 1991-1996 and not part of an HMO, and who had colon cancer surgery performed within 3 months of primary diagnosis. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of patients who received radiotherapy (and chemotherapy) within 6 months of surgery. | 55% of stage III patients received chemotherapy.
| Data sources: Linkage of SEER population-based cancer registries with Medicare database of HCFA | Age at diagnosis was highly associated with receipt of adjuvant treatment.
| Recommended frequency of data collection: No recommendation
Schrag, Gelfand, Bach, et al., 2001 | Quality measure (QM): Percentage of patients with stage II or III rectal cancer receiving chemoradiotherapy | Study population: | | | | | General comments:
#21280 | Basis of QM: NIH consensus statement | N: 1,411 | | | | | The data for this study were generated prior to 1990 so it may not reflect more modern recommendations for management.
| Type of QM: | Age: > 65 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 3
| (a) Process | Race: 88% white, 4% black, 8% other
| (b) General | Sex: Male 54%
| Outcome to which the QM is linked: None is specified, but presumably it would be pelvic recurrence | Tumor stage: Stage II, III
| Intent of QM: Not specified (aim of the study was to examine the relationship between patient characteristics and the use of adjuvant radiotherapy with and without chemotherapy among patients 65 years of age and older with stage II and II rectal cancer) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: 5 states and 6 U.S. metropolitan areas
| Denominator: | Dates: 1992-1996
| Number of patients aged 65 years and older enrolled in Medicare A and B, diagnosed with primary rectal adenocarcinoma stage II or III, in a SEER area during the years 1991-1996 and not part of an HMO, and who had rectal cancer surgery performed within 6 months of primary diagnosis and who survived more than 6 months and who did not have a secondary cancer within 6 months. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of patients who received radiotherapy (and chemotherapy) within 6 months of surgery. | 57% of patients received radiotherapy (42% with chemotherapy and 15% radiation alone).
| Data sources: Linkage of SEER population-based cancer registries with Medicare database of HCFA
| Recommended frequency of data collection: No recommendation
Schrag, Panageas, Riedel, et al., 2003 | Quality measure (QM): Adjuvant chemotherapy rate | Study population: | | | | | General comments:
#34030 | Basis of QM: Clinical practice guideline (not specified) | N = 24,166 | | | | | 2-year postoperative mortality/survival was also assessed.
| Type of QM: | Characteristic | | | | Percent | Study claims that it cannot explain specific processes of care that can account for differences in mortality rates in the various hospitals.
| (a) Process | Male/female | | | | 44.1/55.9 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 4
| (b) General | Age
| Outcome to which the QM is linked: Mortality | 65–69 | | | | 18.6
| Intent of QM: Quality improvement (aim of the study was to compare surgeon and hospital procedure volume as predictors of outcomes following colon cancer resection) | 70–74 | | | | 23.6
| Definition of denominator/numerator: | 75–79 | | | | 23.6
| Denominator: | 80+ | | | | 34.2
| Number of Medicare eligible patients aged 65 or older diagnosed in SEER regions with primary colon cancer in 1991-1996. | Race
| Exclusion criteria: Excluded were patients enrolled in an HMO; operated on exclusively for intestinal bypass; diagnosis noted exclusively on death certificate or at autopsy; month of death was unknown. | White | | | | 87.1
| Numerator: | Black | | | | 6.6
| Number of patients who received adjuvant chemotherapy. | other | | | | 6.3
| Adjustment was made for sex, race, age, stage of tumor, comorbidity and socioeconomic status, whether hospitalization was emergent and whether obstruction or perforation was present. | AJCC stage I | | | | 19.9
| Data sources: SEER, Medicare claims from HCFA | II | | | | 36.9
| Recommended frequency of data collection: No recommendation | III | | | | 26.1
| | IV | | | | 14.1
| | Unstaged | | | | 3.0
| | Romano comorbidity
| | 0 | | | | 71.3
| | 1 | | | | 123.2
| | 2 | | | | 5.6
| | Obstruction (Y/N) | | | | 9.0/91.0
| | Emergent hospitalization (Y/N) | | | | 19.8/80.2
| | Geographic location: U.S.
| | Dates: 1991-1996
| | Healthcare setting: All
| | Results:
| | Adjuvant chemotherapy rate differences were statistically insignificant.
| | Hospital procedure volume | | | | Adjuvant chemo%
| | Very low | | | | 51
| | Low | | | | 56
| | Medium | | | | 57
| | High | | | | 56
| | P value | | | | NS
| | Surgeon procedure volume
| | Very low | | | | 52
| | Low | | | | 55
| | Medium | | | | 54
| | High | | | | 56
| | P value | | | | NS
| | After adjusting for surgeon procedure volume, high hospital procedure volume remained a strong predictor of low postoperative mortality rates.
Steele, 1994 | Quality measure: Percentage of stage III colon cancer patients receiving surgery and chemotherapy | Study population: | | | | | General comments:
#35840 | Basis of QM: Clinical practice guideline It is implicit that the AHCC guidelines be followed but these are not actually cited in the article. There are also guidelines for chemotherapy in stage III colon cancer and chemo/radiation therapy for stage II and III rectal cancer (NCC), but these are not cited by the authors. | Data given as patients (year) | | | | | Some “treatment” data are presented, but these are not stratified by stage or location (colon vs. rectum) and therefore do not provide sufficient information to count as a QM. Only survival would be a potential QM from this paper.
| Type of QM: | N: 40,384 (85/86); 39,751 (91) | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Age: Median 71.3 (85/85); 72.0 (91)
| (b) General | Race:
| Outcome to which the QM is linked: No outcome is exactly linked to the above but is said to be a marker of appropriate cancer diagnosis and treatment. No citation is provided for this statement. | Non-Hispanic whites 86.9% (85/85); 85.9% (91)
| Intent of QM: Not specified (aim of the study was to assess cancer patient care and outcomes on a national basis) | Hispanic 1.1/1.8
| Definition of denominator/numerator: | African-American 6.6/8.1
| Denominator: | Asian 0.9/1.5
| Number of patients in the National Cancer Data Base (NCDB) with a new diagnosis of colon cancer in the years 1985-1986 or 1991. | Unknown 4.5/2.7
| Numerator: | Sex: Male 48.7% (85/85), 49.6% (91)
| Number of the above with stage III cancer who underwent surgery and received chemotherapy. | Tumor stage: 85–86/91
| Data sources: National Cancer Data Base (NCDB) | 0 3.7/6.5
| Recommended frequency of data collection: No recommendation | 1 14.4/19.3
| | 2 13.8/26.2
| | 3 12.9/20.3
| | 4 9.2/15.8
| | Unknown 46.0/11.9
| | Performance status: NR
| | Geographic location: National sample; note that the sample is not probabilistic and represented different hospitals in different years
| | Dates: 1991 and outcomes for 1985-86
| | Healthcare setting: 464 hospital in 1985, 474 hospitals in 1986, 937 hospitals in 1991
| | Results:
| | Treatment trends showed effects of trial data, as a greater percentage of patients were reported as having treatment (including chemotherapy) beyond surgery in 1991 as compared to 1985/86.
Steele Jr., 1994 | Quality measure (QM): Percentage of patients with stage III colon cancer receiving postoperative chemotherapy | Study population: | | | | | General comments:
#35390 | Basis of QM: None | N: 6,299 patients | | | | | This paper addresses similar issues as in Beart et al. (1995; #990).
| Type of QM: | Age: All | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Race: All
| (b) General | Performance status: NR
| Outcome to which the QM is linked: None specified, but presumably it would be survival | Geographic location: Entire U.S.
| Intent of QM: Not specified (aim of the study was assess cancer patient care and outcomes on a national basis) | Dates: 1985, 1988, 1990
| Definition of denominator/numerator: | Healthcare setting: Hospitals
| Denominator: | Results:
| Number of stage III colon cancer patients in 1990 reported to the National Cancer Data Base (NCDB). | 38.9% received chemotherapy and surgery (with or without radiation therapy).
| Numerator:
| Number of above patients receiving chemotherapy (with or without radiation).
| Data sources: Registry information reported to National Cancer Data Base
| Recommended frequency of data collection: No recommendation
| Quality measure (QM): Percentage of patients with stage II or III rectal cancer receiving chemoradiotherapy | Study population:
| Basis of QM: None | N: 5,495
| Type of QM: | Age: Median 69.3 years for rectal cancer
| (a) Process | Race: For entire study: African American, 9.1% for colon cancer and 6.5% for rectal cancer; Hispanic, 2.7% for colon cancer and 3.5% for rectal cancer. 1.4% of cases were Asian. The rest were Caucasian.
| (b) General | Sex: Male 57.2% (rectal).
| Outcome to which the QM is linked: None specified, but presumably it would be survival | Tumor stage: All included (4.7% stage 0, 22.1% stage I, 29.2% stage II, 22.2% stage III, 18.7% stage IV, 3.0% unknown
| Intent of QM: Not specified (aim of the study was assess cancer patient care and outcomes on a national basis) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Entire U.S.
| Denominator: | Dates: Calendar years 1983 and 1988
| Number of patients with stage II, III rectal cancer in 1990 reported to the National Cancer Data Base (NCDB). | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of above patients receiving chemotherapy | Not specifically stated, but can be calculated form Table 19. 43% of stage II or III patients received surgery and radiation (with or without chemotherapy).
| Data sources: Registry information reported to National Cancer Data Base (NCDB)
| Recommended frequency of data collection: No recommendation
Steele and Jessup, 1995 | Quality measure (QM): Percentage of patients with stage III receiving postoperative chemotherapy | Study population: | | | | | General comments:
#35850 | Basis of QM: None | N: 9,465 | | | | | This paper addresses similar issues as Beart et al. (1995; #990), and Steele Jr. (1994; #35390) except that it includes data from 1992, whereas the others have data ending in 1988 and 1990.
| Type of QM: | Age: All | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Race: All
| (b) General | Performance status: Not stated
| Outcome to which the QM is linked: None specified, but presumably it would be survival | Geographic location: Entire U.S.
| Intent of QM: Not specified (aim of the study was assess cancer patient care and outcomes on a national basis) | Dates: Calendar year 1986/7 and 1992
| Definition of denominator/numerator: | Healthcare setting: Hospitals
| Denominator: | Results:
| Number of stage III colon cancer patients in 1992 reported to the National Cancer Data Base (NCDB). | 44.6% received chemotherapy and surgery (with or without radiation therapy).
| Numerator:
| Number of above patients receiving chemotherapy (with or without radiation).
| Data sources: Registry information reported to National Cancer Data Base (NCDB)
| Recommended frequency of data collection: No recommendation
| Quality measure (QM): Percentage of patients with stage II or III rectal cancer receiving chemoradiotherapy | Study population: | | | | | General comments:
| Basis of QM: None | N: 9,465 | | | | | This paper addresses similar issues as Beart et al. (1995; #990), and Steele Jr. (1994; #35390) except that it includes data from 1992, whereas the others have data ending in 1988 and 1990.
| Type of QM: | Age: All | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 2; - Validity: 3; - Adaptability: 5; - Adequacy of risk adjustment: 1
| (a) Process | Race: All
| (b) General | Performance status: Not stated
| Outcome to which the QM is linked: None specified, but presumably it would be survival | Other: Not stated
| Intent of QM: Not specified (aim of the study was assess cancer patient care and outcomes on a national basis) | Geographic location: Entire U.S.
| Definition of denominator/numerator: | Dates: Calendar year 1986/7 and 1992
| Denominator: | Healthcare setting: Hospitals
| Number of stage II, III rectal cancer patients in 1992 reported to the National Cancer Data Base (NCDB). | Results:
| Numerator: | Not specifically stated, but can be calculated form Tables 5–13 that 46% of stage II or III patients received surgery and radiation (with or without chemotherapy).
| Number of above patients receiving chemoradiotherapy.
| Data sources: Registry information reported to National Cancer Data Base (NCDB)
| Recommended frequency of data collection: No recommendation
Sundararajan, Grann, Jacobson, et al., 2001 | Quality measure (QM): Percentage of patients with stage III colon cancer receiving adjuvant chemotherapy | Study population: | | | | | General comments: This paper is very similar to Schrag et al. (2001; #21910), which looked at patients from 1991-1990.
#21760 | Basis of QM: Clinical practice guideline (NCI-NIH Consensus Development Conference) | N: 4,998 patients with stage III colon cancer | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 3
| Type of QM: | Age: > 65
| (a) Process | Race: All races
| (b) General | Sex: Both sexes
| Outcome to which the QM is linked: Survival | Tumor stage: Stage III
| Intent of QM: Not specified (aim of the study was to assess the distribution of adjuvant chemotherapy in the elderly) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: 5 states and 6 U.S. metropolitan areas
| Denominator: | Dates: 1992-1996
| Number of patients aged 65 years and older enrolled in Medicare A and B, diagnosed with primary colon adenocarcinoma stage III, in a SEER area during the years 1992-1996 and not part of an HMO, and who had colon cancer surgery performed within 120 days of primary diagnosis. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of patients who received chemotherapy within 4 months of surgery. | 50% of stage III patients received chemotherapy.
| Data sources: Linkage of SEER population-based cancer registries with Medicare database of HCFA
| Recommended frequency of data collection: No recommendation
Temple, Hsieh, Wong, et al., 2004 | Quality measure (QM): Chemotherapy rate for stage IV colon or rectal cancer | Study population: | | | | | General comments: None
#29890 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network Guideline) | N: 9,011 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 2; - Adequacy of risk adjustment: 2
| Type of QM: | Age: 21% 65–69; 25% 70–74; 23% 75–79; 18% 80–84; 13% ≥ 85
| (a) Process | Sex: 48% male, 52% female
| (b) General | Race: 84% white, 9% black, 7% other
| Outcome to which the QM is linked: Practice patterns of patients with stage IV cancer | Comorbidities: 90% had 0; 5% had 1; 5% had 2+
| Intent of QM: Quality improvement (aim of the study was to evaluate surgical practice patterns for patients 65 years of age and older with stage IV colorectal cancer) | Geographic location: U.S.
| Definition of denominator/numerator: | Dates: 1991-1999
| Denominator: | Healthcare setting: inpatient hospital
| Number of Medicare-enrolled patients aged 65 and older, initially diagnosed with stage IV colon or rectal cancer in a SEER area during the years 1991-1999. Age, sex, race, ethnicity, comorbidity, year of diagnosis, and socioeconomic status were collected and data were risk-adjusted. | Results:
| Exclusion criteria: Cohort restricted to those with a histologic diagnosis consistent with adenocarcinoma. Diagnoses exclusively on death certificates or at autopsy were excluded, as were those in which the month of diagnosis was unknown. Patients enrolled in HMOs were excluded. | Only 44% of the cohort received chemotherapy within 4 months of diagnosis. Palliative radiotherapy was administered to only 12% of cohort members within the first 4 months of treatment; these were primarily patients with rectal cancer.
| Numerator:
| Number of above patients who received chemotherapy within 4 months of diagnosis.
| Data sources: SEER, Medicare claims
| Recommended frequency of data collection: No recommendation
Tropman, Hatzell, Paskett, et al., 1999 | Quality measure (QM): Percentage of patients receiving appropriate adjuvant chemotherapy for CRC as defined by the NCI PDQ guidelines | Study population: | | | | | General comments:
#35610 | Basis of QM: Clinical practice guideline (NCI PDQ Guidelines) | N: 230 | | | | | The article compares rates of compliance with NCI PDQ recommendations in two rural geographic regions (one in NC, one in SC) before (1991) and after (1996) an intervention to educate local physicians. The intervention took place in NC. The SC region served as a control.
| Type of QM: | 1991/1996 data | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 4; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Age: Mean 75/71
| (b) General | Race: 76% white/75% white
| Outcome to which the QM is linked: Locoregional recurrence, overall survival. | Sex: 55% male/58% male
| Intent of QM: Not specified (aim of the study was to determine the degree to which colon cancer treatment in rural North and South Carolina conformed to national treatment recommendations) | Tumor stage: I-III
| Definition of denominator/numerator: | Performance status: NR
| Denominator: | Geographic location: Wayne County, NC, and its six contiguous counties or in Greenwood County, SC, and its four adjacent counties
| Number of patients treated for colon cancer in Wayne County, NC, and its six contiguous counties or in Greenwood County, SC, and its four adjacent counties during the years 1991 and 1996. Cases were identified by the North Carolina Central Cancer Registry and by local tumor registrars in SC. | Dates: 1991, 1996
| Numerator: | Healthcare setting: Rural health care facilities
| Number of patients above who received primary and adjuvant therapy per the NCI PDQ recommendations. | Results:
| Data sources: Patient medical records and records from physician offices in the geographic regions under study | A higher % of patients with stage III cancers received adjuvant chemotherapy compared to patients with stage II disease, a finding in keeping with the stronger PDQ support for adjuvant therapy for stage III disease. 44% of patients in NC with stage III colon cancer received chemotherapy in 1996 compared with 16% of patients with stage II disease.
| Recommended frequency of data collection: No recommendation
Wudel Jr., Chapman, Shyr, et al., 2002 | Quality measure (QM): Percentage of patients with colon or rectal cancer who had chemotherapy | Study population (university hospital = UH, city hospital = CH) | | | | | General comments:
#18640 | Basis of QM: None stated | N: 565 UH; 77 CH | | | | | Mortality was the primary endpoint of the study and the data for other potential QMs (% receiving “curative” surgery, chemo, or radiation therapy) are much weaker, poorly defined, and do not follow guidelines.
| Type of QM: | Age: Median 69 UH, 74 CH | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 2; - Validity: 2; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process | Race: 10.6% black UH; 53% black CH
| (b) General | Sex: 53.3% male UH; 62.7% male CH
| Outcome to which the QM is linked: Mortality | Tumor Stage | | | UH | CH
| Intent of QM: Not specified (aim of the study was to determine the outcome of patients with colorectal cancer treated in the same city at 2 nearby medical centers, a university hospital and a city hospital, and to explore disparities in colorectal cancer outcomes between black and white patients) | I | | | 31.7 | 29.9
| Definition of denominator/numerator: | II | | | 21.9 | 20.8
| Denominator: | III | | | 23.7 | 16.9
| Number of patients with a diagnosis of primary colorectal cancer between 1/1/90 and 12/21/99 in the tumor registry databases at each of 2 institutions (university hospital and a city hospital). Excluded patients who were non-white and non-black. | IV | | | 22.7 | 32.5
| Numerator: | Performance status: NR
| Number of the above patients who received chemotherapy. | Geographic location: Nashville, TN
| Data sources: Hospital tumor registries | Dates: 1/1/90 and 12/21/99 (retrospective review)
| Recommended frequency of data collection: No recommendation | Healthcare setting: University hospital, city hospital
| | Results:
| | There was no significant difference in tumor stage at the time of presentation in the two institutions studied or between racial/ethnic groups. There was no difference in the treatment modalities identified between institutions or racial/ethnic groups.
| | There was a significant difference in overall survival between patients treated at the university hospital (median 5.3 years) and those treated at the city hospital (median 2.1 years). Median survival was 5.7 years for white patients and 3.2 years for black patients treated at the university hospital. White patients treated at the city hospital survived 2.1 years vs. 1.4 years for black patients.
| | There was no survival advantage for patients receiving chemotherapy or radiotherapy.

Evidence Table 8 - Question 2c (Grey Literature): As appropriate to specific stages of colorectal cancer, what quality-of-care measures are available and what evidence is available for measures of quality of care of treatment of colorectal cancer, including appropriate use of adjuvant chemotherapy and adjuvant radiation therapy, including for patients with metastatic but potentially curable (hepatic/pulmonary-resectable) disease?

Study | Characteristics of Quality Measure | Comments/Quality Scoring
Colon Cancer Workgroup, 2003 | Quality measure (QM): Adjuvant chemotherapy is administered to patients with lymph node positive colon cancer | General comments:
# 36650 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guide) | Older patients or those with comorbidities may not receive chemotherapy.
| Type of QM: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| (b) General
| Outcome to which the QM is linked: Improved health status
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients having colon cancer resection.
| Numerator:
| Number of above patients receiving combination chemotherapy.
| Data sources: Medical records
| Recommended frequency of data collection: No recommendation
Institute of Medicine report, 2005 | Quality measure (QM): Adjuvant chemotherapy after surgery for Stage III colon cancer | General comments:
#36680 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Stage III colon cancer refers to tumors that have spread through the wall of the colon or rectum into 1 to 4 regional lymph nodes and nearby tissues or organs. The current standard for chemotherapy is a 6-month course.
| Type of QM: | Older patients are less likely to receive recommended adjuvant chemotherapy, despite evidence that they tolerate it well. Race, marital status, hospital volume and individual hospitals are also associated with receipt of adjuvant chemotherapy.
| (a) Process | Key references cited:
| (b) General | Ayanian et al., 2003
| Outcome to which the QM is linked: | Moore and Haller, 1999
| Intent of QM: Quality improvement | NCCN, 2004
| Definition of denominator/numerator: | Neugut et al., 2002
| Denominator: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Number of patients with Stage III colon cancer who undergo surgery. | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Numerator:
| Number of above patients who receive a full course of adjuvant chemotherapy after surgery.
| Data sources: Surveillance, Epidemiology and End Results Program (SEER)-Medicare dataset, medical records
| Recommended frequency of data collection: No recommendation
National Committee for Quality Assurance, 2005 | Quality measure (QM): Percent of late-stage CRC cancer cases (stage ≥ III) that received one or more courses of adjuvant chemotherapy within 1 year of initial cancer surgery | General comments: None
#36580 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| (a) Process
| (b) General
| Outcome to which the QM is linked: Improved health status
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of newly diagnosed colon cancer cases (stage ≥ III) that received surgical treatment in a 12-month period.
| Numerator:
| Number of above who received one or more courses of adjuvant chemotherapy within 1 year of surgery.
| Data sources: Cancer registry, claims data
| Recommended frequency of data collection: No recommendation

Evidence Table 9 - Question 2d (Published Literature): As appropriate to specific stages of colorectal cancer, what quality-of-care measures are available and what evidence is available for measures of quality of care of treatment of colorectal cancer, including appropriate use of radiation therapy for either curative or palliative therapy, specifically for rectal cancers?

Study | Characteristics of Quality Measure | Testing of Quality Measure | | | | | Comments/Quality Scoring
Ayanian, Zaslavsky, Fuchs, et al., 2003 | Quality measure (QM): Use of adjuvant radiation therapy in patients with stage II or III rectal cancer | Study population: | | | | | General comments:
#34680 | Basis of QM: Other (1990 NIH Consensus Conference) | Eligible for radiation therapy: | | | | | Article attempts to estimate underreporting of adjuvant therapies in routinely collected registry data by comparing registry data with office records and physician surveys.
| Type of QM: | N: 534 | | | | | Because the standard of care is chemo-radiotherapy, this QM would have been more important if it had been modified to the use of adjuvant chemo/radiotherapy after resection of stage II and III rectal cancer.
| (a) Process | Age: 18 to > 85 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 5; - Adaptability: 5; - Adequacy of risk adjustment: 1
| (b) General | Race: 73.4% white
| Outcome to which the QM is linked: Decreased local/regional recurrence. | Sex: 45.9% female
| Intent of QM: Not specified (aim of the study was to estimate underreporting of adjuvant therapies in routinely collected registry data, assess rates of adjuvant therapies and factors associated with use, and ascertain reasons why eligible patients were not treated) | Tumor stage: Rectal stage III 46.8%, rectal stage II 53.2%
| Definition of denominator/numerator: | Performance status: 64.8% comorbidity score 0, 19.3% 1, 15.9% ≥ 2
| Denominator: | Geographic location: San Francisco/Oakland, San Jose/Monterey, and Sacramento, CA areas
| Number of subjects identified from registry records (3 regional registries within the California Cancer Registry) who were 18 years of age and older and diagnosed during 1996 and 1997 with stage II or III adenocarcinoma of the rectum, using staging criteria of the AJCC. Patients had undergone surgery and survived for at least 30 days. | Dates: 1996-97
| Numerator: | Healthcare setting: Hospitals
| Number of above subjects with rectal cancer who received adjuvant radiotherapy. | Results:
| Data sources: | 64% of eligible patients received radiation.
| California Cancer Registry | Sensitivity of routinely collected registry data was 93% for radiation therapy. Only 2% of patients had registry data indicating they had received radiation therapy but were reported by their physicians not to have received the therapy.
| Physician survey | Adjusted rates for radiation therapy for rectal cancer were most strongly associated with age. Older patients were less likely (p< .001) to receive radiation therapy than younger patients.
| Office records | Most common reasons cited for not giving adjuvant therapy: patient refusal, comorbid illness, lack of clinical indication.
| Recommended frequency of data collection: No recommendation
Baxter, Rothenberger, Morris, et al., 2005 | Quality measure (QM): Use of adjuvant radiation therapy in patients with AJCC stage II or III rectal cancer | Study population: | | | | | General comments:
#44990 | Basis of QM: National Institutes of Health (NIH) Consensus Conference | N: 45,627 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 5; - Adequacy of risk adjustment: 1
| Type of QM: | | RT Use | | No RT Use
| (a) Process | N | 14,571 | | 30,429
| (b) General | Median age | 65 | | 70
| Outcome to which the QM is linked: Decreased local/regional recurrence in patients with rectal cancer. | % male | 61 | | 55
| Intent of QM: To evaluate U.S. trends in adjuvant radiation therapy use over a 25-year period, timing of radiation therapy (pre- vs. postoperative) and factors affecting radiation delivery. | % Non AA | 94 | | 95
| Definition of denominator/numerator: | Seer Stage (%)
| Denominator: | Localized | 29 | | 67
| Number of patients ≥ 18 yrs. of age diagnosed with adenocarcinoma of the rectum between January 1976 through December 2000. | Regional | 64 | | 29
| Exclusion criteria: patients who had in situ or metastatic disease, patients with malignancies other than adenocarcinoma and patients who did not undergo some form of surgical therapy. | Unknown | 7 | | 4
| Numerator: | Grade (%)
| Number of above patients with stage II or III rectal cancer who received adjuvant radiotherapy. | Well diff. | 8 | | 15
| Data sources: | Moderate diff. | 62 | | 54
| Surveillance Epidemiology and End Results (SEER) cancer registry | Poor diff. | 19 | | 10
| Recommended frequency of data collection: No recommendation | Unknown | 11 | | 21
| | Geographic location: 14 SEER cancer registry sites across the U.S.
| | Dates: 1976-2000
| | Healthcare setting: Hospitals
| | Results:
| | | RT Use | | No RT Use
| | N | 14,571 | | 30,429
| | Year of Diagnosis | % | | %
| | 1976-1980 | 15 | | 85
| | 1981-1985 | 25 | | 75
| | 1986-1990 | 33 | | 67
| | 1991-1995 | 38 | | 62
| | 1996-2000 | 42 | | 58
| | Frequency of radiation therapy use for patients with rectal cancer increased substantially over study period: 12 percent underwent RT in 1976 compared to 42 percent in 2000 (p < 0.0001). For patients with regional spread, the percent receiving RT increased from 17% to 65%. Of those with regional spread who also underwent radical excision, 41% received RT in 1983 compared to 65% in 2000 (p < 0.0001).
| | By 2000, RT use for Stage II patients was 59%; for stage III, 68%. Increased use was almost entirely due to post operative RT use until 1996. Since then, postoperative use rate has declined while preoperative RT use has increased substantially (p < 0.0001).
| | Demographic differences in RT use exist. Patients who underwent RT tended to be younger (65 yrs) compared to those not undergoing RT use (70 yrs; p < 0.0001). They were more likely to be male (61% vs. 55%; p < 0.0001); they were also more likely to have regional spread (64%) than those who did not undergo RT (29%).
| | AAs were more likely to have received RT (35%) than non-AA (32%), p< .0003. AAs were also more likely to have regional disease (47 vs. 42%) than non-AAs, p < 0.00001.
| | Patients since 1988 | | | | Odds ratio for RT use
| | Age at diagnosis
| | > 70 | | | | 1
| | < 65 - ≤ 70 | | | | 3.03
| | ≤ 60 | | | | 4.95
| | Male | | | | 1
| | Female | | | | .81
| | Non AA | | | | 1
| | AA | | | | .77
| | AJCC tumor stage
| | II | | | | 1
| | III | | | | 1.76
| | Grade
| | Poorly differentiated | | | | 1
| | Moderate | | | | .79
| | Well | | | | .71
| | Type of surgery
| | Local | | | | 1
| | Radical | | | | 1.34
| | Male sex and younger age were predictors of RT use (p < 0.0001). AAs were less likely to undergo RT (p < 0.003) than non-AAs. Patients with poorly differentiated rectal cancer and those with AJCC stage II were significantly more likely to undergo RT use than those with well- or moderately differentiated rectal cancer or with AJCC stage II cancer (p < 0.0001). The year of diagnosis and geographic location by registry remained important predictors of RT use (p < 0.0001).
Beart, Steele Jr., Menck, et al., 1995 | Quality measure (QM): Percentage of patients with rectal cancer receiving radiotherapy | Study population: | | | | | General comments:
#990 | Basis of QM: None | N: 39,502 (10,293 with rectal cancer; 2051 with stage II or III) | | | | | The data for this study were generated prior to 1990 so it may not reflect more modern recommendations for management.
| Type of QM: | Age: Median 69.3 years for rectal cancer | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 3; - Validity: 3; - Adaptability: 5; - Adequacy of risk adjustment: 2
| (a) Process | Race: For entire study: African American, 9.1% for colon cancer and 6.5% for rectal cancer; Hispanic, 2.7% for colon cancer and 3.5% for rectal cancer. 1.4% of cases were Asian. The rest were Caucasian.
| (b) General | Sex: Male 57.2% (rectal)
| Outcome to which the QM is linked: None is specified, but presumably it would be survival | Tumor stage: All included (4.7% stage 0, 22.1% stage I, 29.2% stage II, 22.2% stage III, 18.7% stage IV, 3.0% unknown)
| Intent of QM: Not specified (aim of the study was to identify current trends in the management of patients with carcinoma of the colon or rectum and to identify changes in patterns of care and survival) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Entire U.S.
| Denominator: | Dates: Calendar years 1983 and 1988
| Number of subjects with stage II or III rectal cancer seen in 1988 from amongst cases of colon and rectal cancer (up to 25 per program or facility) reported by over 1200 approved cancer programs and 800 other facilities on the Commission on Cancer mailing list that were invited to participate. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of above subjects receiving chemoradiotherapy. | | Colon Cancer | | Rectal Cancer
| Data sources: Hospitals sent in up to 25 consecutive cases from their medical records | | 1983 | 1988 | 1985 | 1988
| Recommended frequency of data collection: No recommendation | Chemo- therapy | 10.7 | 11.1 | 5.9 | 5.6
| | Radiation therapy | 2.7 | 10.9 | 15.3 | 13.8
| | Combined chemo and RT | 1.5 | 1.6 | 5.5 | 10.1
Coburn, Pricolo, and Soderberg, 1994 | Quality measure (QM): Adjuvant therapy rates | Study population: | | | | | General comments:
#2920 | Basis of QM: None | N: 800 | | | | | Data collected between 1961 and 1987.
| Type of QM: | | < 80 years | | > 80 years | | Other factors that affect mortality rates in the elderly: more aggressive biologic behavior of cancer of the colon and rectum in the elderly, with aggressive local disease and less tendency towards distant dissemination, greater tendency of colon cancer to be right-sided, rarity of adjuvant therapy administered to older patients, higher complication rate in elderly patients due to comorbid conditions, and greater frequency of obstructing and perforated lesions.
| (a) Process | N | 177 | | 623 | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 2; - Adequacy of risk adjustment: 2
| (b) General | Sex (F%/M%) | 48/52 | | 56/44
| Outcome to which the QM is linked: None | Rectal lesions | 36 | | 23
| Intent of QM: Not specified (aim of the study was to perform univariate and multivariate analyses of poor indicators in the elderly undergoing colorectal operation, and to compare clinical, pathologic, and therapeutic factors in patients younger than and older than 80 years of age) | Duke stage
| Definition of denominator/numerator: | A | 9.0 | | 6.0
| Denominator: | B1 | 16.7 | | 12.8
| Number of subjects who had received operative treatment for colon and rectal cancer between 1961 and 1987. | B2 | 31.2 | | 42.7
| Numerator: | C1 | 4.5 | | 0
| Number of above subjects who received adjuvant therapy (chemo- or radiotherapy). | C2 | 21.5 | | 21.8
| Comparisons were made between patients under and over 80 years. | D | 17.1 | | 16.7
| Data sources: Inpatient, outpatient, and office records | Geographic location: Rhode Island, U.S.
| Recommended frequency of data collection: No recommendation | Dates: 1961 and 1987
| | Healthcare setting: Academic institute
| | Results:
| | Adjuvant therapy rate was 5.1% for patients > 80 yrs and 20% for patients < 80 yrs.
| | Long-term survival (at 5 and 8 yr) and rate of recurrence after curative therapy were used to validate the measure.
| | There was a statistically significant difference in survival rates: 48% for patients < 80 vs. 32% for patients > 80.
| | There was no statistically significant difference between the groups with regard to recurrence after curative therapy.
Demissie, Oluwole, Balasubra-manian, et al., 2004 | Quality measure (QM): Non-receipt of standard radiation treatment | Study population: | | | | | General comments:
#31380 | Basis of QM: Clinical practice guideline (NIH guidelines) | Characteristic | Male | | Female | | The intent-to treat and treatment received analyses are compared, and the former is stated to be a more valid comparison.
| Type of QM: | | White | Black | White | Black | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 4
| (a) Process | n | 49,359 | 4383 | 47,803 | 4832
| (b) General | < 84 yr | 92.5 | 95.3 | 84 | 92
| Outcome to which the QM is linked: | AJJCC Tumor Stage
| Intent of QM: Not specified (aim of the study was to examine colorectal cancer treatment differences between races with comparable disease at presentation) | II | 26.84 | 23.07 | 24.18 | 20.99
| Definition of denominator/numerator: | II | 29.54 | 26.44 | 32.49 | 28.04
| Denominator: | III | 22.66 | 23.02 | 23.77 | 24.71
| Number of white or black subjects diagnosed with rectal cancer between Jan 1, 1988 and Dec 31, 1997. | IV | 16.76 | 22.36 | 15.7 | 20.88
| Exclusion criteria: Subjects neither white nor black, unknown treatment history, cancer diagnosed at autopsy, in-situ tumor or carcinoid tumor, rare histological types. | Unknown | 4.2 | 5.11 | 3.87 | 5.38
| Numerator: | Geographic location: SEER geographic regions
| Number of above subjects not receiving radiation therapy (defined as beam radiation, radioactive implants, radioisotopes, or a combination of these). | Dates: 1988-1997
| Comparisons were made between blacks and whites. | Healthcare setting: Mixed
| Data sources: SEER database | Results:
| Recommended frequency of data collection: No recommendation | While there is no significant racial difference in radiation therapy for stages II and IV rectal cancer, notable differences exist for stage I and stage III rectal cancer. For stage III rectal cancer, blacks had a higher risk of non-receipt of radiation therapy. For stage I, black males had a lower likelihood of non-receipt of radiation therapy.
| | Odds of non-receipt of radiation therapy for rectal cancer for blacks as compared with whites by sex (whites formed the reference group):
| | Radiation therapy | Male | | Female
| | | unadjusted | adjusted | unadjusted | adjusted
| | AJCC stage I | 0.5 | 0.51 | 0.93 | 0.96
| | AJCC stage II | 0.67 | 0.81 | 1.22 | 1.37
| | AJCC stage III | 1.67 | 2.04 | 1.14 | 1.54
| | AJCC stage IV | 0.92 | 1.03 | 1.23 | 1.43
| | unstaged | 0.81 | 1.00 | 0.86 | 1.04
| | (adjusted for age, tumor grade and histology)
| | Black-to-white disparity in non-receipt of radiation therapy was more prominent when actual treatment received rather than intent-to-treat was considered. Number of patients who refused treatment:
| | Stage I: 32.8% black and 9.2% white males and 19.4% black and 12.8% white females.
Dominitz, Samsa, Landsman, et al., 1998 | Quality measure (QM): Percentage of patients with colorectal cancer receiving radiation therapy | Study population: | | | | | General comments:
#9380 | Basis of QM: None | N: 2,607 whites + 569 blacks | | | | | The article compares rates of surgery, radiotherapy, and chemotherapy among blacks and whites. No attempt is made to compare to a gold standard (e.g., a guideline) to determine whether the rates in blacks or whites are optimal.
| Type of QM: | Age: 67.1 ± 9.1 (whites); 66.4 ± 9.9 (blacks) | | | | | The study is limited because of its use of an administrative database that lacked clinical details and did not allow for adjustment to disease severity.
| (a) Process | Race: See above | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 1; - Adaptability: 1; - Adequacy of risk adjustment: 1
| (b) General | Sex: 100% male
| Outcome to which the QM is linked: Survival | Tumor stage: All stages
| Intent of QM: Not specified (aim of the study was to assess the influence of race on the treatment and survival of patients with colorectal carcinoma) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: VA Medical Centers
| Denominator: | Dates: 1989
| Number of white/black patients with colorectal cancer identified from the VA Patient Treatment File (PTF) who were discharged from VA hospitals with a diagnosis of CRC (ICD-9-CM codes 153.0–153.4, 153.6–154.1) during fiscal year 1989. To exclude prevalent cases, any patient with a diagnosis of CRC (ICD-9-CM codes 153.0–153.4, 153.6–154.1, V10.05–V10.06 ) for hospitalization during FY 1984-1988, or a personal history of CRC (ICD-9-CM codes V10.05–V10.06) during the index hospitalization, was excluded. Male veterans only. No ulcerative colitis or Crohn's disease. | Healthcare setting: VA Hospitals
| Numerator: | Results:
| Number of above white/black patients treated with radiation therapy, as indicated by specific ICD-9-CM codes in the PTF. | No statistically significant differences in rates of radiation therapy in blacks vs. whites.
| Data sources: VA PTF | No difference in 5-year relative survival or overall survival in blacks vs. whites.
| Recommended frequency of data collection: No recommendation
Govindarajan, Shah, Erkman, et al., 2003 | Quality measure (QM): Percentage of patients with stage II, III colorectal cancer receiving radiation therapy | Study population: | | | | | General comments:
#35310 | Basis of QM: None | N: 617 | | | | | It is not possible to use the QM “rates of use of radiation” because they grouped colon and rectal cancer together, but radiotherapy is only indicated for rectal cancer.
| Type of QM: | All figures below for Caucasians/AAs | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 1; - Adaptability: 1; - Adequacy of risk adjustment: 1
| (a) Process | Age: 60.0/61.5
| (b) General | Race: 427 Caucasians/190 AAs
| Outcome to which the QM is linked: Not firmly linked to any outcome, but presumably to survival, quality of life, or rates of local recurrence | Sex: 47.1% male/39.5% male
| Intent of QM: Not specified (aim of the study was to analyze disease stage, treatment received, and socioeconomic factors to better understand the factors influencing survival differences between African-Americans and Caucasians with colorectal cancer) | Tumor stage: Stages 0–IV
| Definition of denominator/numerator: | Performance status: NR
| Denominator: | Other:; - Not high school grad: 45%/60%; - Low income: 45%/64%; - High poverty: 41%/68%
| Number of African-Americans (AAs)/Caucasians, aged 18 older, with CRC treated between 1984 and 1997 at a state-funded University hospital located in Arkansas, identified through the hospital tumor registry using appropriate tumor registry codes. | Geographic location: Arkansas
| Numerator: | Dates: 1984-1997
| Number of above AAs/Caucasians treated with radiation therapy. | Healthcare setting: University hospital
| Data sources: Tumor registry at Univ. of Arkansas | Results:
| Recommended frequency of data collection: No recommendation | Authors show that significantly higher percentages of Caucasians received radiation therapy, compared with AAs, for patients with all stages of CRC, and for patients with only stages II and III disease.
| | Cancer-specific mortality was higher in African-Americans than in Caucasians for all stages.
Kline, Smith, Coia, et al., 1997 | Quality measure (QM): Adherence to radiotherapy management treatment guidelines for patients with adenocarcinoma of the rectum and sigmoid colon | Study population: | | | | | General comments:
#12070 | Basis of QM: Clinical practice guideline (Patterns of Care Study Treatment-Planning Committee consensus guidelines) | N: NR | | | | | This paper describes a number of very technical measures of quality relevant to radiation therapy rather than a more general measure of whether the radiation was performed at all for a particular indication.
| Type of QM: | Age: NR | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 5; - Adaptability: 5; - Adequacy of risk adjustment: 1
| (a) Process | Race: NR
| (b) Technical | Sex: NR
| Outcome to which the QM is linked: Not specifically stated, but presumably reduction in complications due to radiation therapy, reduction in local-regional recurrence, or improved survival | Tumor stage: NR
| Intent of QM: Not specified (aim of the study was to conduct a study of the process of treatment planning and treatment of adenocarcinoma of the rectum and sigmoid in the U.S., and to compare survey results to consensus guidelines) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: U.S.
| Denominator: | Dates: 1989-90
| Number of cases of cancer of rectum or sigmoid colon treated 1989-90 at one of 75 facilities selected from among a random sample of all U.S. facilities administering megavoltage radiation therapy. | Healthcare setting: Academic, hospital-based, and free-standing radiation therapy centers
| Numerator: | Results:
| Number of above patients receiving radiotherapy according to treatment guidelines. | Adherence to a variety of guideline measures reported in the study. For example:
| Data sources: 1989-90 PCS Survey | Guideline: “Information from a pelvic CT may be useful in determining field borders.”
| Recommended frequency of data collection: No recommendation | Result of survey: CT used for radiation therapy planning in only 17–21% of cases.
| | Other radiation therapy quality indicators assessed include:; 1 Placement of clips by surgeon when tumor adherent to other pelvic structures.; 2 Isodose distribution generated for dose prescription.; 3 Beam energy used should be ≥ 4 MV.; 4 At least 3 radiation therapy fields should be used.; 5 Fields should be shaped with custom blocks.; 6 Wedges or compensators should be used as needed.; 7 Port films should be taken.; 8 Patients should be simulated with contrast in rectum.; 9 A small bowel series should be done if the total dose will exceed 50 Gy.; 10 Prone setup used.
Merrill, Brown, Potosky, et al., 1999 | Quality measure (QM): Percentage of CRC patients who had radiotherapy | Study population: | | | | | General comments:
#27110 | Basis of QM: None | N: 15,352 total | | | | | A very high-quality study by experienced researchers.
| Type of QM: | Age: ≥ 65 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 5
| (a) Structure | Race: 81.2 to 95.3% white depending on subgroup
| (b) General | Sex: 46.8 to 54.3% male, depending on subgroup
| Outcome to which the QM is linked: Presumably survival | Tumor stage: 0–IV
| Intent of QM: Not specified (aim of the study was to compare treatment utilization and long-term survival in HMO and fee-for-service [FFS] settings for Medicare colorectal cancer cases) | Performance status: NR
| Definition of denominator/numerator: | Comorbidity Index: 0–2+
| Denominator: | Geographic location: San-Francisco-Oakland area, Seattle-Puget Sound area
| Number of CRC patients in each subgroup of the dataset (see Data sources, below). | Dates: 1985-1992
| Numerator: | Healthcare setting: 2 tumor registries participating in the SEER Program augmented with Medicare data along with HMOs KPNC and GHC.
| Number of above patients who had adjuvant radiotherapy. | Results:
| Data sources: | The standardized rate of adjuvant radiotherapy use following surgery was significantly higher among HMO cases (44%, 95% CI 37%-50%) than among FFS cases (35%, 95% CI 33–38%).
| 1 Two tumor registries on colon and rectum cancer patients diagnosed 1985-92 and followed up through 31 December 1994. Both registries are part of SEER.; 2 Medicare inpatient claims data.; 3 Databases of two HMO plans, Kaiser Permanente of Northern California and Group Health Cooperative of Puget Sound.; 4 1990 U.S. Census | Cancer-specific mortality rates were similar in both settings.
| Recommended frequency of data collection: No recommendation
Minsky, Coia, Haller, et al., 1998 | Quality measure (QM): Use of modern radiation therapy techniques; adherence to recommendations of NCI-sponsored RCT in rectal cancer patients. | Study population: | | | | | General comments: None
#9280 | Basis of QM: Other: (use of modern radiation therapy techniques as defined by consensus of experts [Patterns of Care Rectal Cancer Committee]; adherence to RCT recommendations described as above) | N: 507 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 3; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 3; - Validity: 3; - Adaptability: 5; - Adequacy of risk adjustment: 1
| Type of QM: | Age: 64
| (a) Process | Race: NS
| (b) General/Technical | Sex: 64% male
| Outcome to which the QM is linked: Presumably locoregional recurrence, survival, and reduction in radiation therapy-related complications | Tumor stage: Tis-3, N0–N3
| Intent of QM: Not specified (aim of the study was to determine the U.S. national practice standards for patients with adenocarcinoma of the rectum treated in radiation oncology facilities) | Performance status: 83% KPS 90–100
| Definition of denominator/numerator: | Differentiation: 65% moderate
| Denominator: | Resection margins: 66% negative
| Number of patients with rectal cancer treated with curative intent from 1992-1994, with no evidence of extrapelvic disease, micro or gross residual disease after surgery, or prior or concurrent malignancies or treatment for rectal cancer, who received radiation therapy as a component of their definitive or adjuvant management, and who were identified from a facilities survey conducted by the PCS. | Geographic location: U.S.
| Numerator: | Dates: 1992-94
| Number of above patients whose radiation therapy conformed to recommendations of the expert panel (on various technical dimensions); subset of above patients whose treatment adhered to specific recommendations of the NCI RCTs. | Healthcare setting: All U.S. radiation oncology facilities
| Data sources: PCS national survey | Results:
| Recommended frequency of data collection: No recommendation | Radiation therapy details:
| | Many factors considered indicative of high-quality radiation therapy were measured in the survey. For example, radiation therapy field arrangement was AP/PA in 11% of patients, 3 or 4 fields in 92%, and unknown in < 0.5%. For full details, see Table 4, p. 2545.
| | Chemotherapy details:
| | Receipt of chemotherapy was documented in the study but the study did not address adherence to treatment guidelines with respect to chemotherapy.
| | Surgery details:
| | Type of surgery performed was documented but no attempt was made to determine if the “correct” surgical procedure was done, or to assess surgical complication rates.
Morris, Billingsley, Baxter, et al., 2004 | Quality measure (QM): Rate of radiation therapy use for stage II, III rectal cancer | Study population: | | | | | General comments: None
#32200 | Basis of QM: Not specified, but appears to be NIH Consensus conference | N = 52,864 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):; - Importance: 4; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 3; - Validity: 3; - Adaptability: 5; - Adequacy of risk adjustment: 1
| Type of QM: | | White | | Black
| (a) Process | n | 44010 | | 3851
| (b) General | Age (%)
| Outcome to which the QM is linked: No explicit outcome link, but presumably to decreased rates of LRR or improved OS | 35–64 | 35 | | 49
| Intent of QM: Aim of the study was to investigate racial variation in the performance of sphincter-sparing procedures for patients with stage II and III rectal cancer who underwent surgery, and to study race and delivery of any surgical treatment, neoadjuvant therapy, and radiation therapy to these patients, with implications for quality of care. | 65–79 | 46 | | 40
| Definition of denominator/numerator: | 80+ | 20 | | 12
| Denominator: | Male (%) | 55 | | 52
| Number of blacks/whites diagnosed with rectal cancer and entered into the SEER database 1988-1999. | Tumor stage (%)
| Exclusion criteria: Prior diagnosis of CRC, prior diagnosis of cancer requiring surgery or radiotherapy in the pelvis, or < age 35. | insitu | 9 | | 8
| Numerator: | I | 3 | | 28
| Number of above patients who received various treatments for CRC including surgery (also type of operation) and radiation (timing of RT also evaluated). | II | 21 | | 20
| Data sources: SEER registry | III | 19 | | 18
| Recommended frequency of data collection: No recommendation | IV | 14 | | 17
| | unstaged | 8 | | 10
| | Geographic location: SEER regions
| | Dates: 1988-1999
| | Healthcare setting: U.S. healthcare facilities
| | Results:
| | N = 18,927 | Radiation Treatment rate (%) | | Adjusted OR (95% CI)
| | | Any | None
| | White | 47 | 53 | 1.30 (1.15–1.47)
| | Black | 44 | 56
| | N = 18,560 | Neoadjuvant Radiation Treatment Rate (%) | | Adjusted OR (95% CI)
| | White | 7 | 93 | 1.04 (.87–1.36)
| | Black | 7 | 93
Neugut, Fleischauer, Sundararajan, et al., 2002 | Quality measure (QM): Use of radiotherapy in stage II and III rectal cancer patients among the elderly | Study population: | | | | | General comments:
#18450 | Basis of QM: Clinical practice guideline (NIH and NCCN) | N: 1,807 | | | | | Impossible from this dataset to ascertain if the frequency of adjuvant use was “optimal” in the population under study. For example, omission of chemotherapy in an elderly patient with stage III rectal cancer may be a medically sound decision if the patient has significant comorbidities.
| Type of QM: | Age: 65–85+ | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | Race: 1592 non-Hispanic white | | | | | - Importance: 4; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 3; - Validity: 3; - Adaptability: 5; - Adequacy of risk adjustment: 1
| (b) General | Sex: 964 female
| Outcome to which the QM is linked: Rates of LRC, DM, and OS | Tumor stage: II (983). III (824)
| Intent of QM: Not specified (aim of the study was to investigate the use of treatment with adjuvant 5-FU-based chemotherapy and radiation therapy among patients over 65 years of age with surgically resected stage II or III rectal cancer) | Performance status: NR
| Definition of denominator/numerator: | Charlson-Deyo comorbidity score: 0 (1098), 1 (299), > 1 (410)
| Denominator: | Geographic location: SEER geographic regions
| Denominator: | Dates: 1992-96
| Number of patients with histologically confirmed primary rectal cancer, diagnosed 1992-1996, stage II–III, age ≥ 65, s/p surgical tumor resection, eligible for Medicare Parts A and B in the 12 mo before diagnosis and 120 days after diagnosis, and had survived more than 4 mo after diagnosis. Excluded members of HMO in the 12 mo before and 4 mo after their diagnosis. | Healthcare setting: U.S. facilities
| Numerator: | Results:
| Number of above patients who received radiation therapy. | 48% of cohort received radiation therapy (11% received postoperative radiation therapy alone, 37% received chemoradiotherapy).
| Data sources: SEER-Medicare database | Age was associated with the overall use of radiation.
| Recommended frequency of data collection: No recommendation
Newcomb and Carbone, 1993 | Quality measure (QM): Rate of adjuvant radiation therapy for colorectal cancer | Study population: | | | | | General comments:
#3760 | Basis of QM: None mentioned, but presumably practice guideline | N: 121 with colorectal | | | | | Relying on recall of patients for whether they received a treatment is open to bias.
| Type of QM: | Age: 20–74 | | | | | The data on radiation treatment is not arranged by stage or location of large bowel cancer. Only rectal cancer and locally advanced colon cancer would typically be radiated. Therefore the results may not be conclusive.
| (a) Process | Race: NR | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (b) General | Sex: Female | | | | | - Importance: 5; - Usability: 3; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 4; - Validity: 4; - Adaptability: 5; - Adequacy of risk adjustment: 1
| Outcome to which the QM is linked: Not specified, but presumably survival | Tumor stage: All stages
| Intent of QM: Not specified (aim of the study was to evaluate the selection of cancer treatment among the elderly) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Wisconsin
| Denominator: | Dates: Sep 1 through Nov 30, 1990
| Number of women residents of Wisconsin aged 20–74 at the time of diagnosis with a new diagnosis of carcinoma of the large bowel during 1989-1991, and who had a listed telephone number and spoke English, and whose physician consented to their participation, and who agreed to a telephone interview, and were among the 628 consecutive participants interviewed September 1, 1990 through November 30, 1990. | Healthcare setting: None (all participants were outpatients contacted by phone)
| Numerator: | Results:
| Number of subjects receiving radiation therapy. | 14% of patients < 65 years of age and 18% ≥ 65 received radiation therapy.
| Data sources: Registry for staging information and patient interviews (for the treatment information)
| Recommended frequency of data collection: No recommendation
O'Connell, Maggard, Liu, et al., 2004 | Quality measure (QM) | Study population: | | | | | General comments:
#45210 | Radiation therapy rate | N = 11,778 | | | | | The SEER registry maintains stringent quality control measures to prevent coding errors and is regarded as one of the best population based databases; however, miscoding and inaccurate data may be present. The registry does not contain all clinically relevant data, such as family history, predisposing factors, etc. A third limitation of the SEER data is that tumor stage or grade was unknown for a number of patients. Another limitation of the study is the substantially smaller sample of young rectal cancer patients compared with the large number of older patients, leading to overestimation of differences.
| Basis of QM: NIH Consensus Conference Guidelines for adjuvant therapy for colorectal cancer | | 20–40 yrs (young) N = 466 | 60–80 yrs (old) N = 11,312 | P-value | | Rating of quality measures as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | Age | 34.1± 4.5 | 70± 5.5 | | | - Importance: 2; - Usability: 5; - Scientific acceptability; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 3
| (a) Process | Male % | 54.9 | 60 | .03
| (b) General | Race
| Intent of QM: Not specified. Aim of study was to compare rectal cancer patient outcomes between young and older populations. | White | 62.6 | 82.3 | <.001
| Definition of denominator/numerator: | Black | 12.7 | 6.1 | <.001
| Denominator: | Hispanic | 8.8 | 3.7 | <.001
| Patients in the SEER database diagnosed with rectal cancer between 1991 and 1999. Tumors identified as “rectum” in location were selected. Specific histologies were chosen to include only adenocarcinomas. | Asian | 7.5 | 6.4 | NS
| Exclusion criteria: Patients with tumors identified as rectosigmoid. Mucinous, signet ring cell, carcinoid, sarcoma and lumphoma histologies were excluded along with those tumors classified as benign or in situ. | other | 8.4 | 1.5 | <.001
| Numerator: | AJCC stage
| Number of above patients who received t radiation therapy subsequent to diagnosis. | I | 17 | 23.7 | <.001
| Data sources: SEER databse | II | 15.5 | 17.8 | NS
| Frequency of data collection: No recommendation | III | 27 | 20 | <.001
| | IV | 17.4 | 13.6 | .02
| | Grade
| | Well | 7.5 | 9.4 | NS
| | Moderate | 50.4 | 61.2 | <.001
| | Poorly | 24.3 | 14 | <.001
| | Anaplastic | 1.7 | 0.7 | .008
| | Unknown | 16.1 | 14.7 | NS
| | Geographic location: U.S.
| | Dates: 1991-1999
| | Healthcare setting: Hospital setting
| | Results:
| | More young patients received radiation therapy both overall and stage-for-stage. Overall, 57.4 percent of young patients and 39.7 of older patients received radiation (p < 0.0001). Similar results were found by stage where a greater share of younger patients received radiation compared to older patients.
| | Median survival was 24 months for the young group and 27 months for the older group. Univariate analysis revealed overall 5-year survival was similar for the young group compared with the older (63.2 vs. 62.1%, p = NS). Five-year, stage-specific survival also was similar for all stages.
| | Multivariate Cox regression analysis revealed that young, rectal cancer patients had a lower hazard of dying (hazard ratio, .693, p = 0.0004) when controlling for tumor stage, patient demographics, tumor characteristics and stage and treatment.
Roetzheim, Pal, Gonzalez, et al., 2000 | Quality measure (QM): Percentage of patients with a colon or rectal cancer diagnosis who received radiation therapy | Study population: | | | | | General comments:
#23910 | Basis of QM: None stated (see General comments) | N: 9,548 | | | | | Existing guidelines are for stage III colon cancer and stage II or III rectal cancer only, so measuring and reporting data on all radiation therapy for all stages of colon or rectal cancer is not guideline- or evidence-driven.
| Type of QM: | Patient characteristic | | | | Percent | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | Male | | | | 51 | - Importance: 5; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (b) General | Race
| Outcome to which the QM is linked: Mortality | White | | | | 85
| Intent of QM: Not specified (aim of the study was to explore the influence of race/ethnicity and insurance payer on the treatment of and outcomes for colorectal cancer patients in Florida) | Black | | | | 6
| Definition of denominator/numerator: | Hispanic | | | | 8
| Denominator: | Diagnosis stage
| Number of incident cases of colon or rectal cancer occurring in Florida in 1994 as listed in the state tumor registry. | In situ | | | | 6
| Numerator: | Local | | | | 30
| Number of the above patients who also received radiation therapy within 4 months of initiation of therapy (stratified by colon or rectal cancer). | Regional | | | | 42
| Data sources: Florida state cancer registry (Florida Cancer Data System = FCDS); Florida Agency for Health Care Administration AHCA discharge abstracts (admissions to all nonfederal acute care hospitals and patient visits to ambulatory surgical centers, freestanding radiation therapy centers and diagnostic imaging centers) | Distant | | | | 16
| Recommended frequency of data collection: No recommendation | Unstaged | | | | 6
| | Anatomic site
| | Colon | | | | 84
| | Rectal | | | | 16
| | Comorbidity index
| | 0 | | | | 71
| | 1 | | | | 21
| | ≥ 2 | | | | 8
| | Geographic location: Florida
| | Dates: 1994
| | Healthcare setting: Multiple
| | Results:
| | 26% of patients received radiation therapy but no validity testing was done for radiation therapy.
| | There were no racial differences in the use of radiation therapy. Among Medicare patients, those having HMO insurance types were less likely to receive radiation therapy, an effect that was primarily restricted to patients with colon cancer. Among Non-Medicare patients, there were no insurance-related differences in the receipt of radiation therapy. Other predictors of using radiation therapy included younger age, lower levels of income, non-urban residence, being married, having rectal cancer, and having lower levels of comorbidity.
Rogers, Ray, and Smalley, 2004 | Quality measure (QM): Percentage of patients with a diagnosis of stage III colorectal cancer receiving radiation therapy for rectal cancer | Study population: | | | | | General comments:
#30130 | Basis of QM: Not stated | N: 969 total (19.3% rectal cancer) | | | | | Study concluded that when there was equal access to care, outcomes were equal in whites and blacks.
| Type of QM: | Age: 78.9 ± 7.5 years | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | Race: 272 black (28%), 697 white (72%) | | | | | - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 5; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (b) General | Sex: 73.9% female (whites), 72.4% female (Blacks)
| Outcome to which the QM is linked: Not stated, but presumably survival or recurrence of colorectal cancer | Tumor stage: 75.6% (whites) and 72.1% (blacks) had stage III disease
| Intent of QM: Not specified (aim of the study was to examine the effect of race on CRC outcomes in patients who had identical health care coverage) | Performance status: Charlson Deyo score of 0 in 64% (whites) and 69% in Blacks
| Definition of denominator/numerator: | Geographic location: Tennessee
| Denominator: | Dates: 1984-1994
| Number of patients enrolled in both Tennessee Medicaid and Medicare and hospitalized with a diagnosis of colorectal cancer. | Healthcare setting: Patients identified from hospitalizations
| Numerator: | Results:
| Number of above patients who received radiation therapy within 180 days of diagnosis. | 4.3% of whites and 12.9% of blacks received radiation therapy (p = 0.001). There was no difference in survival between whites and blacks.
| Data sources: Medical records, administrative files from the Tennessee Medicaid program, Tennessee death certificates, and the National Death Index
| Recommended frequency of data collection: No recommendation
Schrag, Gelfand, Bach, et al., 2001 | Quality measure (QM): Percentage of patients with stage II or III rectal cancer receiving chemoradiotherapy | Study population: | | | | | General comments:
#21280 | Basis of QM: NIH consensus statement | N: 1,411 | | | | | The data for this study were generated prior to 1990 so it may not reflect more modern recommendations for management.
| Type of QM: | Age: > 65 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | Race: 88% white, 4% black, 8% other | | | | | - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 3
| (b) General | Sex: Male 54%
| Outcome to which the QM is linked: None is specified, but presumably it would be pelvic recurrence | Tumor stage: Stage II, III
| Intent of QM: Not specified (aim of the study was to examine the relationship between patient characteristics and the use of adjuvant radiotherapy with and without chemotherapy among patients 65 years of age and older with stage II and II rectal cancer) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: 5 states and 6 U.S. metropolitan areas
| Denominator: | Dates: 1992-1996
| Number of patients aged 65 years and older enrolled in Medicare A and B, diagnosed with primary rectal adenocarcinoma stage II or III, in a SEER area during the years 1991-1996 and not part of an HMO, and who had rectal cancer surgery performed within 6 months of primary diagnosis and who survived more than 6 months and who did not have a secondary cancer within 6 months. | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of patients who received radiotherapy (and chemotherapy) within 6 months of surgery. | 57% of patients received radiotherapy (42% with chemotherapy and 15% radiation alone).
| Data sources: Linkage of SEER population-based cancer registries with Medicare database of HCFA
| Recommended frequency of data collection: No recommendation
Steele Jr., 1994 | Quality measure (QM): Percentage of patients with stage II or III rectal cancer receiving chemoradiotherapy | Study population: | | | | | General comments:
#35390 | Basis of QM: None | N: 5,495 | | | | | This paper addresses similar issues as in Beart et al. (1995; #990).
| Type of QM: | Age: Median 69.3 years for rectal cancer | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | Race: For entire study: African American, 9.1% for colon cancer and 6.5% for rectal cancer; Hispanic, 2.7% for colon cancer and 3.5% for rectal cancer. 1.4% of cases were Asian. The rest were Caucasian. | | | | | - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 3; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (b) General | Sex: Male 57.2% (rectal).
| Outcome to which the QM is linked: None specified, but presumably it would be survival | Tumor stage: All included (4.7% stage 0, 22.1% stage I, 29.2% stage II, 22.2% stage III, 18.7% stage IV, 3.0% unknown
| Intent of QM: Not specified (aim of the study was to assess cancer patient care and outcomes on a national basis) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Entire U.S.
| Denominator: | Dates: Calendar years 1983 and 1988
| Number of patients with stage II, III rectal cancer in 1990 reported to the National Cancer Data Base (NCDB). | Healthcare setting: Hospitals
| Numerator: | Results:
| Number of above patients receiving chemoradiotherapy. | Not specifically stated, but can be calculated form Table 19. 43% of stage II or III patients received surgery and radiation (with or without chemotherapy).
| Data sources: Registry information reported to National Cancer Data Base (NCDB)
| Recommended frequency of data collection: No recommendation
Steele, 1994, #35840 | Quality measure (QM): Percentage of stage II and III rectal cancer patients who underwent radiation therapy | Study population: | | | | | General comments:
| Basis of QM: Clinical practice guideline | Data given as patients (year) | | | | | Some “treatment” data are presented, but these are not stratified by stage or location (colon vs. rectum) and therefore do not provide sufficient information to count as a QM. Only survival would be a potential QM from this paper.
| It is implicit that the AHCC guidelines be followed but these are not actually cited in the article. There are also guidelines for chemotherapy in stage III colon cancer and chemo/radiation therapy for stage II and III rectal cancer (NCC), but these are not cited by the authors. | N: 18,418 (85/86); 17,348 (91) | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | Age: Median 72.7 (85/85); 73.0 (91) | | | | | - Importance: 4; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 3; - Adequacy of risk adjustment: 4
| (a) Process | Race:
| (b) General | Non-hispanic whites 88.0% (85/85) 86.9% (91)
| Outcome to which the QM is linked: No outcome is exactly linked to the above but is said to be a marker of appropriate cancer diagnosis and treatment. No citation is provided for this statement. | Hispanics 1.6/2.3
| Intent of QM: Not specified (aim of the study was to assess cancer patient care and outcomes on a national basis) | African-Americans 4.7/6.3
| Definition of denominator/numerator: | Asian 1.2/2.2
| Denominator: | Unknown 4.5/2.3
| Number of patients in the National Cancer Daba Base (NCDB) with a new diagnosis of rectal cancer (rectosigmoid junction, rectum and anal canal) in the years 1985-1986 or 1991. | Sex: Male 55.3% (85/85) 55.7% (91)
| Numerator: | Tumor stage: 85–86/91
| Number of the above who underwent radiation therapy. | 0 5.8/5.0
| Data sources: National Cancer Data Base (NCDB) | 1 15.2/18.6
| Recommended frequency of data collection: No recommendation | 2 10.5/17.4
| | 3 12.2/20.0
| | 4 5.0/7.8
| | Unknown 51.3/31.2
| | Performance status: NR
| | Geographic location: National sample; note that the sample is not probabilistic and represented different hospitals in different years
| | Dates: 1991 and outcomes for 1985-86
| | Healthcare setting: 464 hospital in 1985, 474 hospitals in 1986, 937 hospitals in 1991
| | Results:
| | Treatment trends showed effects of trial data, as a greater percentage of patients were reported as having treatment (including chemotherapy) beyond surgery in 1991 as compared to 1985/86. Hispanics and African American patients were noted to have more advanced stage cancer (rectal).
Steele and Jessup, 1995 | Quality measure (QM): Percentage of patients with stage II or III rectal cancer receiving chemoradiotherapy | Study population: | | | | | General comments:
#35850 | Basis of QM: None | N: 9,465 | | | | | This paper addresses similar issues as Beart et al. (1995; #990), and Steele Jr. (1994; #35390) except that it includes data from 1992, whereas the others have data ending in 1988 and 1990.
| Type of QM: | Age: All | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | Race: All | | | | | - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 2; - Validity: 3; - Adaptability: 5; - Adequacy of risk adjustment: 1
| (b) General | Performance status: Not stated
| Outcome to which the QM is linked: None specified, but presumably it would be survival | Other: Not stated
| Intent of QM: Not specified (aim of the study was assess cancer patient care and outcomes on a national basis) | Geographic location: Entire U.S.
| Definition of denominator/numerator: | Dates: Calendar year 1986/7 and 1992
| Denominator: | Healthcare setting: Hospitals
| Number of stage II, III rectal cancer patients in 1992 reported to the National Cancer Data Base (NCDB). | Results:
| Numerator: | Not specifically stated, but can be calculated form Tables 5-13 that 46% of stage II or III patients received surgery and radiation (with or without chemotherapy).
| Number of above patients receiving chemoradiotherapy.
| Data sources: Registry information reported to National Cancer Data Base (NCDB)
| Recommended frequency of data collection: No recommendation
Temple, Hsieh, Wong, et al., 2004 | Quality measure (QM): Radiotherapy rate for stage IV colon or rectal cancer | Study population: | | | | | General comments: None
#29890 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network Guideline) | N = 9,011 | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | Age: 21% 65–69; 25% 70–74; 23% 75–79; 18% 80–84; 13% ≥ 85 | | | | | - Importance: 3; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 3; - Adaptability: 4; - Adequacy of risk adjustment: 2
| (a) Process | Sex: 48% male, 52% female
| (b) General | Race: 84% white, 9% black, 7% other
| Outcome to which the QM is linked: Practice patterns of patients with stage IV cancer | Comorbidities: 90% had 0; 5% had 1; 5% had 2+
| Intent of QM: Quality improvement (aim of the study was to evaluate surgical practice patterns for patients 65 years of age and older with stage IV colorectal cancer) | Geographic location: U.S.
| Definition of denominator/numerator: | Dates: 1991-1999
| Denominator: | Healthcare setting: Five states and six U.S. metropolitan areas.
| Number of Medicare-enrolled patients aged 65 and older, initially diagnosed with stage IV colon or rectal cancer in a SEER area during the years 1991-1999. Age, sex, race, ethnicity, comorbidity, year of diagnosis, and socioeconomic status were collected and data were risk-adjusted. | Results:
| Exclusion criteria: Cohort restricted to those with a histologic diagnosis consistent with adenocarcinoma. Diagnoses exclusively on death certificates or at autopsy were excluded, as were those in which the month of diagnosis was unknown. Patients enrolled in HMOs were excluded. | Only 12% of patients received palliative radiotherapy within 4 months of diagnosis (majority with rectal cancer). Patients who underwent primary cancer-directed surgery were more likely to receive radiation therapy (12% vs. 15%, p = 0.01) during their life span when compared with those in the no cancer-directed surgery group.
| Numerator:
| Number of patients who received radiotherapy within 4 months of diagnosis.
| Data sources: SEER data base, Medicare claims
| Recommended frequency of data collection: No recommendation
Wudel Jr., Chapman, Shyr, et al., 2002 | Quality measure (QM): Percentage of patients with colon or rectal cancer who had radiation therapy | Study population (university hospital = UH, city hospital = CH) | | | | | General comments:
#18640 | Basis of QM: None stated | N: 565 UH; 77 CH | | | | | Mortality was the primary endpoint of the study and the data for other potential QMs (% receiving “curative” surgery, chemo, or radiation therapy) are much weaker, poorly defined, and do not follow guidelines.
| Type of QM: | Age: Median 69 UH, 74 CH | | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | Race: 10.6% black UH; 53% black CH | | | | | - Importance: 5; - Usability: 3; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 2; - Validity: 2; - Adaptability: 4; - Adequacy of risk adjustment: 1
| (b) General | Sex: 53.3% male UH; 62.7% male CH
| Outcome to which the QM is linked: Mortality | Tumor stage:
| Intent of QM: Not specified (aim of the study was to determine the outcome of patients with colorectal cancer treated in the same city at 2 nearby medical centers, a university hospital and a city hospital, and to explore disparities in colorectal cancer outcomes between black and white patients) | UH:; I 31.7%; II 21.9%; III 23.7%; IV 22.7%
| Definition of denominator/numerator: | CH:; I 29.9%; II 20.8%; III 16.9%; IV 32.5%
| Denominator: | Performance status: NR
| Number of patients with a diagnosis of primary colorectal cancer between 1/1/90 and 12/21/99 in the tumor registry databases at each of 2 institutions (university hospital and a city hospital). Excluded patients who were non-white and non-black. | Geographic location: Nashville, TN
| Numerator: | Dates: 1/1/90 and 12/21/99 (retrospective review)
| Number of the above patients who received radiation therapy. | Healthcare setting: University hospital, city hospital
| Data sources: Hospital tumor registries | Results:
| Recommended frequency of data collection: No recommendation | There was no difference in the various treatment modalities identified - i.e., curative resection, chemotherapy, and radiation therapy - between institutions or ethnic groups.

Evidence Table 10 - Question 3 (Published Literature): What quality-of-care measures are available and what evidence is available for measures of colonoscopic surveillance for colorectal cancer?

Study | Characteristics of Quality Measure | Testing of Quality Measure | Comments/Quality Scoring
Cooper, Yuan, Chak, et al., 1999 | Quality measure (QM): Percentage of patients with non-metastatic colorectal cancer who had a followup colonoscopy | Study population: | General comments:
#27430 | Basis of QM: Clinical practice guideline (see ref 5 [ASCRS guidelines, Dis Colon Rectum 1992]) | N: 5,716 | Two papers report on same cohort and study.
and | Type of QM: | Age: Mean 74.8 ± 7.0 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
Cooper, Yuan, Chak, et al., 2000 | (a) Process | Race: 6% African-American | - Importance: 4; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 2; - Reliability: 3; - Validity: 2; - Adaptability: 2; - Adequacy of risk adjustment: 2
#35900 | (b) General | Sex: 51% F
| Outcome to which the QM is linked: No definite link to mortality - possible link to earlier detection of recurrence | Tumor stage: 50% local, 50% regional
| Intent of QM: Not specified (aim of the study was to understand geographic and patient variations among Medicare beneficiaries in the use of followup testing after surgery for non-metastatic colorectal carcinoma) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: 9 SEER regions (Atlanta, Detroit, Seattle-Puget Sound, San Francisco-Oakland, Connecticut, Hawaii, Iowa, New Mexico, Utah)
| Denominator: | Dates: Diagnosis in 1991 and followup through the end of calendar year 1994
| Number of patients with invasive colorectal cancer in a merged SEER-Medicare database which included only those patients > 64 years of age living in a SEER area (9 total) in 1991. | Healthcare setting: Non-HMO (Medicare)
| Exclusion criteria: Distant metastasis or unstaged cancer, did not undergo resection, not enrolled in Medicare part B, enrolled in an HMO, died within 6 months of diagnosis, or did not have complete data in the merged database. | Results:
| Numerator: | One or more procedures of interest (colonoscopy, sigmoidoscopy, abdominal CT, pelvic CT, barium enema, abdominal ultrasound, chest X-ray, liver enzymes, CEA) were performed in 87.5%of patients. Of these patients, 52.4% had colonoscopy and 35.3% had CEA.
| Number of the above subjects who underwent colonoscopy during the followup period. | There was a significant variation in rates of testing across the 9 SEER areas. Older patients were less likely than younger patients to undergo followup colonoscopy; there were no differences by race or sex.
| Data sources: Merged SEER and Medicare administrative (inpatient and Part B - outpatient) database
| Recommended frequency of data collection: No recommendation
Keating, Landrum, Meara, et al., 2005 | Quality measure (QM): Rate of complete colonoscopy pre- and perioperatively | Study population: | General comments: None
#36080 | Basis of QM: Clinical practice guideline (not cited, but appears to be 1990 NCI Consensus Statement) | N: 48,027 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | Age: 66–85+ | - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 3; - Validity: 5; - Adaptability: 5; - Adequacy of risk adjustment: 1
| (a) Structure | Race: 88 white
| (b) General | Sex: 46% male
| Outcome to which the QM is linked: Not stated | Tumor stage: NR
| Intent of QM: Not specified (aim of the study was to examine associations between increases in managed care market share and changes in the quality of care delivered to cancer patients in the fee-for-service sector; breast and colorectal cancer studied) | Performance status: NR
| Definition of denominator/numerator: | Other: Income, % high school graduates in census tract of residence, comorbidity score, market share of managed care
| Denominator: | Geographic location: SEER geographic regions
| Number of patients with a first diagnosis of stage III CRC in 1993-1999 in a given SEER county who had undergone surgery, were alive and enrolled in fee-for-service Medicare (parts A and B) through month 4. | Dates: 1993-1999
| Numerator: | Healthcare setting: Not stated
| Number of above patients with stage I,II III CRC in a given county who received complete pre- or perioperative colonoscopy. | Results:
| Data sources: SEER-Medicare dataset; 1990 U.S. Census | 92.5% of patients with stage II or III CRC underwent complete pre- or perioperative colonoscopy.
| Recommended frequency of data collection: No recommendation | Increased market share of managed care in a given county resulted in significant increase in the % of patients with complete colonoscopy pre- or perioperatively.
Keating, Landrum, Meara, et al., 2005 | Quality measure (QM): Rate of colonoscopy 7 to 18 months after diagnosis | Study population: | General comments: None
#36080 | Basis of QM: Clinical practice guideline (not cited) | N: 48,027 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | Age: 66–85+ | - Importance: 5; - Usability: 5; - Importance: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 3; - Validity: 5; - Adaptability: 5; - Adequacy of risk adjustment: 1
| (a) Structure | Race: 88 white
| (b) General | Sex: 46% male
| Outcome to which the QM is linked: Generally, reduced rate of recurrence | Tumor stage: NR
| Intent of QM: Not specified (aim of the study was to examine associations between increases in managed care market share and changes in the quality of care delivered to cancer patients in the fee-for-service sector; breast and colorectal cancer studied) | Performance status: NR
| Definition of denominator/numerator: | Other: Income, % high school graduates in census tract of residence, comorbidity score, market share of managed care
| Denominator: | Geographic location: SEER geographic regions
| Number of patients with a first diagnosis of stage I, II, or III CRC in 1993-1999 in a given SEER county who had undergone surgery, were alive and enrolled in fee-for-service Medicare (parts A and B) through month 4. | Dates: 1993-1999
| Numerator: | Healthcare setting: Not stated
| Number of above patients who received colonoscopy 7 to 18 months after diagnosis. | Results:
| Data sources: SEER-Medicare dataset; 1990 U.S. Census | Number of patients with stage I, II, III CRC with colonoscopy 7 to 18 months after diagnosis was 53%.
| Recommended frequency of data collection: No recommendation | Increased market share of managed care in a given county resulted in no significant change in colonoscopy during months 7 to 18 after diagnosis.
LaFata, Johnson, Ben-Menachem, et al., 2001 | Quality measure (QM): Percentage of patients with colorectal cancer who received a posttreatment colonoscopy | Study population: | General comments: None
#22140 | Basis of QM: Clinical practice guideline (ASCRS, Dis Col Rectum 1992; Desch [ASCO] 1999; NCCN, Oncology 1996; Winawer [AGA, ACG, et al.], Gastroenterology 1997) | N: 251 | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | Age: Mean 65 | - Importance: 4; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 1
| (a) Process; | Race: 157 white, 94 minority
| (b) General | Sex: 62% male
| Outcome to which the QM is linked: No definite link to mortality - possible link to earlier detection of recurrence | Tumor stage: I 28%, II 36%, III 36%
| Intent of QM: Not specified (aim of the study was to examine differences in receipt of colorectal cancer surveillance care by race and income) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: Southeast Michigan
| Denominator: | Dates: 1/1/1990-12/31/1995 for diagnosis plus 18 months of followup to 12/31/1997
| Number of patients diagnosed with colorectal cancer between 1/1/1990 and 12/31/1995 (identified in the tumor registry maintained by a large multispecialty group in Southeast Michigan) who were also enrolled in the affiliated HMO at the time of diagnosis, aged ≥ 40 at time of diagnosis, treated with curative intent (as determined by ICD-9 and CPT procedure codes for endoscopic or surgical resection). | Healthcare setting: HMO
| Exclusion criteria: Ulcerative colitis, Crohn's disease, familial polyposis or IBD (by diagnostic encounter ICD-9 codes). | Results:
| Numerator: | Whites were more likely than non-whites to receive a colon exam. The likelihood of receiving a colon exam also increased with median household income.
| Number of above patients who received a colonoscopy posttreatment (defined as 2 months to 8 years postresection with curative intent)
| Data sources: Tumor registry of a large multi-specialty practice, health plan membership files, HMO administrative and claims databases (including encounter, hospitalization, pharmacy) state vital statistics, SSA Death Index
| Recommended frequency of data collection: No recommendation
Retchin and Brown, 1990 | Quality measure (QM): Percentage of colorectal cancer patients having a surveillance colonoscopy (or sigmoidoscopy) after surgery | Study population: | General comments:
#7970 | Basis of QM: Other (physician advisory panels were selected to develop quality-of-care criteria for the outpatient detection, surgical management, and postoperative followup of colorectal cancer) | N: 119 HMO and 137 FFS patients | The data for this paper comes from prior to 1990.
| Type of QM: | Age: 72.3 years for HMO, 70.1 years for FFS | This paper has a number of potential quality measures that physician advisory panels had chosen for study, but none of them are validated and many are debatable as to whether they constitute useful determinants of quality. A list of these measures includes: questions asked during the medical history (statement of the presence of melena, statement of family history, statement of past GI diseases), physical exam (abdominal exam, digital rectal exam, fecal occult blood test), lab tests (hematocrit, chemistries, CEA, LFTs), imaging (chest X-ray, endoscopy), procedures (laparotomy), and followup (CEA, hemoccult, abdominal and lymph node exam, colonoscopy, chest X-ray). Of these, the surveillance colonoscopy seems to have the greatest face validity and so was included here.
| (a) Process | Race: 95.2% white in HMO, 86.7% white in FFS | The time from symptoms until diagnosis of colon cancer was also evaluated and found to be longer for the HMO patients.
| (b) General | Sex: 41.3% female in HMO, 50.6% female in FFS | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Outcome to which the QM is linked: None stated | Tumor stage: All | - Importance: 4; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 5; - Reliability: 5; - Validity: 4; - Adaptability: 5; - Adequacy of risk adjustment: NA
| Intent of QM: Not specified (aim of the study was to compare the quality of care received by Medicare patients with colorectal cancer in HMOs vs. fee-for-service [FFS] plans) | Performance status: NR
| Definition of denominator/numerator: | Geographic location: “4 geographic areas”
| Denominator: | Dates: January 1983-March 1986.
| Number of Medicare patients with colorectal cancer from either an HMO or FFS plan who had undergone surgery. | Healthcare setting: Hospitals/HMOs
| Numerator: | Results:
| Number of above who had a colonoscopy or sigmoidoscopy within 6 months after surgery. | 22.7% of HMO patients and 22.6% of FFS patients had a colonoscopy in the first 6 months after surgery.
| Data sources: Medicare claims files and HMO plan data
| Recommended frequency of data collection: No recommendation
Rulyak, Mandelson, Brentnall, et al., 2004 | Quality measure (QM): Percentage of patients with local or regional CRC who had colon surveillance after diagnosis | Study population: | General comments:
#31170 | Basis of QM: Clinical practice guideline (Fleischer [AGA/ASGE], JAMA 1989; Desch [ASCO], J Clin Onc 1999; NCCN 1996; Can Soc of Surg Oncol and the Can Soc of Colon and Rectal Surgeons, Can J Surg 1997; ACS/AGA, CA Cancer Journal for Clinicians 1997; Winawer, Gastroenterol 1997; Winawer, Gastroenterol 2003; ASCO, J Clin Oncol 2000) | N: 1,002 | Indication for colonoscopy could have been investigation of symptoms rather than surveillance.
| Type of QM: | Age: < 50 8.7% | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | 50–59 13.3% | - Importance: 4; - Usability: 4; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 3; - Validity: 4; - Adaptability: 3; - Adequacy of risk adjustment: 2
| (b) General | 60–69 24.4%
| Outcome to which the QM is linked: No definite link to mortality - possible link to earlier detection of recurrence | 70–79 3506%
| Intent of QM: Not specified (aim of the study was to investigate the utilization of endoscopic surveillance procedures in a population-based cohort of patients with colon or rectal cancer) | ≥ 80 18.0%
| Definition of denominator/numerator: | Race: 92.7% white, 3.5% African-American, 3.8% other
| Denominator: | Sex: 50.3% M
| Number of patients who were members of GHC and diagnosed with colon or rectal cancer 1993-1999. | Tumor stage:
| Exclusion criteria: Stage IV disease, unknown stage, not treated with resection (surgical or endoscopic), s/p total proctocolectomy, survival < 6 months, IBD. | 0 8.7%
| Numerator: | I 32.5%
| Number of the above patients who had colonoscopy or flexible sigmoidoscopy + barium enema (FSBE) after diagnosis. | II 33.8%
| Data sources: Administrative claims data from HMO, HMO pathology database, SEER database for Seattle | III 25.0%
| Recommended frequency of data collection: No recommendation | Performance status: NR
| | Geographic location: Washington state
| | Dates: Diagnosis between 1/1993-12/1999, followup at 18 months and 5 years
| | Healthcare setting: HMO
| | Results:
| | Colon exams were performed in 61% of patients within 18 months of diagnosis, and in 80% within 5 years of diagnosis. Patients over 80 years of age and those with rectal cancer were less likely to undergo surveillance. Patients of higher socioeconomic status, or who were married, were more likely to undergo colon surveillance. There was a trend toward lower utilization of colon surveillance among African-American patients.

Evidence Table 11 - Question 3 (Grey Literature): What quality-of-care measures are available and what evidence is available for measures of colonoscopic surveillance for colorectal cancer?

Study | Characteristics of Quality Measure | Comments/Quality Scoring
Institute of Medicine report, 2005 | Quality measure (QM): Followup colonoscopy after treatment for Stage I to Stage III colorectal cancer | General comments:
#36680 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Local practice patterns and patient-related factors affect the use of endoscopic procedures.
| Type of QM: | Key references cited:
| (a) Process | Cooper et al., 2000
| (b) General | Fisher et al., 2003
| Outcome to which the QM is linked: reduction in CRC mortality rate | NCCN, 2004
| Intent of QM: Quality improvement | Rulyak et al., 2004
| Definition of denominator/numerator: | Winawer et al., 2003
| Denominator: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Number of stage I to stage III colorectal cancer cases. | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Numerator:
| Number of above cases with a colonoscopy within 1 year of surgery.
| Data sources: Surveillance, Epidemiology, and End Results Program (SEER)-Medicare dataset, special studies of medical records
| Recommended frequency of data collection: No recommendation
National Committee for Quality Assurance, 2005 | Quality measure (QM): Percent of colon cancer cases (all stages) that received a followup colonoscopy within 36 months of surgical treatment | General comments: None
#36580 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| (a) Process
| (b) General
| Outcome to which the QM is linked: Improved health status
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients with colon cancer surgery in a 12-month period.
| Numerator:
| Number of above patients who received a colonoscopy exam within 36 months of surgical treatment.
| Data sources: Cancer registry, claims data
| Recommended frequency of data collection: No recommendation
National Committee for Quality Assurance, 2005 | Quality measure (QM): Percentage of rectal cancer cases (all stages) that received a postsurgical endoscopic exam within 12 months postsurgery | General comments:
#36580 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Long-term followup may not be feasible.
| Type of QM: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| (b) General
| Outcome to which the QM is linked: Improved health status
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients with rectal cancer surgery (all stages) over a 12-month period.
| Numerator:
| Number of above who received an endoscopic exam within 12 months postsurgical treatment.
| Data sources: Cancer registry, claims data
| Recommended frequency of data collection: No recommendation

Evidence Table 12 - Question 4 (Published Literature): What measures are available and what evidence is available for measures to assess the adequacy and completeness of documentation of pathology, operative, and chemotherapy reports?

Study | Characteristics of Quality Measure | Testing of Quality Measure | | | | Comments/Quality Scoring
Wei, Miller, Woosley, et al., 2004 | Quality measure (QM): Adherence to individual Association of Directors of Anatomic and Surgical Pathology (ADASP) recommended items in pathology reports | Study population: | | | | General comments:
#31910 | Basis of QM: Clinical practice guideline (Association of Directors of Anatomic and Surgical Pathology [ADASP] recommendations) | N: 438 reports | | | | Colon and rectal carcinoma data have not been separated. Labs may be utilizing other protocols for reporting. When quality is being compared it would be essential to understand if the same protocols are being used in the albs being evaluated. Alternatively, elements of the protocol could be compared instead of the entire protocol, and items that represent significant leverage points could be selected for comparisons.
| Type of QM: | 20 Community hospital labs: 264 reports | | | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| (a) Process | 5 Teaching hospital labs: 115 reports | | | | - Importance: 5; - Usability: 5; - Scientific acceptability (five criteria):; - Precise specifications: 4; - Reliability: 5; - Validity: 5; - Adaptability: 5; - Adequacy of risk adjustment: 5
| (b) Technical | 6 Contract hospital labs: 59 reports
| Outcome to which the QM is linked: | 6 Low-volume institutions: 31 reports
| Intent of QM: Quality improvement (aims of the study were to describe the completeness of pathology reporting for colon carcinoma, evaluate potential variation in reporting by laboratory type or hospital case volume, and identify areas for improvement using the recommendations of the ADASP) | 9 Medium-volume institutions 126 reports
| Definition of denominator/numerator: | 10 High-volume institutions: 222 reports
| Denominator: Number of subjects with surgically resected colon carcinoma of tumor stages T2–T4 with available surgical pathology reports | Geographic location: North Carolina
| Numerator: | Dates: 1997-2000
| (a) Number of above subjects with reports that described how specimens were received | Healthcare setting: Pathology laboratories: contract, teaching hospitals, community hospital
| (b) Number of above subjects with reports that described how specimen was identified | Results: (Global scores were not reported)
| (c) Number of above subjects with reports that described part included | Low-volume hospital labs were less likely to report some items compared with high-volume labs
| (d) Number of above subjects with reports that described tumor site | Macro-scopic description | Hospital Volume
| (e) Number of above subjects with reports that described proximity to nearest margin | | High (n = 222) | Medium (n = 126) | Low (n = 31)
| (f) Number of above subjects with reports that described macroscopic subtype | How specimen was received | 76 | 67.5 | 45.2
| (g) Number of above subjects with reports that described tumor dimensions | Specimen identified | 73.9 | 76.2 | 32.3
| (h) Number of above subjects with reports that described macroscopic depth of penetration | Part included | 100 | 100 | 100
| (i) Number of above subjects with reports that described appearance of serosa adjacent to the tumor | Tumor site | 100 | 100 | 93.6
| (j) Number of above subjects with reports that described status of residual bowel | Proximity to nearest margin | 96.4 | 91.3 | 93.6
| (k) Number of above subjects with reports that described histologic type | Macro-scopic subtype | 99.6 | 100 | 100
| (l) Number of above subjects with reports that described histologic grade | Tumor dimensions | 94.6 | 96.0 | 87.1
| (m) Number of above subjects with reports that described depth of infiltration | Macro-scopic depth of penetration | 83.8 | 89.6 | 64.5
| (n) Number of above subjects with reports that described lymph node metastases | Appearance of serosa adjacent to tumor | 53.9 | 57.9 | 51.6
| (o) Number of above subjects with reports that described involvement of margins | Appearance of residual bowel | 72.1 | 78.6 | 71.0
| Data sources: Pathology reports | Histologic information
| Frequency of data collection: No recommendation | Histologic type | 100 | 100 | 100
| | Histologic grade | 97.7 | 99.2 | 96.8
| | Depth of infiltration | 97.3 | 98.4 | 96.8
| | Lymph node metastases | 99.1 | 99.2 | 100
| | Involvement of margins | 97.3 | 93.7 | 64.5
| | Community labs were less likely to report several items compared with contract or medical school-affiliated labs.
| | Macro-scopic description | Lab Type
| | | Teach-ing(n = 115) | Contract (n = 59) | Com-munity (n = 264)
| | How specimen received | 68.7 | 54.2 | 71.5
| | Specimen identified | 83.5 | 72.9 | 65.9
| | Part included | 100 | 100 | 100
| | Tumor site | 100 | 98.3 | 99.2
| | Proximity to nearest margin | 97.4 | 88.1 | 93.2
| | Macro-scopic subtype | 100 | 96.6 | 99.6
| | Tumor dimensions | 97.4 | 91.5 | 93.2
| | Macro-scopic depth of penetration | 90.4 | 66.1 | 81.4
| | Appearance of serosa adjacent to tumor | 57.4 | 39.0 | 48.5
| | Appearance of residual bowel | 76.5 | 67.8 | 73.1
| | Histologic information
| | Histologic type | 100 | 100 | 100
| | Histologic grade | 98.3 | 96.6 | 98.1
| | Depth of infiltration | 99.1 | 100 | 97.0
| | Lymph node metastases | 100 | 100 | 98.9
| | Involvement of margins | 95.7 | 96.6 | 92.4

Evidence Table 13 - Question 4 (Grey Literature): What measures are available and what evidence is available for measures to assess the adequacy and completeness of documentation of pathology, operative, and chemotherapy reports?

Study | Characteristics of Quality Measure | Comments/Quality Scoring
Colon Cancer Workgroup, 2003 | Quality measure (QM): Pathology reporting of the surgical specimen is concordant with the guidelines of the College of American Pathologists (CAP), including reporting of number of nodes resected, number of nodes positive, tumor characteristics (grade, depth of invasion), mucosal and radial margins | General comments: None
#36650 | Basis of QM: Clinical practice guideline (National Comprehensive Cancer Network [NCCN] guidelines) | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Type of QM: | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| (a) Process
| (b) Technical
| Outcome to which the QM is linked: Pathology staging (and subsequent treatment planning and survival)
| Intent of QM: Quality improvement
| Definition of denominator/numerator:
| Denominator:
| Number of patients having colon cancer surgery.
| Numerator:
| Number of above patients with pathology reports in concordance with CAP guidelines.
| Data sources: Pathology, surgical reports
| Recommended frequency of data collection: No recommendation
Institute of Medicine, 2005 | Quality measure (QM): Pathology reports on colorectal cancer surgical specimens that include College of American Pathologists (CAP) data elements as required by the American College of Surgeons' Commission on Cancer | General comments:
#36680 | Basis of QM: Clinical practice guideline (CAP, Commission on Cancer) | Measurement goal should be 100 percent. Findings should be reported in the aggregate and individually by pathology laboratory.
| Type of QM: | Key references cited:
| (a) Structure | Compton (CAP), 2004
| (b) General | Commission on Cancer, 2003
| Outcome to which the QM is linked: Pathology staging (and subsequent treatment planning and survival) | Compton, 2003
| Intent of QM: Quality improvement | Stocchi et al., 2001
| Definition of denominator/numerator: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Denominator: | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Number of pathology reports on colorectal cancer surgical specimens.
| Numerator:
| Number of above reports that include CAP data elements as required by the Commission on Cancer.
| Data sources: CAP, Commission on Cancer, baseline special studies
| Recommended frequency of data collection: No recommendation
Institute of Medicine, 2005 | Quality measure (QM): Colorectal cancer cases in which pathologic staging preceded chemotherapy and radiation treatment | General comments: None
#36680 | Basis of QM: Clinical practice guideline (American College of Radiology, American Society of Clinical Oncology, Commission on Cancer, National Comprehensive Cancer Network) | Key references cited:
| Type of QM: | Compton (CAP), 2004
| (a) Process | NCCN, 2004
| (b) General | American College of Radiology, 1999
| Outcome to which the QM is linked: | Commission on Cancer, 2003
| Intent of QM: Quality improvement | Greene et al., 2002
| Definition of denominator/numerator: | Rating of quality measure as presented (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Denominator: | - Importance: 5; - Usability: 5; - Scientific acceptability (two criteria):; - Precise specifications: 4; - Adaptability: 4
| Number of new colorectal cancer cases with chemotherapy or radiation treatment.
| Numerator:
| Number of above cases with medical chart documentation of pathologic stage before chemotherapy or radiation is initiated.
| Data sources: Medical records
| Recommended frequency of data collection: No recommendation

## References Cited in the Evidence Tables

Agarwal N, Leighton L, Mandile MA, et al. Outcomes of surgery for colorectal cancer in patients age 80 years and older. Am J Gastroenterol. 1990;85(9):1096-101. [pmid: 2389721].
Ayanian JZ, Zaslavsky AM, Fuchs CS, et al. Use of adjuvant chemotherapy and radiation therapy for colorectal cancer in a population-based cohort. J Clin Oncol. 2003;21(7):1293-300. [pmid: 12663717].
Baig N, Myers RE, Turner BJ, et al. Physician-reported reasons for limited follow-up of patients with a positive fecal occult blood test screening result. Am J Gastroenterol. 2003;98(9):2078-81. [pmid: 14499791].
Baxter N, Virnig D, Rothenberger D, et al. Lymph Node Evaluation in Colorectal Cancer Patients: A Population Based Study. J Natl Cancer Inst. 2005;97(3):219-25. [pmid: 15687365].
Baxter NN, Rothenberger DA, Morris AM, et al. Adjuvant radiation for rectal cancer: do we measure up to the standard of care? An epidemiologic analysis of trends over 25 years in the United States. Dis Colon Rectum. 2005;48(1):9-15. [pmid: 15690651].
Beart RW, Steele GD Jr, Menck HR, et al. Management and survival of patients with adenocarcinoma of the colon and rectum: a national survey of the Commission on Cancer. J Am Coll Surg. 1995;181(3):225-36. [pmid: 7670682].
Chiaverini L, Fulton JP, Darcy DM. Progress in the control of colorectal cancer in Rhode Island, 1987-2000. Med Health R I. 2002;85(7):226-8. [pmid: 12182097].
Coburn MC, Pricolo VE, Soderberg CH. Factors affecting prognosis and management of carcinoma of the colon and rectum in patients more than eighty years of age. J Am Coll Surg. 1994;179(1):65-9. [pmid: 8019727].
Coia L, Wizenberg M, Hanlon A, et al. Evaluation and treatment of patients receiving radiation for cancer of the rectum or sigmoid colon in the United States: results of the 1988-1989 Patterns of Care Study process survey. J Clin Oncol. 1994;12(5):954-9. [pmid: 8164047].
Colon Cancer Workgroup. Quality of Cancer Care Evaluation and Improvement: Commission on Cancer, American College of Surgeons, American Cancer Society and Tenet Health Care System, December, 2003. Electronically received February 7, 2005.
Cooper GS, Yuan Z, Chak A, et al. Geographic and patient variation among Medicare beneficiaries in the use of follow-up testing after surgery for nonmetastatic colorectal carcinoma. Cancer. 1999;85(10):2124-31. [pmid: 10326689].
Cooper GS, Yuan Z, Chak A, et al. Patterns of endoscopic follow-up after surgery for nonmetastatic colorectal cancer. Gastrointest Endosc. 2000;52(1):33-8. [pmid: 10882959].
Cooper GS, Yuan Z, Landefeld CS, et al. Surgery for colorectal cancer: Race-related differences in rates and survival among Medicare beneficiaries. Am J Public Health. 1996;86(4):582-6. [pmid: 8604797]. [pmcid: 1380567].
Demissie K, Oluwole OO, Balasubramanian BA, et al. Racial differences in the treatment of colorectal cancer: a comparison of surgical and radiation therapy between Whites and Blacks. Ann Epidemiol. 2004;14(3):215-21. [pmid: 15036226].
Dimick JB, Cowan JA Jr, Upchurch GR Jr, et al. Hospital volume and surgical outcomes for elderly patients with colorectal cancer in the United States. J Surg Res. 2003;114(1):50-6. [pmid: 13678698].
Dominitz JA, Samsa GP, Landsman P, et al. Race, treatment, and survival among colorectal carcinoma patients in an equal-access medical system. Cancer. 1998;82(12):2312-20. [pmid: 9635522].
Galvis CO, Raab SS, D'Amico F, et al. Pathologists' assistants practice: a measurement of performance. Am J Clin Pathol. 2001;116(6):816-22. [pmid: 11764069].
Govindarajan R, Shah RV, Erkman LG, et al. Racial differences in the outcome of patients with colorectal carcinoma. Cancer. 2003;97(2):493-8. [pmid: 12518374].
Harewood GC, Sharma VK, de Garmo P. Impact of colonoscopy preparation quality on detection of suspected colonic neoplasia. Gastrointest Endosc. 2003;58(1):76-9. [pmid: 12838225].
Harmon J, Tang D, Gordon T, et al. Hospital Volume Can Serve as a Surrogate for Surgeon Volume for Achieving Excellent Outcomes in Colorectal Resection. Ann Surg. 1999;230(3):404-13. [pmid: 10493487]. [pmcid: 1420885].
Haseman JH, Lemmel GT, Rahmani EY, et al. Failure of colonoscopy to detect colorectal cancer: evaluation of 47 cases in 20 hospitals. Gastrointest Endosc. 1997;45(6):451-5. [pmid: 9199899].
Hodgson DC, Zhang W, Zaslavsky AM, et al. Relation of hospital volume to colostomy rates and survival for patients with rectal cancer. J Natl Cancer Inst. 2003;95(10):708-16. [pmid: 12759388].
Hyman N, Labow SB. Vermont Chapter of the American College of Surgeons. The Vermont colorectal cancer project: self-portrait. Arch Surg. 2002;137(4):413-6. [pmid: 11926944].
Institute of Medicine. Asessing the Quality of Cancer Care: An Approach to Measurement in Georgia. Committee on Assessing Improvements in Cancer Care in Georgia. National Cancer Policy Board. The National Academies Press: Washington, DC; 2005.
Jessup JM, McGinnis LS, Steele GD Jr, et al. The National Cancer Data Base. Report on colon cancer. Cancer. 1996;78(4):918-26. [pmid: 8756390].
Keating N, Landrum M, Meara E, et al. Do Increases in the Market Share of Managed Care Influence Quality of Care in the Fee-For-Service Sector?. J Natl Cancer Inst. 2005;97(4):257-64. [pmid: 15713960].
Kline RW, Smith AR, Coia LR, et al. Treatment planning for adenocarcinoma of the rectum and sigmoid: a patterns of care study. PCS Committee. Int J Radiat Oncol Biol Phys. 1997;37(2):305-11. [pmid: 9069301].
Ko CY, Chang JT, Chaudhry S, et al. Are high-volume surgeons and hospitals the most important predictors of in-hospital outcome for colon cancer resection?. Surgery. 2002;132(2):268-73. [pmid: 12219022].
LaFata EJ, Johnson C, Ben-Menachem T, et al. Sociodemographic differences in the receipt of colorectal cancer surveillance care following treatment with curative intent. Med Care. 2001;39(4):361-72. [pmid: 11329523].
Levin B, Hess K, Johnson C. Screening for colorectal cancer. A comparison of 3 fecal occult blood tests. Arch Intern Med. 1997;157(9):970-6. [pmid: 9140267].
Mahoney T, Kuo YH, Topilow A, et al. Stage III colon cancers: why adjuvant chemotherapy is not offered to elderly patients. Arch Surg. 2000;135(2):182-5. [pmid: 10668878].
Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343(22):1603-7. [pmid: 11096167].
Marble K, Banerjee S, Greenwald L. Colorectal carcinoma in young patients. J Surg Oncol. 1992;51(3):179-82. [pmid: 1434643].
Merrill RM, Brown ML, Potosky AL, et al. Survival and treatment for colorectal cancer Medicare patients in two group/staff health maintenance organizations and the fee-for-service setting. Med Care Res Rev. 1999;56(2):177-96. [pmid: 10373723].
Minnesota Gastroenterology PA. 2004 Colonoscopy Quality Assurance Initiative. Electronically received: January 26, 2005.
Minsky BD, Coia L, Haller DG, et al. Radiation therapy for rectosigmoid and rectal cancer: results of the 1992-1994 Patterns of Care process survey. J Clin Oncol. 1998;16(7):2542-7. [pmid: 9667276].
Morris AM, Billingsley KG, Baxter NN, et al. Racial disparities in rectal cancer treatment: a population-based analysis. Arch Surg. 2004;139(2):151-5. discussion 156. [pmid: 14769572].
Myers RE, Turner B, Weinberg D, et al. Impact of a physician-oriented intervention on follow-up in colorectal cancer screening. Prev Med. 2004;38(4):375-81. [pmid: 15020170].
National Committee for Quality Assurance (NCQA). Final List of Colon Cancer Measures Based on Domain Expert Review. Measures developed by Kaiser Permanente, Internountain Health Care and NCQA. Electronically delivered February 8, 2005.
National Quality Measures Clearinghouse (NQMC). Intra-procedure colonosopy complication rate: percentage of patients who developed one or more intrao-procedure complications. Available at: http://www.qualitymeasures.ahrq.gov/summary/summary.aspx?doc_id=4868. Accessed: March 21, 2005.
Nelson DB, McQuaid KR, Bond JH, et al. Procedural success and complications of large-scale screening colonoscopy. Gastrointest Endosc. 2002;55(3):307-14. [pmid: 11868001].
Neugut AI, Fleischauer AT, Sundararajan V, et al. Use of adjuvant chemotherapy and radiation therapy for rectal cancer among the elderly: a population-based study. J Clin Oncol. 2002;20(11):2643-50. [pmid: 12039925].
Newcomb PA, Carbone PP. Cancer treatment and age: patient perspectives. J Natl Cancer Inst. 1993;85(19):1580-4. [pmid: 8411231].
O'Connell JB, Maggard MA, Liu JH, et al. Are survival rates different for young and older patients with rectal cancer?. Dis Colon Rectum. 2004;47(12):2064-9. [pmid: 15657655].
O'Connell JB, Maggard MA, Liu JH, et al. Do young colon cancer patients have worse outcomes?. World J Surg. 2004;28(6):558-62. [pmid: 15366745].
Oliveria SA, Yood MU, Campbell UB, et al. Treatment and referral patterns for colorectal cancer. Med Care. 2004;42(9):901-6. [pmid: 15319616].
Potosky AL, Harlan LC, Kaplan RS, et al. Age, sex, and racial differences in the use of standard adjuvant therapy for colorectal cancer. J Clin Oncol. 2002;20(5):1192-202. [pmid: 11870160].
Purves H, Pietrobon R, Hervey S, et al. Relationship between surgeon caseload and sphincter preservation in patients with rectal cancer. Dis Colon Rectum. 2005;48(2):195-202. discussion 202–4. [pmid: 15812583].
Rabeneck L, Davila JA, Thompson M, et al. Outcomes in elderly patients following surgery for colorectal cancer in the veterans affairs health care system. Aliment Pharmacol Ther. 2004;20(10):1115-24. [pmid: 15569114].
Read TE, Myerson RJ, Fleshman JW, et al. Surgeon specialty is associated with outcome in rectal cancer treatment. Dis Colon Rectum. 2002;45(7):904-14. [pmid: 12130879].
Retchin SM, Brown B. Management of colorectal cancer in Medicare health maintenance organizations. J Gen Intern Med. 1990;5(2):110-4. [pmid: 2179490].
Roetzheim RG, Pal N, Gonzalez EC, et al. Effects of health insurance and race on colorectal cancer treatments and outcomes. Am J Public Health. 2000;90(11):1746-54. [pmid: 11076244]. [pmcid: 1446414].
Rogers SO, Ray WA, Smalley WE. A population-based study of survival among elderly persons diagnosed with colorectal cancer: does race matter if all are insured? (United States). Cancer Causes Control. 2004;15(2):193-9. [pmid: 15017132].
Rulyak SJ, Mandelson MT, Brentnall TA, et al. Clinical and sociodemographic factors associated with colon surveillance among patients with a history of colorectal cancer. Gastrointest Endosc. 2004;59(2):239-47. [pmid: 14745398].
Schrag D, Cramer LD, Bach PB, et al. Age and adjuvant chemotherapy use after surgery for stage III colon cancer. J Natl Cancer Inst. 2001;93(11):850-7. [pmid: 11390534].
Schrag D, Cramer LD, Bach PB, et al. Influence of hospital procedure volume on outcomes following surgery for colon cancer. JAMA. 2000;284(23):3028-35. [pmid: 11122590].
Schrag D, Gelfand SE, Bach PB, et al. Who gets adjuvant treatment for stage II and III rectal cancer? Insight from surveillance, epidemiology, and end results--Medicare. J Clin Oncol. 2001;19(17):3712-8. [pmid: 11533092].
Schrag D, Panageas KS, Riedel E, et al. Hospital and surgeon procedure volume as predictors of outcome following rectal cancer resection. Ann Surg. 2002;236(5):583-92. [pmid: 12409664]. [pmcid: 1422616].
Schrag D, Panageas KS, Riedel E, et al. Surgeon volume compared to hospital volume as a predictor of outcome following primary colon cancer resection. J Surg Oncol. 2003;83(2):68-78. discussion 78–9. [pmid: 12772198].
Shehadeh I, Rebala S, Kumar R, et al. Retrospective analysis of missed advanced adenomas on surveillance colonoscopy. Am J Gastroenterol. 2002;97(5):1143-7. [pmid: 12014718].
Shields HM, Weiner MS, Henry DR, et al. Factors that influence the decision to do an adequate evaluation of a patient with a positive stool for occult blood. Am J Gastroenterol. 2001;96(1):196-203. [pmid: 11197252].
Simons AJ, Ker R, Groshen S, et al. Variations in treatment of rectal cancer: the influence of hospital type and caseload. Dis Colon Rectum. 1997;40(6):641-6. [pmid: 9194456].
Steele GD Jr. The National Cancer Data Base report on colorectal cancer. Cancer. 1994;74(7):1979-89. [pmid: 8082105].
Steele G. National Cancer Database: Annual review of patient care, 1994. Atlanta, Ga. American Cancer Society. 1994;24–42.
Steele G, Jessup J. National Cancer Database: Annual review of patient care, 1995. Atlanta, Ga. American Cancer Society. 1995;66ndash;83.
Sundararajan V, Grann VR, Jacobson JS, et al. Variations in the use of adjuvant chemotherapy for node-positive colon cancer in the elderly: a population-based study. Cancer J. 2001;7(3):213-8. [pmid: 11419029].
Temple LK, Hsieh L, Wong WD, et al. Use of surgery among elderly patients with stage IV colorectal cancer. J Clin Oncol. 2004;22(17):3475-84. [pmid: 15337795].
Tropman S, Hatzell T, Paskett E, et al. Colon cancer treatment in rural North and South Carolina. Cancer Detect Prev. 1999;23(5):428-34. [pmid: 10468896].
Ure T, Dehghan K, Vernava AM 3rd,, et al. Colonoscopy in the elderly. Low risk, high yield. Surg Endosc. 1995;9(5):505-8. [pmid: 7676371].
Vernon SW, Hughes JI, Heckel VM, et al. Quality of care for colorectal cancer in a fee-for-service and health maintenance organization practice.[erratum appears in Cancer 1994 Dec 15;74(12):3249]. Cancer 1992;69(10):2418–25.
Weaver P, Harrison B, Eskander G, et al. Colon cancer in blacks: a disease with a worsening prognosis. J Natl Med Assoc. 1991;83(2):133-6. [pmid: 2005649]. [pmcid: 2627026].
Wei JT, Miller EA, Woosley JT, et al. Quality of colon carcinoma pathology reporting: a process of care study. Cancer. 2004;100(6):1262-7. [pmid: 15022295].
Whittle J, Steinberg EP, Anderson GF, et al. Results of colectomy in elderly patients with colon cancer, based on Medicare claims data. Am J Surg. 1992;163(6):572-6. [pmid: 1308654].
Wudel LJ Jr, Chapman WC, Shyr Y, et al. Disparate outcomes in patients with colorectal cancer: effect of race on long-term survival. Arch Surg. 2002;137(5):550-4. discussion 554–6. [pmid: 11982467].