# Appendix D: Sample Data Abstraction Forms^*^

Blank Data Abstraction Form/ET for CRC Care Quality Evidence Report (to be used for published quality measures only)

General instructions:

1) If an article includes more than one quality measure, please complete a separate evidence table entry (row) for each measure.
2) If an article includes a quality measure having to do with the quality of a data source, please note this under “General comments” in the Comments column, but do not abstract the data pertaining to this measure (we will do that separately).
3) If an article reports on long-term survival/mortality as a quality measure, please note this under “General comments” in the Comments column, but do not abstract the data pertaining to this measure (we will do that separately). Please do abstract data on short-term post-surgical mortality.

Study | Characteristics of Quality Measure | Testing of Quality Measure | Comments/Quality Scoring
First author, date, Pro-Cite# | Quality measure (QM): [include formal name of measure, if any, or give description (“the percentage of ...”)] | Study population: | If article should be EXCLUDED, please indicate why: [delete as appropriate]
| Basis of QM: [delete all but one] | N: | Non-US data
| Clinical practice guideline | Age: | Review article
| Other (please specify): | Race: | Wrong study population: [delete as appropriate]
| None | Sex: | Screening of asymptomatic individuals
| If basis was clinical practice guideline or “other,” was this named/cited in the article? Yes/No | Tumor stage: | Familial polyposis syndrome
| If yes, please specify here: | Performance status: | Ulcerative colitis
| If no, do you think you know what it was?: | Other: | Colorectal CA with hereditary nonpolyposis
| Yes (please specify): | Geographic location: | Multiple metastases (majority not colorectal CA)
| No | Dates: | Other (please specify):
| Type of QM: [delete all but one in each line] | Healthcare setting: | No explicit QM with positive colorectal CA diagnosis
| (a) Structure/Process/Outcome | Is this a formal validation study?: Yes/No | No data source testing of validity/reliability
| (b) General/Technical | If no, does it cite a formal validation study?: Yes (give citation #)/No | Other (falls outside scope of Task Order)
| For structure and process measures, please indicate the Outcome to which the QM is linked: | Results: | General comments:
| Intent of QM: [delete as appropriate] | | Rating of quality measure as presented in this study (scale of 1–5, where 1 = poor, 3 = moderate, 5 = ideal):
| Quality improvement | | - Importance:; - Usability:; - Scientific acceptability (five criteria):; - Precise specifications:; - Reliability:; - Validity:; - Adaptability:; - Adequacy of risk adjustment:
| Accountability | | This QM is relevant to: [please delete as appropriate]
| Research | | Question 1a (imaging, visualization, biopsy)
| Other (please specify): | | Question 1b (pathologic staging)
| Not specified: | | Question 2a (polypectomy, eval surgical margins)
| Definition of denominator/numerator: | | Question 2b (surgical therapy)
| Denominator: | | Question 2c (adj chemo and metastatic CRC)
| Numerator: | | Question 2d (radiation therapy)
| Data sources: | | Question 3 (colonoscopic surveillance)
| Recommended frequency of data collection: | | Question 4 (documentation of reporting)
| | | Question 5a (patient populations and purposes)
| | | Question 5b (demographic differences)

* The data abstraction form reproduced here was used for published quality measures. The form used for unpublished measures was identical to the above, except that it omitted the center column, on “Testing of Quality Measure.”