# Appendix C: List of Excluded Studies

All excluded studies list below were reviewed in their full-text version. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## References

Aaltonen LA, Sankila R, Mecklin JP, et al. A novel approach to estimate the proportion of hereditary nonpolyposis colorectal cancer of total colorectal cancer burden. Cancer Detect Prev. 1994;18(1):57-63. Exclude non-U.S. data. [pmid: 8162607].
Abel U, Wollermann C. Methodological aspects of the evaluation of postoperative cancer surveillance. Part II: Efficacy. Clin Lab. 2003;49(78):379-98. Exclude non-U.S. data. [pmid: 12908737].
Abulafi AM, Williams NS. Local recurrence of colorectal cancer: the problem, mechanisms, management and adjuvant therapy. Br J Surg. 1994;81(1):7-19. Exclude review. [pmid: 8313126].
Achkar E. Colorectal cancer screening in primary care: the long and short of it. Am J Gastroenterol. 2004;99(5):837-8. Exclude falls outside Task Order scope. [pmid: 15128346].
Adair A, Bennis M, Clifton MA. Referral guidelines for colorectal cancer--do they work. Ann R Coll Surg Engl. 2004;86(2):144. Exclude non-U.S. data.
Adam IJ, Mohamdee MO. Role of Circumferential Margin Involvement in the Local Recurrence of Rectal Cancer. Lancet 1994;344(8924). Exclude non-U.S. data.
Adams J, White M, Barker G, et al. Are there socio-economic inequalities in age of resection of colorectal cancer in people with HNPCC. Fam Cancer. 2003;2(34):169-73. Exclude non-U.S. data. [pmid: 14707528].
Adams T, Dufton R, Lamb C, et al. Hospital secondments of community nurses to improve stoma care. Br J Community Nurs. 2003;8(12):539-43. Exclude non-U.S. data. [pmid: 14688659].
Adler GS, Shatto A. Screening for osteoporosis and colon cancer under Medicare. Health Care Financ Rev. 2002;23(4):189-200. Exclude falls outside Task Order scope. [pmid: 12500479].
Afridi SA, Jafri SF, Marshall JB. Do gastroenterologists themselves follow the American Cancer Society recommendations for colorectal cancer screening?. Am J Gastroenterol. 1994;89(12):2184-7. Exclude falls outside Task Order scope. [pmid: 7977238].
Agrez MV, Coory M, Cockburn J. Population screening for colorectal carcinoma with fecal-occult blood testing: are we sufficiently informed. Cancer. 1998;82(10):1803-7. Exclude falls outside Task Order scope. [pmid: 9587111].
Ahlquist DA. Fecal occult blood testing for colorectal cancer. Can we afford to do this. Gastroenterol Clin North Am. 1997;26(1):41-55. Exclude review. [pmid: 9119439].
Ahlquist DA, Shuber AP. Stool screening for colorectal cancer: evolution from occult blood to molecular markers. Clin Chim Acta. 2002;315(12):157-68. Exclude falls outside Task Order scope. [pmid: 11728417].
Ahmad NA, Hoops TC. The role of colonoscopy for screening of colorectal cancer. Semin Roentgenol. 2000;35(4):404-8. Exclude review. [pmid: 11060926].
Ahnen DJ, Lynch KL. Colorectal cancer screening in average - and high-risk groups. Adv Intern Med. 2001;46:77-106. . Exclude review. [pmid: 11147261].
Aihara H, Kawamura YJ, Konishi F. Reduced medical costs achieved after elective oncological colorectal surgery by early feeding and fewer scheduled examinations. J Gastroenterol. 2003;38(8):747-50. Exclude non-U.S. data. [pmid: 14505128].
Akerley WL 3rd, Moritz TE, Ryan LS, et al. Racial comparison of outcomes of male Department of Veterans Affairs patients with lung and colon cancer. Arch Intern Med. 1993;153(14):1681-8. Exclude no explicit QM. [pmid: 8333805].
Alexander D, Chatla C, Funkhouser E, et al. Postsurgical disparity in survival between African Americans and Caucasians with colonic adenocarcinoma. Cancer. 2004;101(1):66-76. Exclude survival only. [pmid: 15221990].
Alexander D, Jhala N, Chatla C, et al. High-grade tumor differentiation is an indicator of poor prognosis in African Americans with colonic adenocarcinomas. Cancer. 2005;103(10):2163-70. Exclude review. [pmid: 15816050].
Alici S, Aykan NF, Sakar B, et al. Colorectal cancer in young patients: characteristics and outcome. Tohoku J Exp Med. 2003;199(2):85-93. Exclude non-U.S. data. [pmid: 12705353].
Allal AS, Mermillod B, Roth AD, et al. The impact of treatment factors on local control in T2-T3 anal carcinomas treated by radiotherapy with or without chemotherapy. Cancer. 1997;79(12):2329-35. Exclude no explicit QM. [pmid: 9191520].
Allenmersh TG, Earlam S. Quality of Life and Survival with Continuous Heaptic-Artery Floxuridine Infusion for Colorectal Liver Metastases. Lancet 1994;344(8932). Exclude no explicit QM.
American Society of Clinical Oncology. Outcomes of cancer treatment for technology assessment and cancer treatment guidelines: outcomes for technology assessments and guideline development. Available at: http:www.asco.org/ac/. Accessed: April 6, 2005. 1995. Exclude review.
Andreoni B, Biffi R, Torri V. Follow-up in colorectal cancer. Tumori. 1997;83(1 Suppl):S19-20. Exclude non-U.S. data. [pmid: 9154062].
Ang YS, Macaleenan N, Mahmud N, et al. The yield of colonoscopy in average-risk patients with non-specific colonic symptoms. Eur J Gastroenterol Hepatol. 2002;14(10):1073-7. Exclude non-U.S. data. [pmid: 12362097].
Angelo N, Dreyer L. Colorectal carcinoma--a new threat to black patients? A retrospective analysis of colorectal carcinoma received by the Institute for Pathology, University of Pretoria. S Afr Med J. 2001;91(8):689-93. Exclude non-U.S. data. [pmid: 11584786].
Anonymous. Recommendations for the reporting of resected large intestinal carcinomas. Association of Directors of Anatomic and Surgical Pathology. Mod Pathol 1996;9(1):73–6. Exclude review.
Anonymous. Screening for colorectal cancer--United States, 1992-1993, and new guidelines. MMWR Morb Mortal Wkly Rep 1996;45(5):107–10. Exclude falls outside Task Order scope.
Anonymous. AHCPR releases evidence report on colorectal cancer screening. Oncology (Huntingt). 1997;11(3):342–4. Exclude review.
Anonymous. Clinical pathways for general surgeons: elective colectomy for cancer. Am Surg 1998;64(5):481–4. Exclude no explicit QM.
Anonymous. Colonoscopy in the screening and surveillance of individuals at increased risk for colorectal cancer. American Society for Gastrointestinal Endoscopy. Gastrointest Endosc 1998;48(6):676–8. Exclude review.
Anonymous. Guidelines for colorectal cancer screening and surveillance. Gastrointest Endosc 2000;51(6):777–82. Exclude review.
Anonymous. Surgery for colorectal cancer in elderly patients: a systematic review. Colorectal Cancer Collaborative Group. Lancet 2000;356(9234):968–74. Exclude review.
Anonymous. Colonoscopy benchmarks suggest less invasive tack not always most productive. Data Strateg Benchmarks 2001;5(8):116–9, 113. Exclude review.
Anonymous. Summaries for patients. Choice of statistical analysis can change the results of studies of the relationship between hospital and surgeon volume and outcomes of cancer surgery. Ann Intern Med 2003;139(8):I44. Exclude no explicit QM.
Anonymous. Summaries for patients. Relationships between the amount of colon cancer surgery a hospital performs and patient outcomes. Ann Intern Med 2003;139(8):I28. Exclude no explicit QM.
Anonymous. Summaries for patients. Using risks to tailor screening for colorectal cancer. Ann Intern Med 2003;139(12):I10. Exclude non-U.S. data.
Anonymous. Summaries for patients. What is the best way to test for colorectal cancer? [original report in Ann Intern Med. 2005 Jan 18;142(2):81–5; PMID: 15657155]. Ann Intern Med 2005;142(2):I23. Exclude wrong population
Anthony T, Fleming JB, Bieligk SC, et al. Postoperative colorectal cancer surveillance. J Am Coll Surg. 2000;190(6):737-49. Exclude review. [pmid: 10873011].
Anthony T, Jones C, Antoine J, et al. The effect of treatment for colorectal cancer on long-term health-related quality of life. Ann Surg Oncol. 2001;8(1):44-9. Exclude review. [pmid: 11206224].
Anthony T, Simmang C, Hyman N, et al. Practice parameters for the surveillance and follow-up of patients with colon and rectal cancer. Dis Colon Rectum. 2004;47(6):807-17. Exclude review. [pmid: 15108028].
Aparicio T, Desrame J, Lecomte T, et al. Oxaliplatin- or irinotecan-based chemotherapy for metastatic colorectal cancer in the elderly. Br J Cancer. 2003;89(8):1439-44. Exclude non-U.S. data. [pmid: 14562014].
Apolone G, Cavuto S, Torri V, et al. Effectiveness of adjuvant fluorouracil in elderly colon cancer patients: the internal and external validity of nonrandomized research design. J Clin Oncol. 2003;21(9):1892. author reply 1893. Exclude non-U.S. data. [pmid: 12721271].
Apolone G, Filiberti A, Cifani S, et al. Evaluation of the EORTC QLQ-C30 questionnaire: a comparison with SF-36 Health Survey in a cohort of Italian long-survival cancer patients. Ann Oncol. 1998;9(5):549-57. Exclude non-U.S. data. [pmid: 9653497].
Apse KA, Biesecker BB, Giardiello FM, et al. Perceptions of genetic discrimination among at-risk relatives of colorectal cancer patients. Genet Med. 2004;6(6):510-6. Exclude falls outside Task Order scope. [pmid: 15545747].
Archer SB, Burnett RJ, Flesch LV, et al. Implementation of a clinical pathway decreases length of stay and hospital charges for patients undergoing total colectomy and ileal pouch/anal anastomosis. Surgery. 1997;122(4):699-703. discussion 703–5. Exclude falls outside Task Order scope. [pmid: 9347845].
Arenal JJ, Benito C, Concejo MP, et al. Colorectal resection and primary anastomosis in patients aged 70 and older: prospective study. Eur J Surg. 1999;165(6):593-7. Exclude non-U.S. data. [pmid: 10433146].
Armbrecht U, Manus B, Bragelmann R, et al. Acceptance and outcome of endoscopic screening for colonic neoplasia in patients undergoing clinical rehabilitation for gastrointestinal and metabolic diseases. NZ Gastroenterol. 1994;32(1):3-7. Exclude non-U.S. data.
Arnaud JP, Schloegel M, Ollier JC, et al. Colorectal cancer in patients over 80 years of age. Dis Colon Rectum. 1991;34(10):896-8. . Exclude non-U.S. data. [pmid: 1717209].
Arndt V, Merx H, Stegmaier C, et al. Quality of life in patients with colorectal cancer 1 year after diagnosis compared with the general population: a population-based study. [erratum appears in J Clin Oncol 2005 Jan 1;23(1):248]. J Clin Oncol. 2004;22(23):4829-36. Exclude non-U.S. data. [pmid: 15570086].
Arora A, Singh P. Colonoscopy in patients 80 years of age and older is safe, with high success rate and diagnostic yield. Gastrointest Endosc. 2004;60(3):408-13. Exclude non-U.S. data. [pmid: 15332032].
Ashley OS, Nadel M, Ransohoff DF. Achieving quality in flexible sigmoidoscopy screening for colorectal cancer. Am J Med. 2001;111(8):643-53. Exclude review. [pmid: 11755508].
Atkin W, Rogers P, Cardwell C, et al. Wide variation in adenoma detection rates at screening flexible sigmoidoscopy. Gastroenterology. 2004;126(5):1247-56. Exclude non-U.S. data. [pmid: 15131784].
Audisio RA, Filiberti A, Geraghty JG, et al. Personalized surgery for rectal tumours: the patient's opinion counts. Support Care Cancer. 1997;5(1):17-21. Exclude no explicit QM. [pmid: 9010985].
Audisio RA, Robertson C. Colorectal cancer follow-up: perspectives for future studies. Eur J Surg Oncol. 2000;26(4):329-37. Exclude review. [pmid: 10873351].
Austin D, Russell EM. Is there ageism in oncology. Scott Med J. 2003;48(1):17-20. Exclude non-U.S. data. [pmid: 12669497].
Ayanian JZ, Zaslavsky AM, Guadagnoli E, et al. Patient perceptions of quality of care for colorectal cancer by race, ethnicity, and language. Jl Clin Oncol 2005;23(27):TBD. Exclude QOL.
Baier M, Calonge N, Cutter G, et al. Validity of self-reported colorectal cancer screening behavior. Cancer Epidemiol Biomarkers Prev. 2000;9(2):229-32. Exclude falls outside Task Order scope. [pmid: 10698488].
Baig MK, Marks CG. Referral guidelines for colorectal cancer: a threat or a challenge. Hosp Med. 2000;61(7):452-3. Exclude review. [pmid: 11091797].
Bailes J. Final report of the national initiative on cancer care quality. American Society of Clinical Oncology. Slide presentation. Available at: http://www.asco.org/ac/. Accessed: April 6, 2005. 2004. Exclude review.
Bailey C, Corner J, Addington-Hall J, et al. Older patients' experiences of treatment for colorectal cancer: an analysis of functional status and service use. Eur J Cancer Care (Engl). 2004;13(5):483-93. Exclude non-U.S. data. [pmid: 15606716].
Bailey C, Corner J, Addington-Hall J, et al. Treatment decisions in older patients with colorectal cancer: the role of age and multidimensional function. Eur J Cancer Care (Engl). 2003;12(3):257-62. Exclude non-U.S. data.
Baker D. Current surgical management of colorectal cancer. Nurs Clin North Am 2001;36(3):579–92, xi–xii. Exclude review.
Balducci L. Believing is seeing: a new parameter to study cancer prevention and cancer treatment in older individuals. Cancer. 2004;(1005):881-2. Exclude no explicit QM.
Balducci L, Mowry K. Pharmacology and organ toxicity of chemotherapy in older patients. Oncology (Huntingt). 1992;6(2 Suppl):62-8. Exclude review.
Ball JK, Elixhauser A. Treatment differences between blacks and whites with colorectal cancer. Med Care. 1996;34(9):970-84. Exclude no explicit QM. [pmid: 8792784].
Bampton PA, Sandford JJ, Cole SR, et al. Interval faecal occult blood testing in a colonoscopy based screening programme detects additional pathology. Gut. 2005;54(6):803-6. Exclude non-U.S. data. [pmid: 15888788]. [pmcid: 1774549].
Bampton PA, Sandford JJ, Young GP. Applying evidence-based guidelines improves use of colonoscopy resources in patients with a moderate risk of colorectal neoplasia. Med J Aust. 2002;176(4):155-7. Exclude non-U.S. data. [pmid: 11913914].
Baquet CR, Commiskey P. Colorectal cancer epidemiology in minorities: a review. J Assoc Acad Minor Phys. 1999;10(3):51-8. Exclude falls outside Task Order scope. [pmid: 10826010].
Barkun AN, Jobin G, Cousineau G, et al. The Quebec Association of Gastroenterology position paper on colorectal cancer screening - 2003. Can J Gastroenterol. 2004;18(8):509-19. Exclude non-U.S. data. [pmid: 15372115].
Baron PL, Sigurdson ER. Local surgical treatment of rectal cancer. Cancer Invest. 1995;13(6):612-6. Exclude review. [pmid: 7583712].
Barrier A, Ferro L, Houry S, et al. Rectal cancer surgery in patients more than 80 years of age. Am J Surg. 2003;185(1):54-7. Exclude non-U.S. data. [pmid: 12531446].
Barry MJ. Fecal occult blood testing for colorectal cancer: a perspective. Ann Oncol. 2002;13(1):61-4. Exclude review.
Barton J, Langdale L, Cummins J, et al. The utility of routine preoperative computed tomography scanning in the management of veterans with colon cancer. The American Journal of Surgery. 2002;183:499-503. Exclude no explicit QM.
Bartram C. National audit of the sensitivity of double-contrast barium enema for colorectal carcinoma, using control charts. Clin Radiol. 2005;60(5):555-7. Exclude non-U.S. data. [pmid: 15851042].
Basdanis G, Papadopoulos VN, Michalopoulos A, et al. Colorectal cancer in patients over 70 years of age: determinants of outcome. Tech Coloproctol. 2004;8(Suppl 1):s112-5. . Exclude non-U.S. data. [pmid: 15655591].
Bast R, Ravdin P, Hayes D, et al. 2000 Update of Recommendations for the Use of Tumor Markers in Breast and Colorectal Cancer: Clinical Practice Guidelines of the American Society of Clinical Oncology. J Clin Oncol. 2001;19(6):1865-78. Exclude no explicit QM. [pmid: 11251019].
Beart RW. National Cancer Database: Annual review of patient care, 1992. Atlanta, GA. American Cancer Society 1992;40–6. Exclude falls outside Task Order scope.
Beattie GC, McAdam TK, Elliott S, et al. Improvement in quality of colorectal cancer pathology reporting with a standardized proforma--a comparative study. Colorectal Dis. 2003;5(6):558-62. Exclude non-U.S. data. [pmid: 14617240].
Bech K, Kronborg O, Fenger C. Adenomas and hyperplastic polyps in screening studies. World J Surg. 1991;15(1):7-13. Exclude non-U.S. data. [pmid: 1994609].
Beck NE, Tomlinson IP, Homfray T, et al. Genetic testing is important in families with a history suggestive of hereditary non-polyposis colorectal cancer even if the Amsterdam criteria are not fulfilled. Br J Surg. 1997;84(2):233-7. Exclude falls outside Task Order scope. [pmid: 9052445].
Begg C, Cramer L, Hoskins W, et al. Impact of Hospital Volume on Operative Mortality for Major Cancer Surgery. JAMA. 1998;280(20):1747-51. Exclude falls outside Task Order scope. [pmid: 9842949].
Belkacemi Y, Berger C, Poortmans P, et al. Management of primary anal canal adenocarcinoma: a large retrospective study from the Rare Cancer Network. Int J Radiat Oncol Biol Phys. 2003;56(5):1274-83. Exclude no explicit QM. [pmid: 12873671].
Benson A, Desch C, Flynn P, et al. 2000 Update of American Cancer Society of Clinical Oncology Colorectal Cancer Surveillance Guidelines. J Clin Oncol. 2000;18(20):3586-8. Exclude review. [pmid: 11032600].
Benson AB 3rd, Schrag D, Somerfield MR, et al. American Society of Clinical Oncology recommendations on adjuvant chemotherapy for stage II colon cancer. J Clin Oncol. 2004;22(16):3408-19. Exclude no explicit QM. [pmid: 15199089].
Berberoglu U. Prognostic significance of total lymph node number in patients with T1-4N0M0 colorectal cancer. Hepatogastroenterology. 2004;51(60):1689-93. Exclude falls outside Task Order scope. [pmid: 15532806].
Berg A. Promoting early detection tests for colorectal carcinoma and adenomatous polyps. Cancer. 2003;97(9):2348. Exclude non-U.S. data. [pmid: 12712493].
Bergamaschi R. Surgical strategies in the treatment of colorectal cancer. Eur J Surg Acta Chir Suppl 1995;(575):1–22. Exclude non-U.S. data.
Berlin L. Failure to order. AJR Am J Roentgenol. 1997;168(1):19-21. Exclude no explicit QM. [pmid: 8976912].
Berry DP, Clarke P, Hardcastle JD, et al. Randomized trial of the addition of flexible sigmoidoscopy to faecal occult blood testing for colorectal neoplasia population screening. Br J Surg. 1997;84(9):1274-6. Exclude non-U.S. data. [pmid: 9313712].
Bertagnolli M, Miedema B, Redston M, et al. Sentinel node staging of resectable colon cancer: results of a multicenter study. Ann Surg. 2004;240(4):624-8. discussion 628–30. Exclude review. [pmid: 15383790]. [pmcid: 1356464].
Biganzoli L, Aapro M. Adjuvant chemotherapy in the elderly. Ann Oncol. 2003;14(Suppl 3):iii-3. Exclude non-U.S. data.
Biondo S, Marti-Rague J, Kreisler E, et al. A prospective study of outcomes of emergency and elective surgeries for complicated colonic cancer. Am J Surg. 2005;189(4):377-83. Exclude non-U.S. data. [pmid: 15820446].
Birbeck KF, Macklin CP, Tiffin NJ, et al. Rates of circumferential resection margin involvement vary between surgeons and predict outcomes in rectal cancer surgery. Ann Surg. 2002;235(4):449-57. Exclude non-U.S. data. [pmid: 11923599]. [pmcid: 1422458].
Birkmeyer J, Siewers A, Finlayson E, et al. Hospital volume and surgical mortality in the United States. N Engl J Med. 2002;346(15):1128-37. Exclude falls outside Task Order scope. [pmid: 11948273].
Birkmeyer JD, Dimick J, Birkmeyer N. Measuring the quality of surgical care: structure, process or outcomes. J Am Coll Surg. 2004;198(4):626-32. Exclude review. [pmid: 15051016].
Bjerkeset T, Edna TH. Rectal cancer: the influence of type of operation on local recurrence and survival. Eur J Surg. 1996;162(8):643-8. Exclude non-U.S. data. [pmid: 8891623].
Bleiker EM, Menko FH, Taal BG, et al. Experience of discharge from colonoscopy of mutation negative HNPCC family members. J Med Genet. 2003;40(5):e55. Exclude non-U.S. data. [pmid: 12525544].
Blijham GH, Labianca R, Bleiberg H. Should patients with advanced colorectal cancer be treated with chemotherapy. Eur J Cancer. 1997;33(6):815-24. Exclude non-U.S. data. [pmid: 9291799].
Blom J, Liden A, Jeppsson B, et al. Compliance and findings in a Swedish population screened for colorectal cancer with sigmoidoscopy. Eur J Surg Oncol. 2002;28(8):827-31. Exclude non-U.S. data. [pmid: 12477473].
Blumberg D, Paty PB, Picon AI, et al. Stage I rectal cancer: identification of high-risk patients. J Am Coll Surg. 1998;186(5):574-9. discussion 579–80. Exclude no explicit QM. [pmid: 9583699].
Bond JH. Colorectal cancer and polyps: clinical decisions for screening, early diagnosis, and surveillance of high-risk groups. Compr Ther. 1996;22(2):100-6. Exclude no explicit QM. [pmid: 8689863].
Bond JH. Colorectal surveillance for neoplasia: an overview. Gastrointest Endosc. 1999;49(3 Pt 2):S35-40. Exclude review. [pmid: 10049446].
Bond JH. Colorectal cancer update. Prevention, screening, treatment, and surveillance for high-risk groups. Med Clin North Am 2000;84(5):1163–82, viii. Exclude review.
Bond JH. Update on colorectal polyps: management and follow-up surveillance. Endocsopy. 2003;35(8):S35-40. Exclude review.
Borie F, Combescure C, Daures JP, et al. Cost-effectiveness of two follow-up strategies for curative resection of colorectal cancer: comparative study using a Markov model. World J Surg. 2004;28(6):563-9. Exclude non-U.S. data. [pmid: 15366746].
Borner M, Scheithauer W, Twelves C, et al. Answering patients' needs: oral alternatives to intravenous therapy. Oncologist. 2001;6(Suppl 4):12-6. Exclude review.
Borras M, Sanchez-Hernandez A, Navarro M, et al. Compliance, satisfaction, and quality of life of patients wth colorectal cancer receiving home chemotherapy or outpatient treatment: a randomized controlled trial. Br Med J. 2001;322(7):1-5. Exclude no explicit QM. [pmid: 11141128].
Bosset JF, Horiot JC. Adjuvant treatment in the curative management of rectal cancer: a critical review of the results of clinical randomised trials. Eur J Cancer. 1993;29A(5):770-4. Exclude review. [pmid: 8471338].
Bouchardy C, Queneau PE, Fioretta G, et al. Adjuvant chemotherapy for colon carcinoma with positive lymph nodes: use and benefit in routine health care practice. Br J Cancer. 2001;85(9):1251-7. Exclude non-U.S. data. [pmid: 11720457].
Bouhier K, Maurel J, Lefevre H, et al. Changing practices for diagnosis and treatment of colorectal cancer in Calvados: 1990-1999. Gastroenterol Clin Biol. 2004;28(4):371-6. Exclude non-U.S. data. [pmid: 15146153].
Bowman KF, Deimling GT, Smerglia V, et al. Appraisal of the cancer experience by older long-term survivors. Psychooncology. 2003;12(3):226-38. Exclude no explicit QM. [pmid: 12673807].
Bozzetti F. Operative risk of rectal cancer surgery in the elderly. Am J Surg. 2004;187(1):150-1. author reply 151. Exclude no explicit QM. [pmid: 14706612].
Bradley CJ, Given CW, Roberts C. Late stage cancers in a Medicaid-insured population. Med Care. 2003;41(6):722-8. Exclude data sources. [pmid: 12773838].
Brady AP, Stevenson GW, Stevenson I. Colorectal cancer overlooked at barium enema examination and colonoscopy: a continuing perceptual problem. Radiology. 1994;192(2):373-8. Exclude non-U.S. data. [pmid: 8029400].
Branston LK, Greening S, Newcombe RG, et al. The implementation of guidelines and computerised forms improves the completeness of cancer pathology reporting. The CROPS project: a randomised controlled trial in pathology. Eur J Cancer. 2002;38(6):764-72. Exclude non-U.S. data. [pmid: 11937309].
Brawley OW, Freeman HP. Race and outcomes: is this the end of the beginning for minority health research. J Natl Cancer Inst. 1999;91(22):1908-9. Exclude no explicit QM. [pmid: 10564668].
Bretthauer M, Skovlund E, Grotmol T, et al. Inter-endoscopist variation in polyp and neoplasia pick-up rates in flexible sigmoidoscopy screening for colorectal cancer. Scand J Gastroenterol. 2003;38(12):1268-74. Exclude non-U.S. data. [pmid: 14750648].
Brewster D, Muir C, Crichton J. Registration of colorectal cancer in Scotland: an assessment of data accuracy based on review of medical records. Public Health. 1995;109(4):285-92. Exclude non-U.S. data. [pmid: 7667493].
Brown BW, Brauner C, Minnotte MC. Noncancer deaths in white adult cancer patients. J Natl Cancer Inst. 1993;85(12):979-87. Exclude falls outside Task Order scope. [pmid: 8496983].
Brown ML, Riley GF, Potosky AL, et al. Obtaining long-term disease specific costs of care: application to Medicare enrollees diagnosed with colorectal cancer. Med Care. 1999;37(12):1249-59. Exclude no explicit QM. [pmid: 10599606].
Brown MT, Frelick RW, Topham A. Trends in colorectal cancer in Delaware. Del Med J. 1992;64(1):33-5. Exclude no explicit QM. [pmid: 1572495].
Brown SC, Abraham JS, Walsh S, et al. Risk factors and operative mortality in surgery for colorectal cancer. Ann R Coll Surg Engl. 1991;73(5):269-72. Exclude non-U.S. data. [pmid: 1929123]. [pmcid: 2499498].
Bruinvels DJ, de Brauw LM, Kievit J, et al. Attitudes towards detection and management of hepatic metastases of colorectal origin: a second look. HPB Surg. 1994;8(2):115-22. Exclude non-U.S. data. [pmid: 7880770]. [pmcid: 2423768].
Bujko K, Nowacki MP, Nasierowska-Guttmejer A, et al. Sphincter preservation following preoperative radiotherapy for rectal cancer: report of a randomised trial comparing short-term radiotherapy vs. conventionally fractionated radiochemotherapy. Radiother Oncol. 2004;72(1):15-24. Exclude non-U.S. data. [pmid: 15236870].
Bull AD, Biffin AH, Mella J, et al. Colorectal cancer pathology reporting: a regional audit. J Clin Pathol. 1997;50(2):138-42. Exclude non-U.S. data. [pmid: 9155695]. [pmcid: 499739].
Bulow S, Bulow C, Nielsen TF, et al. Centralized registration, prophylactic examination, and treatment results in improved prognosis in familial adenomatous polyposis. Results from the Danish Polyposis Register. Scand J Gastroenterol. 1995;30(10):989-93. Exclude non-U.S. data. [pmid: 8545620].
Bulow S, Burn J, Neale K, et al. The establishment of a polyposis register. Int J Colorectal Dis. 1993;8(1):34-8. Exclude non-U.S. data. [pmid: 8388012].
Bumpers HL, Williams WL Jr, Hassett JM Jr, et al. Colon cancer in blacks: age-related presentation and survival within a similar socioeconomic group. J Natl Med Assoc. 1994;86(3):216-8. Exclude survival only. [pmid: 8189455]. [pmcid: 2568181].
Burke C. The Cleveland Clinic Disease Management Project 2002. Exclude no explicit QM.
Burn J, Chapman P, Delhanty J, et al. The UK Northern region genetic register for familial adenomatous polyposis coli: use of age of onset, congenital hypertrophy of the retinal pigment epithelium, and DNA markers in risk calculations. J Med Genet. 1991;28(5):289-96. Exclude non-U.S. data. [pmid: 1650842]. [pmcid: 1016845].
Burnand B, Vader JP, Froehlich F, et al. Reliability of panel-based guidelines for colonoscopy: an international comparison. Gastrointest Endosc. 1998;47(2):162-6. Exclude no explicit QM. [pmid: 9512282].
Burton A. Will you survive surgery for colorectal cancer. Lancet Oncol. 2004;5(1):7. Exclude non-U.S. data.
Butler Nattinger A, Schapira MM, Warren JL, et al. Methodological issues in the use of administrative claims data to study surveillance after cancer treatment. Med Care 2002;40(8 Suppl):IV-69–74. Exclude data sources.
Byers T, Levin B, Rothenberger D, et al. American Cancer Society guidelines for screening and surveillance for early detection of colorectal polyps and cancer: update 1997. American Cancer Society Detection and Treatment Advisory Group on Colorectal Cancer. CA Cancer J Clin. 1997;47(3):154-60. Exclude falls outside Task Order scope. [pmid: 9152173].
Byles JE, Sanson-Fisher RW, Redman S, et al. Early detection of colorectal cancer: a profile of current practice. Cancer Detect Prev. 1992;16(4):245-52. Exclude non-U.S. data. [pmid: 1458515].
Caffo O, Amichetti M, Romano M, et al. Evaluation of toxicity and quality of life using a diary card during postoperative radiotherapy for rectal cancer. Dis Colon Rectum. 2002;45(4):459-65. discussion 465–7. Exclude QOL. [pmid: 12006925].
Cairns S, Scholefield JH. Guidelines for colorectal cancer screening in high risk groups. Gut. 2002;51(Suppl 5):V1-2. Exclude non-U.S. data. [pmid: 12077078].
Campbell NC, Elliott AM, Sharp L, et al. Impact of deprivation and rural residence on treatment of colorectal and lung cancer. Br J Cancer. 2002;87(6):585-90. Exclude non-U.S. data. [pmid: 12237766].
Campbell RJ, Ferrante JM, Gonzalez EC, et al. Predictors of advanced stage colorectal cancer diagnosis: results of a population-based study. Cancer Detect Prev. 2001;25(5):430-8. Exclude no explicit QM. [pmid: 11718449].
Canadian Task Force on Preventive Health Care. Colorectal cancer screening. Recommendation statement from the Canadian Task Force on Preventive Health Care. CMAJ 2001;165(2):206-8. Exclude review.
Cancer Quality Council of Ontario. Improving the management of colorectal cancer. Summary of the cancer quality council of ontario signature event on colorectal cancer. Available at: http://www.cancer.care.on.ca/pdf/CQCOColorectalProceedings.pdf. Accessed: April 6, 2005. 2003;1–30. Exclude review.
Cancer Quality Council of Ontario. Strengthening the Quality of Cancer Services in Ontario:Synopsis. Cancer Quality Council of Ontario. Available at http://www.cancercare.on.ca/pdf/synopsis_CQCO_Report.pdf. Accessed: May 9, 2005. 2003. Exclude review.
Canon CL, Smith JK, Morgan DE, et al. Double reading of barium enemas: is it necessary. AJR Am J Roentgenol. 2003;181(6):1607-10. Exclude wrong population. [pmid: 14627582].
Caplin S, Cerottini JP, Bosman FT, et al. For patients with Dukes' B (TNM Stage II) colorectal carcinoma, examination of six or fewer lymph nodes is related to poor prognosis. Cancer. 1998;83(4):666-72. Exclude non-U.S. data. [pmid: 9708929].
Capocaccia R, Gatta G, Roazzi P, et al. The EUROCARE-3 database: methodology of data collection, standardisation, quality control and statistical analysis. Ann Oncol. 2003;13(Suppl 5):v14-27. Exclude non-U.S. data.
Carmody BJ, Otchy DP. Learning curve of transrectal ultrasound. Dis Colon Rectum. 2000;43(2):193-7. Exclude no explicit QM. [pmid: 10696893].
Carstensen B, Soll-Johanning H, Villadsen E, et al. Familial aggregation of colorectal cancer in the general population. Int J Cancer. 1996;68(4):428-35. Exclude non-U.S. data. [pmid: 8945611].
Carter S, Winslet M. Delay in the presentation of colorectal carcinoma: a review of causation. Int J Colorectal Dis. 1998;13(1):27-31. Exclude non-U.S. data. [pmid: 9548097].
Carter SD. The surgeon as a risk factor. Adv Surg. 2002;36:141-65. Exclude non-U.S. data. [pmid: 12465550].
Cascinu S, Del Ferro E, Grianti C, et al. S-phase fraction and tumor aneuploidy in colorectal carcinoma of young patients. Cancer. 1996;78(9):1857-60. Exclude no explicit QM. [pmid: 8909303].
Castells A, Bessa X, Daniels M, et al. Value of postoperative surveillance after radical surgery for colorectal cancer: results of a cohort study. Dis Colon Rectum. 1998;41(6):714-23. discussion 723–4. Exclude non-U.S. data. [pmid: 9645739].
Castiglione G, Zappa M, Grazzini G, et al. Cost analysis in a population based screening programme for colorectal cancer: comparison of immunochemical and guaiac faecal occult blood testing. J Med Screen. 1997;4(3):142-6. Exclude non-U.S. data. [pmid: 9368871].
Chak A, Cooper GS, Blades EW, et al. Prospective assessment of colonoscopic intubation skills in trainees. Gastrointest Endosc. 1996;44(1):54-7. Exclude no explicit QM. [pmid: 8836717].
Chapman JR, Larson DW, Wolff BG, et al. Ileal pouch-anal anastomosis: does age at the time of surgery affect outcome. Arch Surg. 2005;140(6):534-9. discussion 539–40. Exclude QOL. [pmid: 15967900].
Charnley N, Choudhury A, Chesser P, et al. Effective treatment of anal cancer in the elderly with low-dose chemoradiotherapy. Br J Cancer. 2005;92(7):1221-5. Exclude falls outside Task Order scope. [pmid: 15798772].
Chen HS, Sheen-Chen SM. Obstruction and perforation in colorectal adenocarcinoma: an analysis of prognosis and current trends. Surgery. 2000;127(4):370-6. Exclude non-U.S. data. [pmid: 10776426].
Chen VW, Wu XC, Ahmed MN, et al. Cancer of the colon and rectum in Louisiana. J La State Med Soc. 1999;151(4):189-97. Exclude survival only. [pmid: 10234894].
Cheson BD. Clinical trials referral resource. Adjuvant therapy for colon cancer. Oncology (Huntingt) 1990;4(4):67–9, 74, 79–84. Exclude no explicit QM.
Cheson BD. Clinical trials referral resource. Rectal cancer. Oncology (Huntingt). 1990;4(6):58-71. Exclude no explicit QM. [pmid: 2145000].
Cheson BD. Clinical trials referral resource. Oncology (Huntingt). 1990;4(11):72. Exclude no explicit QM.
Cheson BD. Clinical trials referral resource. Treatment of advanced colorectal cancer. Oncology (Huntingt) 1991;5(4):61–2, 65–6, 68 passim. Exclude no explicit QM.
Cheson BD, Kaplan RS, Phillips PH. Clinical trials referral resource. Colon cancer. Oncology (Huntingt). 1994;8(8):43-4. Exclude no explicit QM.
Cheson BD, Ungerleider RS. Clinical trials referral resource. [erratum appears in Oncology (Huntingt) 1993 Apr;7(4):38]. Oncology (Huntingt) 1993;7(3):55–6, 59. Exclude no explicit QM.
Child PW, Yan TD, Perera DS, et al. Surveillance-detected hepatic metastases from colorectal cancer had a survival advantage in seven-year follow-up. Dis Colon Rectum. 2005;48(4):744-8. Exclude non-U.S. data. [pmid: 15747072].
Chin SM. Clinical pathway for colorectal procedures. Hosp Case Manag. 2002;10(12):183-5. Exclude non-U.S. data. [pmid: 12489388].
Christensen M, Katballe N, Wikman F, et al. Antibody-based screening for hereditary nonpolyposis colorectal carcinoma compared with microsatellite analysis and sequencing. Cancer. 2002;95(11):2422-30. Exclude falls outside Task Order scope. [pmid: 12436451].
Chu E. Lessons learned from the Saltz and Mayo Clinic regimens. Clin Colorectal Cancer. 2002;2(1):13. Exclude no data source val. or rel. testing. [pmid: 12453330].
Chung YF, Eu KW, Machin D, et al. Young age is not a poor prognostic marker in colorectal cancer. Br J Surg. 1998;85(9):1255-9. . Exclude non-U.S. data. [pmid: 9752871].
Church J, Kiringoda R, LaGuardia L. Inherited colorectal cancer registries in the United States. Dis Colon Rectum. 2004;47(5):674-8. Exclude review. [pmid: 15037932].
Church JM. The ileal pouch-anal anastomosis in challenging patients: stretching the limits. Ann N Z J Surg. 1995;65(2):104-6. Exclude non-U.S. data.
Church JM. Clinical significance of small colorectal polyps. Dis Colon Rectum. 2004;47(4):481-5. Exclude no explicit QM. [pmid: 14994108].
Church TR, Ederer F, Mandel JS. Fecal occult blood screening in the Minnesota study: sensitivity of the screening test. J Natl Cancer Inst. 1997;89(19):1440-8. Exclude falls outside Task Order scope. [pmid: 9326913].
Cianchi F, Palomba A, Boddi V, et al. Lymph node recovery from colorectal tumor specimens: recommendation for a minimum number of lymph nodes to be examined. World J Surg. 2002;26(3):384-9. Exclude non-U.S. data. [pmid: 11865379].
Ciferri E, Bondanza GS, Municino O, et al. Colorectal cancer metastases: surgical indications and multimodal approach. Hepatogastroenterology. 2003;50(54):1836-46. Exclude non-U.S. data. [pmid: 14696416].
Clemmesen T, Sprechler M. Recording of patients with colorectal cancer on a database: results and advantages. Eur J Surg. 1994;160(3):175-8. Exclude non-U.S. data. [pmid: 8003570].
Clipp EC, Carver EH, Pollak KI, et al. Age-related vulnerabilities of older adults with colon adenomas: evidence from Project Prevent. Cancer. 2004;100(5):1085-94. Exclude no explicit QM. [pmid: 14983506].
Cockburn J, Paul C, Tzelepis F, et al. Screening for bowel cancer among NSW adults with varying levels of risk: a community survey. Aust N Z J Public Health. 2002;26(3):236-41. Exclude non-U.S. data. [pmid: 12141619].
Cockburn J, Paul C, Tzelepis F, et al. Delay in seeking advice for symptoms that potentially indicate bowel cancer. Am J Health Behav. 2003;27(4):401-7. Exclude non-U.S. data. [pmid: 12882434].
Cole SR, Young GP, Byrne D, et al. Participation in screening for colorectal cancer based on a faecal occult blood test is improved by endorsement by the primary care practitioner. J Med Screen. 2002;9(4):147-52. Exclude non-U.S. data. [pmid: 12518003].
Collett JA, Olynyk JK, Platell CF. Flexible sigmoidoscopy screening for colorectal cancer in average-risk people: update of a community-based project. Med J Aust. 2000;173(9):463-6. Exclude non-U.S. data. [pmid: 11149301].
Collopy BT. Quantity, qualifications and quality in surgery. Med J Aust. 1999;171(6):306-7. Exclude review. [pmid: 10560447].
Colombet I, Xu Y, Jaulent MC, et al. A generic computerized method for estimate of familial risks. Proc AMIA Symp 2002;175–9. Exclude non-U.S. data.
Compton CC, Fielding LP, Burgart LJ, et al. Prognostic factors in colorectal cancer. College of American Pathologists Consensus Statement 1999. Arch Pathol Lab Med. 2000;124(7):979-94. Exclude no explicit QM. [pmid: 10888773].
Compton CC, Henson DE, Hutter RV, et al. Updated protocol for the examination of specimens removed from patients with colorectal carcinoma. A basis for checklists. Arch Pathol Lab Med. 1997;121(12):1247-54. Exclude no explicit QM. [pmid: 9431313].
Conley BA, Kaplan RS, Arbuck SG. National Cancer Institute clinical trials program in colorectal cancer. Cancer Chemother Pharmacol. 1998;42(Suppl):S75-9. Exclude no explicit QM. [pmid: 9750034].
Connell W. PRO: Endoscopic surveillance minimizes the risk of cancer. Am J Gastroenterol. 2004;99(9):1631-3. Exclude no explicit QM. [pmid: 15330891].
Connor S, Frizelle FA, Bagshaw PF. Follow-up after attempted curative surgery for colorectal cancer; postal survey of New Zealand surgeons' practice. N Z Med J. 2001;114(1129):151-3. Exclude non-U.S. data. [pmid: 11400920].
Cooney A, Donnelly NJ, Gattellari M, et al. Surgeons' views about colorectal cancer screening before and after national guidelines. Med J Aust. 2002;177(5):278-9. Exclude non-U.S. data.
Cooper GS, Fortinsky RH, Hapke R, et al. Primary care physician recommendations for colorectal cancer screening. Patient and practitioner factors. Arch Intern Med. 1997;157(17):1946-50. Exclude falls outside Task Order scope. [pmid: 9308506].
Cooper GS, Fortinsky RH, Hapke R, et al. Factors associated with the use of flexible sigmoidoscopy as a screening test for the detection of colorectal carcinoma by primary care physicians. Cancer. 1998;82(8):1476-81. Exclude falls outside Task Order scope. [pmid: 9554523].
Cooper GS, Koroukian SM. Racial disparities in the use of and indications for colorectal procedures in Medicare beneficiaries. Cancer. 2004;100(2):418-24. Exclude no explicit QM. [pmid: 14716780].
Cooper GS, Yuan Z, Stange KC, et al. Use of Medicare claims data to measure county-level variations in the incidence of colorectal carcinoma. Cancer. 1998;83(4):673-8. Exclude no explicit QM. [pmid: 9708930].
Cordice JW Jr,, Johnson H Jr. Anatomic distribution of colonic cancers in middle-class black Americans. J Natl Med Assoc. 1991;83(8):730-2. Exclude no explicit QM. [pmid: 1956086]. [pmcid: 2627127].
Courtier R, Casamitjana M, Macia F, et al. Participation in a colorectal cancer screening programme: influence of the method of contacting the target population. Eur J Cancer Prev. 2002;11(3):209-13. Exclude non-U.S. data. [pmid: 12131653].
Cravo ML, Fidalgo PO, Lage PA, et al. Validation and simplification of Bethesda guidelines for identifying apparently sporadic forms of colorectal carcinoma with microsatellite instability. Cancer. 1999;85(4):779-85. Exclude non-U.S. data. [pmid: 10091754].
Crawley MT, Booth A. Reducing dose at barium enema: radiographers do it digitally. Br J Radiol. 2002;75(896):652-6. Exclude non-U.S. data. [pmid: 12153938].
Crespi M, Stigliano V, Assisi D. Current trends in screening and secondary prevention of colorectal cancer. Hepatogastroenterology. 2001;48(42):1635-40. Exclude non-U.S. data. [pmid: 11813590].
Cress RD, Zaslavsky AM, West DW, et al. Completeness of information on adjuvant therapies for colorectal cancer in population-based cancer registries. Med Care. 2003;41(9):1006-12. Exclude no explicit QM. [pmid: 12972840].
Cripps NP, Heald RJ. Family based colorectal cancer screening in a district hospital. Gut. 1996;38(3):421-5. Exclude non-U.S. data. [pmid: 8675097]. [pmcid: 1383073].
Cross SS, Bull AD. Is the informational content of histopathological reports increasing?. J Clin Pathol. 1992;45(2):179-80. Exclude non-U.S. data. [pmid: 1541706]. [pmcid: 495678].
Cross SS, Burton JL, Dube AK, et al. Offline telepathology diagnosis of colorectal polyps: a study of interobserver agreement and comparison with glass slide diagnoses. J Clin Pathol. 2002;55(4):305-8. Exclude non-U.S. data. [pmid: 11919218]. [pmcid: 1769634].
Cross SS, Feeley KM, Angel CA. The effect of four interventions on the informational content of histopathology reports of resected colorectal carcinomas. J Clin Pathol. 1998;51(6):481-2. Exclude non-U.S. data. [pmid: 9771453]. [pmcid: 500757].
Culpan DG, Mitchell AJ, Hughes S, et al. Double contrast barium enema sensitivity: a comparison of studies by radiographers and radiologists. Clin Radiol. 2002;57(7):604-7. Exclude non-U.S. data. [pmid: 12096859].
Cumbo A, Agre P, Dougherty J, et al. Online cancer patient education: evaluating usability and content. Cancer Pract. 2002;10(3):155-61. Exclude no explicit QM. [pmid: 11972570].
Curb JD, McTiernan A, Heckbert SR, et al. Outcomes ascertainment and adjudication methods in the Women's Health Initiative. Ann Epidemiol. 2003;13(9 Suppl):S122-8. Exclude no explicit QM. [pmid: 14575944].
Cusack JC, Giacco GG, Cleary K, et al. Survival factors in 186 patients younger than 40 years old with colorectal adenocarcinoma. J Am Coll Surg. 1996;183(2):105-12. Exclude no explicit QM. [pmid: 8696540].
Dachman AH, Zalis ME. Quality and consistency in CT colonography and research reporting. Radiology. 2004;230(2):319-23. Exclude falls outside Task Order scope. [pmid: 14752176].
Daher M. Consensus conference. Colorectal cancer: prevention, screening and management. J Med Liban. 1998;46(5):268-79. Exclude no explicit QM. [pmid: 10349261].
Dahlberg M, Stenborg A, Pahlman L, et al. Cost-effectiveness of preoperative radiotherapy in rectal cancer: results from the Swedish Rectal Cancer Trial. Int J Radiat Oncol Biol Phys. 2002;54(3):654-60. Exclude non-U.S. data. [pmid: 12377315].
Damhuis RA, Wereldsma JC, Wiggers T. The influence of age on resection rates and postoperative mortality in 6457 patients with colorectal cancer. Int J Colorectal Dis. 1996;11(1):45-8. Exclude non-U.S. data. [pmid: 8919342].
Damhuis RA, Wiggers T, Wereldsma JC. Association between age and local recurrence of rectal cancer: results from a retrospective study of 902 patients. Int J Colorectal Dis. 1997;12(4):235-9. Exclude non-U.S. data. [pmid: 9272454].
Daneker GW Jr,, Staley CA. Surgical resection of hepatic tumors-patient selection and technical considerations. Cancer Treat Res. 2001;109:229-46. Exclude review. [pmid: 11775439].
Dangelica MI, Shoup MC, Nissan A. Randomized clinical trials in advanced and metastatic colorectal carcinoma. Surg Oncol Clin N Am 2002;11(1):173–91, ix. Exclude review.
Davidson-Homewood J, Norman A, Kuchler T, et al. Development of a disease specific questionnaire to supplement a generic tool for QoL in colorectal cancer. Psychooncology 2003;12(7):675–85. Exclude non-U.S. data.
Davidson P, Cockburn J, Daly J, et al. Patient-centered needs assessment: rationale for a psychometric measure for assessing needs in heart failure. J Cardiovasc Nurs. 2004;19(3):164-71. . Exclude no explicit QM. [pmid: 15191258].
Davies RJ, Collins CD, Vickery CJ, et al. Reduction in the proportion of patients with colorectal cancer presenting as an emergency following the introduction of fast-track flexible sigmoidoscopy: a three-year prospective observational study. Colorectal Dis. 2004;6(4):265-7. Exclude non-U.S. data. [pmid: 15206971].
Davis TC, Dolan NC, Ferreira MR, et al. The role of inadequate health literacy skills in colorectal cancer screening. Cancer Invest. 2001;19(2):193-200. Exclude falls outside Task Order scope. [pmid: 11296623].
Dawkins FW, Laing AE, Smoot DT, et al. The impact of health insurance on an African-American population with colorectal cancer. J Natl Med Assoc. 1995;87(4):301-3. Exclude survival only. [pmid: 7752284]. [pmcid: 2607812].
de Bosset V, Froehlich F, Rey JP, et al. Do explicit appropriateness criteria enhance the diagnostic yield of colonoscopy. Endocsopy. 2002;34(5):360-8. Exclude non-U.S. data.
de Haes JC, van Knippenberg FC, Neijt JP. Measuring psychological and physical distress in cancer patients: structure and application of the Rotterdam Symptom Checklist. Br J Cancer. 1990;62(6):1034-8. Exclude non-U.S. data. [pmid: 2257209].
de Vos tot Nederveen Cappel WH, Nagengast FM, Griffioen G, et al. Surveillance for hereditary nonpolyposis colorectal cancer: a long-term study on 114 families. Dis Colon Rectum. 2002;45(12):1588-94. Exclude non-U.S. data. [pmid: 12473880].
Debinski HS, Love S, Spigelman AD, et al. Colorectal polyp counts and cancer risk in familial adenomatous polyposis. Gastroenterology. 1996;110(4):1028-30. Exclude falls outside Task Order scope. [pmid: 8612989].
Debnath D, Dielehner N, Gunning KA. Guidelines, compliance, and effectiveness: a 12 months' audit in an acute district general healthcare trust on the two week rule for suspected colorectal cancer. Postgrad Med J. 2002;78(926):748-51. Exclude non-U.S. data. [pmid: 12509694]. [pmcid: 1757929].
DeCosse J, Cennerazzo W. Quality - of - life management of patients with colorectal cancer. CA Cancer J Clin. 1997;47:198-206. Exclude review. [pmid: 9242168].
Dehni N, Schlegel D, Tiret E, et al. Effects of aging on the functional outcome of coloanal anastomosis with colonic J-pouch. Am J Surg. 1998;175(3):209-12. Exclude non-U.S. data. [pmid: 9560121].
Delaney CP, Fazio VW, Remzi FH, et al. Prospective, age-related analysis of surgical results, functional outcome, and quality of life after ileal pouch-anal anastomosis. Ann Surg. 2003;238(2):221-8. Exclude no explicit QM. [pmid: 12894015]. [pmcid: 1422678].
Delea TE, Vera-Llonch M, Edelsberg JS, et al. The incidence and cost of hospitalization for 5-FU toxicity among Medicare beneficiaries with metastatic colorectal cancer. Value Health. 2002;5(1):35-43. Exclude falls outside Task Order scope. [pmid: 11873382].
Delgado S, Lacy AM, Garcia Valdecasas JC, et al. Could age be an indication for laparoscopic colectomy in colorectal cancer. Surg Endosc. 2000;14(1):22-6. Exclude no explicit QM. [pmid: 10653230].
Demartines N, von Flue MO, Harder FH. Transanal endoscopic microsurgical excision of rectal tumors: indications and results. World J Surg. 2001;25(7):870-5. Exclude no explicit QM. [pmid: 11572026].
Demers RY, Severson RK, Schottenfeld D, et al. Incidence of colorectal adenocarcinoma by anatomic subsite. An epidemiologic study of time trends and racial differences in the Detroit, Michigan area. Cancer. 1997;79(3):441-7. Exclude no explicit QM. [pmid: 9028352].
Demetriades H, Kanellos I, Vasiliadis K, et al. Age-associated prognosis following curative resection for colorectal cancer. Tech Coloproctol. 2004;8(Suppl 1):s144-6. Exclude non-U.S. data. [pmid: 15655602].
Demols A, Van Laethem JL. Adjuvant chemotherapy for colorectal cancer. Curr Gastroenterol Rep. 2002;4(5):420-6. Exclude review. [pmid: 12228045].
Denis B, Weiss AM, Peter A, et al. Quality assurance and gastrointestinal endoscopy: an audit of 500 colonoscopic procedures. Gastroenterol Clin Biol. 2004;28(12):1245-55. Exclude non-U.S. data. [pmid: 15671936].
Dent OF, Goulston KJ, Tennant CC, et al. Rectal bleeding. Patient delay in presentation. Dis Colon Rectum. 1990;33(10):851-7. Exclude non-U.S. data. [pmid: 2209274].
Desch C, Benson A, Smith T, et al. Recommended Colorectal Cancer Surveillance Guidelines by the American Society of Clinical Oncology. J Clin Oncol. 1999;17(4):1312-21. . Exclude review. [pmid: 10561194].
Dharma-Wardene MW, de Gara C, Au HJ, et al. Ageism in rectal carcinoma? Treatment and outcome variations. Int J Gastrointest Cancer. 2002;32(23):129-38. Exclude non-U.S. data. [pmid: 12794249].
DiBetta E, D'Hoore A, Filez L, et al. Sphincter saving rectum resection is the standard procedure for low rectal cancer. Int. J Colorectal Dis. 2003;18:463-9. Exclude non-U.S. data.
Dietrich AJ, Sox CH, Tosteson TD, et al. Durability of improved physician early detection of cancer after conclusion of intervention support. Cancer Epidemiol Biomarkers Prev. 1994;3(4):335-40. Exclude no explicit QM. [pmid: 8061583].
Dignam JJ, Colangelo L, Tian W, et al. Outcomes among African-Americans and Caucasians in colon cancer adjuvant therapy trials: findings from the National Surgical Adjuvant Breast and Bowel Project. J Natl Cancer Inst. 1999;91(22):1933-40. Exclude no explicit QM. [pmid: 10564677].
DiPalma AM, Barnes SE, DiPalma JA. Patient participation in colon cancer screening programs. South Med J. 1998;91(4):342-4. Exclude falls outside Task Order scope. [pmid: 9563424].
Dittrich K, Armbruster C, Hoffer F, et al. Nd:YAG laser treatment of colorectal malignancies: an experience of 4 1/2 years. Lasers Surg Med. 1992;12(2):199-203. Exclude non-U.S. data. [pmid: 1374143].
Dolan JG, Bordley DR. Using the analytic hierarchy process (AHP) to develop and disseminate guidelines. QRB Qual Rev Bull. 1992;18(12):440-7. Exclude falls outside Task Order scope. [pmid: 1287526].
Dominitz JA, Provenzale D. Patient preferences and quality of life associated with colorectal cancer screening. Am J Gastroenterol. 1997;92(12):2171-8. Exclude falls outside Task Order scope. [pmid: 9399747].
Donaldson GW, Moinpour CM. Individual differences in quality-of-life treatment response. Med Care. 2002;40(6 Suppl):III39-53. Exclude no explicit QM. [pmid: 12064757].
Dorrance HR, Docherty GM, O'Dwyer PJ. Effect of surgeon specialty interest on patient outcome after potentially curative colorectal cancer surgery. Dis Colon Rectum. 2000;43(4):492-8. Exclude non-U.S. data. [pmid: 10789744].
Dowdall JF, Maguire D, McAnena OJ. Adjuvant therapy for rectal cancer cannot be based on the results of other surgeons (Br J Surg 2002; 89: 946–947). Br J Surg. 2003;90(5):594. Exclude non-U.S. data.
Duffy MJ, van Dalen A, Haglund C, et al. Clinical utility of biochemical markers in colorectal cancer: European Group on Tumour Markers (EGTM) guidelines. Eur J Cancer. 2003;39(6):718-27. Exclude non-U.S. data. [pmid: 12651195].
Durkalski VL, Palesch YY, Pineau BC, et al. The virtual colonoscopy study: a large multicenter clinical trial designed to compare two diagnostic screening procedures. Control Clin Trials. 2002;23(5):570-83. Exclude no explicit QM. [pmid: 12392872].
Duxbury MS, Brodribb AJ, Oppong FC, et al. Management of colorectal cancer: variations in practice in one hospital. Eur J Surg Oncol. 2003;29(4):400-2. Exclude non-U.S. data. [pmid: 12711298].
Dwyer K. Breaks in care in the ambulatory care setting: the risks to patient safety. [erratum appears in Int J Qual Health Care 2003 Feb;15(1):99]. Int J Qual Health Care. 2002;14(3):259-60. Exclude review. [pmid: 12108536].
Eaden JA, Ward BA, Mayberry JF. How gastroenterologists screen for colonic cancer in ulcerative colitis: an analysis of performance. Gastrointest Endosc. 2000;51(2):123-8. Exclude non-U.S. data. [pmid: 10650251].
Earle CC, Grunfeld E, Coyle D, et al. Cancer physicians' attitudes toward colorectal cancer follow-up. Ann Oncol. 2003;14(3):400-5. Exclude non-U.S. data. [pmid: 12598345].
Earle CC, Neville BA. Under use of necessary care among cancer survivors. Cancer. 2004;101(8):1712-9. Exclude no explicit QM. [pmid: 15386307].
Easson AM, Cotterchio M, Crosby JA, et al. A population-based study of the extent of surgical resection of potentially curable colon cancer. Ann Surg Oncol. 2002;9(4):380-7. Exclude non-U.S. data. [pmid: 11986190].
Eccersley AJ, Wilson EM, Makris A, et al. Referral guidelines for colorectal cancer--do they work. Ann R Coll Surg Engl. 2003;85(2):107-10. . Exclude non-U.S. data. [pmid: 12648341]. [pmcid: 1963720].
Eckardt VF, Schmitt T, Kanzler G, et al. Does scant hematochezia necessitate the performance of total colonoscopy. Endocsopy. 2002;34(8):599-603. Exclude non-U.S. data.
Eddy DM. Clinical decision making: from theory to practice. Designing a practice policy. Standards, guidelines, and options. JAMA 1990;263(22):3077, 3081, 3084. Exclude falls outside Task Order scope
Ederer F, Church TR, Mandel JS. Fecal occult blood screening in the Minnesota study: role of chance detection of lesions. J Natl Cancer Inst. 1997;89(19):1423-8. Exclude falls outside Task Order scope. [pmid: 9326911].
Ederer F, Geisser MS, Mongin SJ, et al. Colorectal cancer deaths as determined by expert committee and from death certificate: a comparison. The Minnesota Study. J Clin Epidemiol. 1999;52(5):447-52. Exclude data sources. [pmid: 10360340].
Edna TH, Bjerkeset T. Perioperative blood transfusions reduce long-term survival following surgery for colorectal cancer. Dis Colon Rectum. 1998;41(4):451-9. Exclude non-U.S. data. [pmid: 9559629].
Edna TH, Bjerkeset T. Association between transfusion of stored blood and infective bacterial complications after resection for colorectal cancer. Eur J Surg. 1998;164(6):449-56. Exclude non-U.S. data. [pmid: 9696446].
Edwards JT, Wood CJ, Mendelson RM, et al. Extracolonic findings at virtual colonoscopy: implications for screening programs. Am J Gastroenterol. 2001;96(10):3009-12. Exclude non-U.S. data. [pmid: 11693340].
Efficace F, Bottomley A, Blazeby JM. Randomized clinical trial comparing quality of life after straight and pouch coloanal reconstruction (Br J Surg 2003; 89: 1108–1117). Br J Surg. 2003;90(5):594-5. Exclude non-U.S. data.
Ekelund G. The colorectal surgeon's scientific and economic responsibility. Dis Colon Rectum. 1993;36(8):728-30. Exclude non-U.S. data. [pmid: 8348858].
Elliott BA, Renier CM, Haller IV, et al. Health-related quality of life (HRQoL) in patients with cancer and other concurrent illnesses. Qual Life Res. 2004;13(2):457-62. Exclude QOL. [pmid: 15085918].
Ellison GL, Warren JL, Knopf KB, et al. Racial differences in the receipt of bowel surveillance following potentially curative colorectal cancer surgery. Health Serv Res. 2003;38(6 Pt 2):1885-903. Exclude results combined across modalities. [pmid: 14727802]. [pmcid: 1360978].
Elsaleh H, Iacopetta B. Re: Pooled analysis of fluorouracil-based adjuvant therapy of stage II and III colon cancer: who benefits and by how much. J Clin Oncol. 2005;23(3):653-4. author reply 654–5. Exclude no explicit QM. [pmid: 15659520].
Enblad G, Enblad P, Adami HO, et al. Relationship between age and survival in cancer of the colon and rectum with special reference to patients less than 40 years of age. Br J Surg. 1990;77(6):611-6. Exclude non-U.S. data. [pmid: 2383722].
Engel AF, Oomen JL, Eijsbouts QA, et al. Nationwide decline in annual numbers of abdomino-perineal resections: effect of a successful national trial?. Colorectal Dis. 2003;5(2):180-4. Exclude non-U.S. data. [pmid: 12780910].
Engel J, Kerr J, Schlesinger-Raab A, et al. Comparison of breast and rectal cancer patients' quality of life: results of a four year prospective field study. Eur J Cancer Care (Engl). 2003;12(3):215-23. Exclude non-U.S. data. [pmid: 12919300].
Engstrom PF, Benson AB 3rd, Cohen A, et al. NCCN Colorectal Cancer Practice Guidelines. The National Comprehensive Cancer Network. Oncology (Huntingt). 1996;10(11 Suppl):140-75. Exclude no explicit QM. [pmid: 8953601].
Enker WE. Potency, cure, and local control in the operative treatment of rectal cancer. Arch Surg. 1992;127(12):1396-401. discussion 1402. Exclude no explicit QM. [pmid: 1365683].
Erban S, Zapka J, Puleo E, et al. Colorectal cancer screening in Massachusetts: measuring compliance with current guidelines. Eff Clin Pract. 2001;4(1):10-7. Exclude falls outside Task Order scope. [pmid: 11234181].
Essiet A, Iwatt AR. Surgical management of large bowel cancer 1983-1988, University of Calabar Teaching Hospital audit. Cent Afr J Med. 1994;40(1):8-13. Exclude non-U.S. data. [pmid: 8082150].
Extermann M. Measuring comorbidity in older cancer patients. Eur J Cancer. 2000;36:453-71. Exclude no explicit QM. [pmid: 10717521].
Fallahzadeh H, Mays ET. Preexisting disease as a predictor of the outcome of colectomy. Am J Surg. 1991;162(5):497-8. Exclude no explicit QM. [pmid: 1951920].
Faris I. Guidelines for the management of colonic cancer. Ann N Z J Surg. 1999;69(6):410. Exclude non-U.S. data.
Farmer KC, Penfold C, Millar JL, et al. Rectal cancer in Victoria in 1994: patterns of reported management. ANZ J Surg. 2002;72(4):265-70. Exclude non-U.S. data. [pmid: 11982512].
Farraye FA, Horton K, Hersey H, et al. Screening flexible sigmoidoscopy using an upper endoscope is better tolerated by women. Am J Gastroenterol. 2004;99(6):1074-80. Exclude falls outside Task Order scope. [pmid: 15180728].
Farrington SM, Lin-Goerke J, Ling J, et al. Systematic analysis of hMSH2 and hMLH1 in young colon cancer patients and controls. Am J Hum Genet. 1998;63(3):749-59. Exclude falls outside Task Order scope. [pmid: 9718327]. [pmcid: 1377385].
Fata F, Mirza A, Craig G, et al. Efficacy and toxicity of adjuvant chemotherapy in elderly patients with colon carcinoma: a 10-year experience of the Geisinger Medical Center. Cancer. 2002;94(7):1931-8. Exclude no explicit QM. [pmid: 11932894].
Fazio VW, Tekkis PP, Remzi F, et al. Assessment of operative risk in colorectal cancer surgery: the Cleveland Clinic Foundation colorectal cancer model. Dis Colon Rectum. 2004;47(12):2015-24. Exclude QOL. [pmid: 15657649].
Feliu J, Escudero P, Llosa F, et al. Capecitabine as first-line treatment for patients older than 70 years with metastatic colorectal cancer: an oncopaz cooperative group study. J Clin Oncol. 2005;23(13):3104-11. Exclude non-U.S. data. [pmid: 15860870].
Feliu J, Mel JR, Camps C, et al. Raltitrexed in the treatment of elderly patients with advanced colorectal cancer: an active and low toxicity regimen. Eur J Cancer. 2002;38(9):1204-11. Exclude non-U.S. data. [pmid: 12044507].
Fernandez E, La Vecchia C, D'Avanzo B, et al. Oral contraceptives, hormone replacement therapy and the risk of colorectal cancer. Br J Cancer. 1996;73(11):1431-5. Exclude non-U.S. data. [pmid: 8645593].
Fernandez E, Linares A, Alonso JL, et al. Colonoscopic findings in patients with lower gastrointestinal bleeding send to a hospital for their study. Value of clinical data in predicting normal or pathological findings. Rev Esp Enferm Dig. 1996;88(1):16-25. Exclude no explicit QM. [pmid: 8615995].
Ferraris R, Senore C, Fracchia M, et al. Predictive value of rectal bleeding for distal colonic neoplastic lesions in a screened population. Eur J Cancer. 2004;40(2):245-52. Exclude non-U.S. data. [pmid: 14728939].
Fielding LP, Arsenault PA, Chapuis PH, et al. Clinicopathological staging for colorectal cancer: an International Documentation System (IDS) and an International Comprehensive Anatomical Terminology (ICAT). J Gastroenterol Hepatol. 1991;6(4):325-44. Exclude non-U.S. data. [pmid: 1912440].
Finn-Faivre C, Maurel J, Benhamiche AM, et al. Evidence of improving survival of patients with rectal cancer in france: a population based study. Gut. 1999;44(3):377-81. Exclude non-U.S. data. [pmid: 10026324]. [pmcid: 1727407].
Fitzgerald SD, Longo WE, Daniel GL, et al. Advanced colorectal neoplasia in the high-risk elderly patient: is surgical resection justified?. Dis Colon Rectum. 1993;36(2):161-6. Exclude no explicit QM. [pmid: 8425420].
Fitzpatrick RJ. Closing the gap in trust: to refer out or not?. HMO Pract. 1997;11(3):137-8. Exclude review. [pmid: 10174524].
Fleming BB, Petzel RA. Performance Measurement Workgroup. Pitfalls of converting practice guidelines into quality measures. JAMA. 2004;292(11):1301-2. author reply 1302. Exclude review.
Fludger S, Turner AM, Harvey RF, et al. Controlled prospective study of faecal occult blood screening for colorectal cancer in Bury, black pudding capital of the world. BMJ. 2002;325(7378):1444-5. Exclude falls outside Task Order scope. [pmid: 12493657]. [pmcid: 139030].
Foley EF, Schoetz DJ Jr, Roberts PL, et al. Rediversion after ileal pouch-anal anastomosis. Causes of failures and predictors of subsequent pouch salvage. Dis Colon Rectum. 1995;38(8):793-8. Exclude falls outside Task Order scope. [pmid: 7634973].
Folkesson J, Nilsson J, Pahlman L, et al. The circular stapling device as a risk factor for anastomotic leakage. Colorectal Dis. 2004;6(4):275-9. Exclude non-U.S. data. [pmid: 15206973].
Folprecht G, Cunningham D, Ross P, et al. Efficacy of 5-fluorouracil-based chemotherapy in elderly patients with metastatic colorectal cancer: a pooled analysis of clinical trials. Ann Oncol. 2004;15(9):1330-8. Exclude non-U.S. data. [pmid: 15319237].
Fong Y, Blumgart LH, Fortner JG, et al. Pancreatic or liver resection for malignancy is safe and effective for the elderly. Ann Surg. 1995;222(4):426-34. discussion 434–7. Exclude survival only. [pmid: 7574924]. [pmcid: 1234870].
Fong Y, Fortner J, Sun RL, et al. Clinical score for predicting recurrence after hepatic resection for metastatic colorectal cancer: analysis of 1001 consecutive cases. Ann Surg. 1999;230(3):309-18. discussion 318–21. Exclude review. [pmid: 10493478]. [pmcid: 1420876].
Foutch PG, Mai H, Pardy K, et al. Flexible sigmoidoscopy may be ineffective for secondary prevention of colorectal cancer in asymptomatic, average-risk men. Dig Dis Sci. 1991;36(7):924-8. Exclude falls outside Task Order scope. [pmid: 2070706].
Freeman H. The Meaning of Race in Science-Considerations for Cancer Research. Cancer. 82(1):219-25. Exclude no explicit QM. [pmid: 9428500].
Freeman HP, Alshafie TA. Colorectal carcinoma in poor blacks. Cancer. 2002;94(9):2327-32. Exclude falls outside Task Order scope. [pmid: 12015756].
Frontin K. Colon cancer: update on treatment. Are outcome disparities real? Ethn Dis 2003;13(3 Suppl 3):S3–42–5. Exclude QOL.
Fu CG, Tominaga O, Nagawa H, et al. Role of p53 and p21/WAF1 detection in patient selection for preoperative radiotherapy in rectal cancer patients. Dis Colon Rectum. 1998;41(1):68-74. Exclude non-U.S. data. [pmid: 9510313].
Fujita S, Akasu T, Moriya Y. Resection of synchronous liver metastases from colorectal cancer. Jpn J Clin Oncol. 2000;30(1):7-11. Exclude non-U.S. data. [pmid: 10770561].
Funkhouser E, Cole P. Declining mortality rates for cancer of the rectum in the United States: 1940-1985. Cancer. 1992;70(11):2597-601. Exclude no explicit QM. [pmid: 1423187].
Gafa L, Amendola P, Dardanoni G, et al. Survival of patients with cancer of the stomach, colon and rectum, lung and breast in Ragusa, Sicily. Tumori. 1991;77(1):7-11. Exclude non-U.S. data. [pmid: 2017800].
Galandiuk S, Wieand HS, Moertel CG, et al. Patterns of recurrence after curative resection of carcinoma of the colon and rectum. Surg Gynecol Obstet. 1992;174(1):27-32. Exclude no explicit QM. [pmid: 1729745].
Garbus JE, Potenti F, Wexner SD. Current controversies in pouch surgery. South Med J. 2003;96(1):32-6. Exclude review. [pmid: 12602710].
Garcia-Granero E, Marti-Obiol R, Gomez-Barbadillo J, et al. Impact of surgeon organization and specialization in rectal cancer outcome. Colorectal Dis. 2001;3:179-84. Exclude non-U.S. data. [pmid: 12790986].
Gattellari M, Ward J, Solomon M. Implementing guidelines about colorectal cancer: a national survey of target groups. ANZ J Surg. 2001;71(3):147-53. Exclude non-U.S. data. [pmid: 11277143].
Gayowski TJ, Iwatsuki S, Madariaga JR, et al. Experience in hepatic resection for metastatic colorectal cancer: analysis of clinical and pathologic risk factors. Surgery. 1994;116(4):703-10. discussion 710–1. Exclude falls outside Task Order scope. [pmid: 7940169].
Gazelle GS, Hunink MG, Kuntz KM, et al. Cost-effectiveness of hepatic metastasectomy in patients with metastatic colorectal carcinoma: a state-transition Monte Carlo decision analysis. Ann Surg. 2003;237(4):544-55. Exclude falls outside Task Order scope. [pmid: 12677152]. [pmcid: 1514476].
Gazelle GS, McMahon PM, Scholz FJ. Screening for colorectal cancer. Radiology. 2000;215(2):327-35. Exclude review. [pmid: 10796903].
Gazzoli I, De Andreis C, Sirchia SM, et al. Molecular screening of families affected by familial adenomatous polyposis (FAP). J Med Screen. 1996;3(4):195-9. Exclude falls outside Task Order scope,. [pmid: 9041484].
Geddes M, Carli S, Ercolanelli M, et al. Colorectal, lung, and breast cancer care during the three years following the diagnosis: a population-based study. Tumori. 1996;82(3):210-4. Exclude non-U.S. data. [pmid: 8693594].
Gelfand DW. Colorectal cancer. Screening strategies. Radiol Clin North Am. 1997;35(2):431-8. Exclude review. [pmid: 9087212].
Giacomantonio CA, Temple WJ. Quality of cancer surgery: challenges and controversies. Surg Oncol Clin N Am 2000;9(1):51–60, vii. Exclude review.
Giardiello FM, Brensinger JD, Petersen GM. AGA technical review on hereditary colorectal cancer and genetic testing. Gastroenterology. 2001;121(1):198-213. Exclude falls outside Task Order scope. [pmid: 11438509].
Giardiello FM, Brensinger JD, Petersen GM, et al. The use and interpretation of commercial APC gene testing for familial adenomatous polyposis. N Engl J Med. 1997;336(12):823-7. Exclude falls outside Task Order scope. [pmid: 9062090].
Gibson M, Byrd C, Pierce C, et al. Laparoscopic colon resections: a five-year retrospective review. Am Surg. 2000;66(3):245-8. discussion 248–9. Exclude falls outside Task Order scope. [pmid: 10759193].
Gimbel MI, Paty PB. A current perspective on local excision of rectal cancer. Clin Colorectal Cancer. 2004;4(1):26-35. discussion 36–7. Exclude review. [pmid: 15207017].
Giridharan S, Vakkalanka B, Anwar MS, et al. Multicentre prospective audit of surgical outcomes and acute complications following short course pre-operative radiotherapy for resectable rectal cancer. Colorectal Dis. 2005;7(1):43-6. Exclude falls outside Task Order scope. [pmid: 15606583].
Glanz K, Grove J, Lerman C, et al. Correlates of intentions to obtain genetic counseling and colorectal cancer gene testing among at-risk relatives from three ethnic groups. Cancer Epidemiol Biomarkers Prev. 1999;8(4 Pt 2):329-36. Exclude falls outside Task Order scope. [pmid: 10207637].
Glaser F, Schlag P, Herfarth C. Endorectal sonography for the assessment of invasion of rectal tumors and lymph node involvement. Br J Surg. 1990;77:883-7. Exclude no explicit QM. [pmid: 2203508].
Glick SN, Ralls PW, Balfe DM, et al. Screening for colorectal cancer. American College of Radiology. ACR Appropriateness Criteria. Radiology 2000;215 Suppl(`231–7). Exclude review.
Glimelius B, Hoffma K, Fraf W, et al. Quality of Life during chemotherapy in patients with symptomatic advanced colorectal cancer. Cancer. 73(3):556-62. Exclude non-U.S. data. [pmid: 8299077].
Gluecker TM, Johnson CD, Harmsen WS, et al. Colorectal cancer screening with CT colonography, colonoscopy, and double-contrast barium enema examination: prospective assessment of patient perceptions and preferences. Radiology. 2003;227(2):378-84. Exclude falls outside Task Order scope. [pmid: 12732696].
Goel V. Appraising organised screening programmes for testing for genetic susceptibility to cancer. BMJ. 2001;322(7295):1174-8. Exclude no explicit QM. [pmid: 11348918]. [pmcid: 1120291].
Goldberg HI, Neighbor WE, Cheadle AD, et al. A controlled time-series trial of clinical reminders: using computerized firm systems to make quality improvement research a routine part of mainstream practice. Health Serv Res. 2000;34(7):1519-34. Exclude no explicit QM. [pmid: 10737451]. [pmcid: 1975658].
Goldschmidt J. The appropriate use of chemotherapy in older adults with colon cancer. J Am Med Dir Assoc. 2004;5(1):47-9. Exclude no data source validity or reliability testing. [pmid: 14706128].
Goldstein N. Lymph node recoveries from 2427 pT3 colorectal resection specimen spanning 45 years: recommendations for a minimum number of recovered lymph nodes based on predictive probabilities. Am J SurgPathol. 26(2):179-89. Exclude no explicit QM.
Gondal G, Grotmol T, Hofstad B, et al. Grading of distal colorectal adenomas as predictors for proximal colonic neoplasia and choice of endoscope in population screening: experience from the Norwegian Colorectal Cancer Prevention study (NORCCAP). Gut. 2003;52(3):398-403. Exclude non-U.S. data. [pmid: 12584223]. [pmcid: 1773542].
Gondal G, Grotmol T, Hofstad B, et al. The Norwegian Colorectal Cancer Prevention (NORCCAP) screening study: baseline findings and implementations for clinical work-up in age groups 50–64 years. Scand J Gastroenterol. 2003;38(6):635-42. Exclude non-U.S. data. [pmid: 12825872].
Gordon T, Bowman H, Bass E, et al. Complex gastrointestinal surgery: impact of provider experience on clinical and economic outcomes. J Am Coll Surg. 1999;189(1):46-56. Exclude falls outside Task Order scope. [pmid: 10401740].
Gosney M. Investigation and treatment of cancer in old age. Age Ageing. 1998;27(4):417-9. Exclude review. [pmid: 9883995].
Gowen GF. A new method of recording endoscopic and operative findings in colorectal neoplasia. Surg Endosc. 1992;6(5):239-43. . Exclude no explicit QM. [pmid: 1465731].
Graham RA, Wang S, Catalano PJ, et al. Postsurgical surveillance of colon cancer: preliminary cost analysis of physician examination, carcinoembryonic antigen testing, chest x-ray, and colonoscopy. Ann Surg. 1998;228(1):59-63. Exclude no explicit QM. [pmid: 9671067]. [pmcid: 1191428].
Grassi A, Casale V, Fracasso P, et al. Medium-large polyps of the colon: a contribution for their clinical profile and a proper surveillance. J Exp Clin Cancer Res. 1997;16(3):313-9. Exclude non-U.S. data. [pmid: 9387907].
Green AJ. Practice parameters for the management of colonic cancer I: surgical issues. Recommendations of the Colorectal Surgical Society of Australia: comment. Ann N Z J Surg. 2000;70(1):73-4. Exclude non-U.S. data.
Greene FL. Standard setting for laparoscopic resection of colorectal cancer. Surg Endosc. 2001;15(2):109. Exclude review. [pmid: 11285948].
Greene FL, Stewart AK, Norton HJ. A new TNM staging strategy for node-positive (stage III) colon cancer: an analysis of 50,042 patients. Ann Surg. 2002;236(4):416-21. discussion 421. Exclude no explicit QM. [pmid: 12368669]. [pmcid: 1422595].
Greff M. Colorectal cancer screening in France: guidelines and professional reality. Endocsopy. 1999;31(6):471. Exclude non-U.S. data.
Griffin PM, Liff JM, Greenberg RS, et al. Adenocarcinomas of the colon and rectum in persons under 40 years old. A population-based study. Gastroenterology. 1991;100(4):1033-40. Exclude no explicit QM. [pmid: 2001800].
Grilli R, Apolone G, Marsoni S, et al. The impact of patient management guidelines on the care of breast, colorectal, and ovarian cancer patients in Italy. Med Care. 1991;29(1):50-63. Exclude non-U.S. data. [pmid: 1986177].
Guadagnoli E, Weitberg A, Mor V, et al. The influence of patient age on the diagnosis and treatment of lung and colorectal cancer. Arch Intern Med. 1990;150(7):1485-90. Exclude no explicit QM. [pmid: 2164363].
Guest JF, Ruiz FJ, Tang R, et al. Cost implications of post-surgical morbidity following blood transfusion in cancer patients undergoing elective colorectal resection: an evaluation in the US hospital setting. Curr Med Res Opin. 2005;21(3):447-55. Exclude falls outside Task Order scope. [pmid: 15811214].
Gunderson LL, Sargent DJ, Tepper JE, et al. Impact of T and N stage and treatment on survival and relapse in adjuvant rectal cancer: a pooled analysis. J Clin Oncol. 2004;22(10):1785-96. Exclude review. [pmid: 15067027].
Gunnarsson U. Quality assurance in surgical oncology. Colorectal cancer as an example. Eur J Surg Oncol. 2003;29(1):89-94. Exclude non-U.S. data. [pmid: 12559084].
Gunnarsson U, Seligsohn E, Jestin P, et al. Registration and validity of surgical complications in colorectal cancer surgery. Br J Surg. 2003;90(4):454-9. Exclude non-U.S. data. [pmid: 12673748].
Gunter Ollenschlager. Indicators and Guidelines: Companions on the Quality Path. Presented at the Joint CoE/ESQH/G-I-N Workship. Krakow, April 9, 2003. Available at: http://www.aezq.de/aezq/kooperationspartner_en/pdf/foginindicatorkakau090403go.pdf. Accessed: May 9, 2005. Exclude review.
Gunther K, Radkow T, Reymond MA, et al. Angiogenesis and dendritic cell density are not correlated with metachronous distant metastasis in curatively operated rectal cancer. Int J Colorectal Dis. 2003;18(4):300-8. Exclude no explicit QM. [pmid: 12774244].
Gupta AK, Melton LJ 3rd, Petersen GM, et al. Changing trends in the incidence, stage, survival, and screen-detection of colorectal cancer: a population-based study. Clin Gastroenterol Hepatol. 2005;3(2):150-8. Exclude no explicit QM. [pmid: 15704049].
Gupta D, Lammersfeld CA, Burrows JL, et al. Bioelectrical impedance phase angle in clinical practice: implications for prognosis in advanced colorectal cancer. Am J Clin Nutr. 2004;80(6):1634-8. Exclude falls outside Task Order scope. [pmid: 15585779].
Gupta D, Lammersfeld CA, Vashi PG, et al. Prognostic significance of Subjective Global Assessment (SGA) in advanced colorectal cancer. Eur J Clin Nutr. 2005;59(1):35-40. Exclude QOL. [pmid: 15252422].
Gyrd-Hansen D, Sogaard J, Kronborg O. Colorectal cancer screening: efficiency and effectiveness. Health Econ. 1998;7(1):9-20. Exclude falls outside Task Order scope. [pmid: 9541080].
Haidet P, Hamel MB, Davis RB, et al. Outcomes, preferences for resuscitation, and physician-patient communication among patients with metastatic colorectal cancer. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. Am J Med. 1998;105(3):222-9. Exclude falls outside Task Order scope. [pmid: 9753025].
Halasz n. Letters to the Editor. Ann Surg. 1999;229(3):443. Exclude review. [pmid: 10077060].
Hall HI, Van Den Eeden SK, Tolsma DD, et al. Testing for prostate and colorectal cancer: comparison of self-report and medical record audit. Prev Med. 2004;39(1):27-35. Exclude falls outside Task Order scope. [pmid: 15207983].
Hanauer SB. Surveying surveillance: are gastroenterologists consistently inconsistent, inconsistently consistent, or poorly educated?. Gastrointest Endosc. 2000;51(2):240-2. Exclude non-U.S. data. [pmid: 10650283].
Harewood GC, Lieberman DA. Prevalence of advanced neoplasia at screening colonoscopy in men in private practice versus academic and Veterans Affairs medical centers. Am J Gastroenterol. 2003;98(10):2312-6. Exclude falls outside Task Order scope. [pmid: 14572585].
Harriss DR, Blake JR. Computerised audit for colorectal cancer. Ann R Coll Surg Engl. 1993;75(4):268-71. Exclude non-U.S. data. [pmid: 8379631]. [pmcid: 2497933].
Hart AR, Barone TL, Gay SP, et al. The effect on compliance of a health education leaflet in colorectal cancer screening in general practice in central England. J Epidemiol Community Health. 1997;51(2):187-91. Exclude non-U.S. data. [pmid: 9196650]. [pmcid: 1060443].
Hart AR, Barone TL, Mayberry JF. Increasing compliance with colorectal cancer screening: the development of effective health education. Health Educ Res. 1997;12(2):171-80. Exclude falls outside Task Order scope. [pmid: 10168571].
Hart AR, Jestico B, Antill C, et al. Blood donor centres can effectively publicise cancer screening. Public Health. 1996;110(4):247-9. Exclude falls outside Task Order scope. [pmid: 8757707].
Harvey EH, Young MR, Flanigan TL, et al. Complications are increased with the need for an abdominal-assisted Kraske procedure. Am Surg. 2004;70(3):193-6. discussion 197. Exclude falls outside Task Order scope. [pmid: 15055840].
Hasson MA, Fagerstrom RM, Kahane DC, et al. Design and evolution of the data management systems in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control Clin Trials. 2000;21(6 Suppl):329S-48S. Exclude falls outside Task Order scope. [pmid: 11189686].
Hatzell TA, Ricketts TC, Tropman SE, et al. Rural physicians' understanding of the state-of-the-art in breast, colon and rectum cancer treatment. Cancer Causes Control. 1999;10(4):261-7. Exclude no explicit QM. [pmid: 10482484].
Havranek E, Steiner J. Valuation of Health States in the US versus the UK: Two Measures Divided by a Common Language. Med Care. 2005;43(3):201-2. Exclude review. [pmid: 15725976].
Hawley ST, Foxhall L, Vernon SW, et al. Colorectal cancer screening by primary care physicians in Texas: a rural-urban comparison. J Cancer Educ. 2001;16(4):199-204. Exclude falls outside Task Order scope. [pmid: 11848667].
Hawley ST, Levin B, Vernon SW. Colorectal cancer screening by primary care physicians in two medical care organizations. Cancer Detect Prev. 2001;25(3):309-18. Exclude falls outside Task Order scope. [pmid: 11425273].
Hawley ST, Vernon SW, Levin B, et al. Prevalence of colorectal cancer screening in a large medical organization. Cancer Epidemiol Biomarkers Prev. 2004;13(2):314-9. Exclude falls outside Task Order scope. [pmid: 14973108].
Hayes RB, Smith CO, Huang WY, et al. Whole blood cryopreservation in epidemiological studies. Cancer Epidemiol Biomarkers Prev. 2002;11(11):1496-8. Exclude falls outside Task Order scope. [pmid: 12433734].
Heald RJ, Moran BJ, Ryall RD, et al. Rectal cancer: the Basingstoke experience of total mesorectal excision, 1978-1997. Arch Surg. 1998;133:894-9. Exclude non-U.S. data. [pmid: 9711965].
Hefferman N, Cella D, Webster K, et al. Measuring Health Related Quality of Life in Patients with Hepatobiliary Cancers: The Functional Assessment of Cancer Therapy-Hepatobiliary Questionnaire. J Clin Oncol. 2002;20(9):2229-39. Exclude no explicit QM. [pmid: 11980994].
Heldenberg E, Vishne TH, Onaka N, et al. Rectal cancer: the impact of a colorectal unit on the preservation of the anal sphincter. Isr Med Assoc J. 2004;6(8):471-3. Exclude non-U.S. data. [pmid: 15326826].
Hellinger M. Colon and Rectal Cancer. American Society of Colon and Rectal Surgeons. Available at : http://www.fascrs.org/displaycommon.cfm?an=1&subarticlenbr=109. Accessed Feburary 8, 2005. Exclude review.
Hemingway D. A novel indicator for surveillance colonoscopy following colorectal cancer resection. Colorectal Dis. 2003;5(3):270. author reply 271. Exclude non-U.S. data.
Hemmings C, Jeffery M, Frizelle F. Changes in the pathology reporting of rectal cancer: is it time to adopt synoptic reporting. N Z Med J. 2003;116(1178):U513. Exclude non-U.S. data. [pmid: 12897881].
Hendryx MS. The impact of cancer screening promotion by rural hospitals on cancer detection. Med Care. 1993;31(6):488-97. Exclude falls outside Task Order scope. [pmid: 8501996].
Hermanek P. Impact of surgeon's technique on outcome after treatment of rectal carcinoma. Dis Colon Rectum. 1999;42(5):559-62. Exclude non-U.S. data. [pmid: 10344676].
Hermanek P, Hermanek P, Hohenberger W, et al. The pathological assessment of mesorectal excision: implications for further treatment and quality management. Int J Colorectal Dis. 2003;18(4):335-41. Exclude non-U.S. data. [pmid: 12774249].
Hermanek P, Hohenberger W. The importance of volume in colorectal cancer surgery. Eur J Surg Oncol. 1996;22(3):213-5. Exclude non-U.S. data. [pmid: 8654598].
Hermanek P, Mansmann U, Staimmer DS, et al. The German experience: the surgeon as a prognostic factor in colon and rectal cancer surgery. Surg Oncol Clin N Am 2000;9(1):33–49, vi. Exclude non-U.S. data.
Hermanek P, Wiebelt H, Staimmer D, et al. Prognostic factors of rectum carcinoma--experience of the German Multicentre Study SGCRC. German Study Group Colo-Rectal Carcinoma. Tumori. 1995;81(3 Suppl):60-4. Exclude non-U.S. data. [pmid: 7571056].
Hiatt RA, Klabunde C, Breen N, et al. Cancer screening practices from National Health Interview Surveys: past, present, and future. J Natl Cancer Inst. 2002;94(24):1837-46. Exclude falls outside Task Order scope. [pmid: 12488477].
Hida J, Yoshifuji T, Tokoro T, et al. Long-term functional outcome of low anterior resection with colonic J-pouch reconstruction for rectal cancer in the elderly. Dis Colon Rectum. 2004;47(9):1448-54. Exclude non-U.S. data. [pmid: 15486740].
Hill GJ, Hill HZ. Four-way test of mortality: a useful tool for cancer education. J Cancer Educ. 2001;16(4):185-7. Exclude no explicit QM. [pmid: 11848664].
Hillner B, Smith T, Desch C. Hospital and Physician Volume or Specialization and Outcomes in Cancer Treatment: Importance in Quality of Cancer Care. J Clin Oncol. 2000;18(11):2327-40. Exclude no explicit QM. [pmid: 10829054].
Hippisley-Cox J, Hardy C, Pringle M, et al. Are patients who present late with cancer registered with low referring practices?. Br J Gen Pract. 1997;47(424):731-2. Exclude non-U.S. data. [pmid: 9519522]. [pmcid: 1409950].
Hixson LJ, Fennerty MB, Sampliner RE, et al. Prospective study of the frequency and size distribution of polyps missed by colonoscopy. J Natl Cancer Inst. 1990;82(22):1769-72. Exclude no explicit QM. [pmid: 2231773].
Hocht S. Evaluating toxicity in neoadjuvant radio-chemotherapy of rectal cancer. Int J Colorectal Dis. 2003;18(6):500-2. Exclude non-U.S. data. [pmid: 14517687].
Hodgson DC, Fuchs CS, Ayanian JZ. Impact of patient and provider characteristics on the treatment and outcomes of colorectal cancer. J Natl Cancer Inst. 2001;93(7):501-15. Exclude review. [pmid: 11287444].
Hoff G, Blanchard J, Crespi M, et al. Public Awareness and Lobbying: Group 3 Report. ESGE/UEGF Colorectal Cancer--Public Awareness Campaign. The Public/Professional Interface Workshop: Oslo, Norway, June 20 - 22, 2003. Endocsopy. 2004;36(4):359-61. Exclude non-U.S. data.
Hoff G, Sauar J, Vatn MH, et al. Polypectomy of adenomas in the prevention of colorectal cancer: 10 years' follow-up of the Telemark Polyp Study I. A prospective, controlled population study. Scand J Gastroenterol. 1996;31(10):1006-10. Exclude non-U.S. data. [pmid: 8898422].
Hoffmann D, Moore J, Roder D. Trends in survival from colonic cancer: the impact of subspecialization. Ann N Z J Surg. 1997;67(12):842-5. Exclude non-U.S. data.
Holm T, Johansson H, Cedermark B, et al. Influence of Hospital and Surgeon-related factors on outcome after treatment of rectal cancer with or without preoperative radiotherapy. Br J Surg. 1997;84(5):657-63. Exclude non-U.S. data. [pmid: 9171755].
Holman JR, Marshall RC, Jordan B, et al. Technical competency in flexible sigmoidoscopy. J Am Board Fam Pract. 2001;14(6):424-9. Exclude falls outside Task Order scope. [pmid: 11757884].
Hopper W, Kyker KA, Rodney WM. Colonoscopy by a family physician: a 9-year experience of 1048 procedures. J Fam Pract. 1996;43(6):561-6. Exclude falls outside Task Order scope. [pmid: 8969704].
Houry S, Amenabar J, Rezvani A, et al. Should patients over 80 years old be operated on for colorectal or gastric cancer?. Hepatogastroenterology. 1994;41(6):521-5. Exclude non-U.S. data. [pmid: 7536703].
Hristova L, Hakama M. Effect of screening for cancer in the Nordic countries on deaths, cost and quality of life up to the year 2017. Acta Oncol. 1997;36(Suppl 9):1-60. Exclude non-U.S. data.
Hundahl SA. Surgical quality in trials of adjuvant cancer therapy. J Surg Oncol. 2002;80(4):177-80. Exclude review. [pmid: 12210030].
Hunt LM, Rooney PS, Hardcastle JD, et al. Endoscopic screening of relatives of patients with colorectal cancer. Gut. 1998;42(1):71-5. Exclude no explicit QM. [pmid: 9505888]. [pmcid: 1726961].
Isbister WH. Colorectal surgery in the elderly: an audit of surgery in octogenarians. Ann N Z J Surg. 1997;67(8):557-61. Exclude non-U.S. data.
Isbister WH. Audit of definitive colorectal surgery in patients with early and advanced colorectal cancer. ANZ J Surg. 2002;72(4):271-4. Exclude non-U.S. data. [pmid: 11982513].
Isenberg G. Differences in the diagnostic criteria used by Japanese and Western pathologists to diagnose colorectal carcinoma. Gastrointest Endosc. 1999;50(3):446-7. discussion 447–8. Exclude non-U.S. data. [pmid: 10515720].
Isenring E, Bauer J, Capra S. The scored Patient-generated Subjective Global Assessment (PG-SGA) and its association with quality of life in ambulatory patients receiving radiotherapy. Eur J Clin Nutr. 2003;57(2):305-9. Exclude non-U.S. data. [pmid: 12571664].
Iversen LH, Thomsen GH, Thorlacius-Ussing O. Systemic coagulation activation and anastomotic leakage after colorectal cancer surgery. Dis Colon Rectum. 1999;42(1):56-65. Exclude non-U.S. data. [pmid: 10211521].
Iwama T, Mishima Y. Factors affecting the risk of rectal cancer following rectum-preserving surgery in patients with familial adenomatous polyposis. Dis Colon Rectum. 1994;37(10):1024-6. Exclude non-U.S. data. [pmid: 7924709].
Izbicki JR, Hosch SB, Knoefel WT, et al. Extended resections are beneficial for patients with locally advanced colorectal cancer. Dis Colon Rectum. 1995;38(12):1251-6. Exclude non-U.S. data. [pmid: 7497835].
Jackson C. Colorectal cancer screening--what the guidelines don't tell you. Aust Fam Physician. 2001;30(1):8. Exclude review. [pmid: 11211721].
Jacobs LA. Health beliefs of first-degree relatives of individuals with colorectal cancer and participation in health maintenance visits: a population-based survey. Cancer Nurs. 2002;25(4):251-65. Exclude wrong population. [pmid: 12181494].
James AS, Campbell MK, Hudson MA. Perceived barriers and benefits to colon cancer screening among African Americans in North Carolina: how does perception relate to screening behavior?. Cancer Epidemiol Biomarkers Prev. 2002;11(6):529-34. Exclude falls outside Task Order scope. [pmid: 12050093].
James DS, Bull AD. Information on death certificates: cause for concern?. J Clin Pathol. 1996;49(3):213-6. Exclude non-U.S. data. [pmid: 8675731]. [pmcid: 500400].
Janda M, Hughes K, Tong S, et al. Faecal occult blood test: current practice in a rural Queensland community. Aust J Rural Health. 2002;10(1):57-64. Exclude non-U.S. data. [pmid: 11952524].
Jass J.R. Prognostic factors in rectal cancer. Eur J Cancer. 1995;31A(6):862-3. Exclude non-U.S. data. [pmid: 7646911].
Jemal A, Murray T, Ward E, et al. Cancer statistics, 2005. CA Cancer J Clin. 2005;55(1):10-30. Exclude review. [pmid: 15661684].
Jenkins PJ, Fairclough PD, Richards T, et al. Acromegaly, colonic polyps and carcinoma. Clin Endocrinol (Oxf). 1997;47(1):17-22. Exclude no explicit QM. [pmid: 9302367].
Jepson R, Clegg A, Forbes C, et al. The determinants of screening uptake and interventions for increasing uptake: a systematic review. Health Technol Asses 2000;4(14):i–vii, 1–133. Exclude review.
Jess P, Christiansen J, Bech P. Quality of life after anterior resection versus abdominoperineal extirpation for rectal cancer. Scand J Gastroenterol. 2002;37(10):1201-4. Exclude non-U.S. data. [pmid: 12408526].
Jiwa M, Burr J. GP letter writing in colorectal cancer: a qualitative study. Curr Med Res Opin. 2002;18(6):342-6. Exclude non-U.S. data. [pmid: 12442881].
Jiwa M, Drury D, Hunt L. Improving the outcome in colorectal cases. Br J Gen Pract. 2002;52(477):329-30. Exclude non-U.S. data.
Johnson BA. Flexible sigmoidoscopy: screening for colorectal cancer. [republished in Am Fam Physician. 1999 Mar 15;59(6):1537–46; PMID: 10193595]. Am Fam Physician 1999;59(2):313–24, 327–8. Exclude falls outside Task Order scope.
Johnson FE, Longo WE, Vernava AM, et al. How tumor stage affects surgeons' surveillance strategies after colon cancer surgery. Cancer. 1995;76(8):1325-9. Exclude no explicit QM. [pmid: 8620404].
Johnson FE, McKirgan LW, Coplin MA, et al. Geographic variation in patient surveillance after colon cancer surgery. J Clin Oncol. 1996;14(1):183-7. Exclude falls outside Task Order scope. [pmid: 8558196].
Johnson FE, Novell LA, Coplin MA, et al. How practice patterns in colon cancer patient follow-up are affected by surgeon age. Surg Oncol. 1996;5(3):127-31. Exclude no explicit QM. [pmid: 8908718].
Johnson J, Luo N, Shar J, et al. Valuations of EQ-5D Health States: Are the United States and United Kingdon Different. Med Care. 2005;43(3):221-8. Exclude QOL. [pmid: 15725978].
Johnson KA, Trimbath JD, Petersen GM, et al. Impact of genetic counseling and testing on colorectal cancer screening behavior. Genet Test. 2002;6(4):303-6. Exclude falls outside Task Order scope. [pmid: 12537654].
Joint Test and Technology Transfer Committee Working Group ACoMG9RPBMD 20814–3998, United States. Genetic testing for colon cancer: joint statement of the American College of Medical Genetics and American Society of Human Genetics. Joint Test and Technology Transfer Committee Working Group. Genet Med 2000;2(6):362–6. Exclude falls outside Task Order scope.
Jonker DJ, Maroun JA, Kocha W. Survival benefit of chemotherapy in metastatic colorectal cancer: a meta-analysis of randomized controlled trials. Br J Cancer. 2000;82(11):1789-94. Exclude non-U.S. data. [pmid: 10839292].
Jorge JM, Wexner SD, James K, et al. Recovery of anal sphincter function after the ileoanal reservoir procedure in patients over the age of fifty. Dis Colon Rectum. 1994;37(10):1002-5. Exclude falls outside Task Order scope. [pmid: 7924704].
Joshi AV, Miller LA. Hospital procedure volume and outcomes. Ann Intern Med. 2004;140(12):1061-2. author reply 1062. Exclude no explicit QM.
Jouret-Mourin A. Working Party fo G.I. Cancer. Recommendations for pathological examination and reporting for colorectal cancer. Belgian consensus. Acta Gastroenterol Belg. 2004;67(1):40-5. Exclude non-U.S. data. [pmid: 15149085].
Kaiser AM, Nunoo-Mensah JW, Wasserberg N. Re: Surgical volume and long-term survival following surgery for colorectal cancer in the Veterans Affairs Health-Care System. Am J Gastroenterol. 2005;100(1):250. Exclude falls outside Task Order scope.
Kapiteijn E, van De Velde CJ. European trials with total mesorectal excision. Semin Surg Oncol. 2000;19(4):350-7. Exclude non-U.S. data. [pmid: 11241917].
Kashtan H, Papa MZ, Stern HS. Is age an independent variable in the morbidity and mortality of patients with colorectal cancer? A prospective study. Can J Surg. 1991;34(4):374-6. Exclude non-U.S. data. [pmid: 1868395].
Kashtan H, Werbin N, Wasserman I, et al. Colorectal cancer in patients over 70 years old. A prospective study of operative results. Isr J Med Sci. 1992;28(12):861-4. Exclude non-U.S. data. [pmid: 1286956].
Kato I, Tominaga S, Ikari A. The role of socioeconomic factors in the survival of patients with gastrointestinal cancers. Jpn J Clin Oncol. 1992;22(4):270-7. Exclude non-U.S. data. [pmid: 1434026].
Kavadas V, Blazeby JM, Conroy T, et al. Development of an EORTC disease-specific quality of life questionnaire for use in patients with liver metastases from colorectal cancer. Eur J Cancer. 2003;39(9):1259-63. Exclude non-U.S. data. [pmid: 12763214].
Kaye JA, Shulman LN. Screening program for colorectal cancer: effect on stage distribution. HMO Pract. 1992;6(3):13-5. Exclude falls outside Task Order scope.
Keating J, Lolohea S, Kenwright D. Pathology reporting of rectal cancer: a national audit. N Z Med J. 2003;116(1178):U514. Exclude non-U.S. data. [pmid: 12897882].
Kee F, Wilson RH, Harper C, et al. Influence of hospital and clinician workload on survival from colorectal cancer: cohort study. BMJ. 1999;318(7195):1381-5. Exclude non-U.S. data. [pmid: 10334746]. [pmcid: 27880].
Kerr J, Engel J, Schlesinger-Raab A, et al. Doctor-patient communication: results of a four-year prospective study in rectal cancer patients. Dis Colon Rectum. 2003;46(8):1038-46. Exclude non-U.S. data. [pmid: 12907897].
Kewenter J, Brevinge H. Endoscopic and surgical complications of work-up in screening for colorectal cancer. Dis Colon Rectum. 1996;39(6):676-80. Exclude non-U.S. data. [pmid: 8646956].
Khuri S, Daley J, Henderson W, et al. Relation of Surgical Volume to Outcome in Eight Common Operations. results from the VA National Surgical Quality Improvement Program. Ann Surg. 1999;230(3):414-32. Exclude falls outside Task Order scope. [pmid: 10493488]. [pmcid: 1420886].
Khuri SF, Daley J, Henderson W, et al. The National Veterans Administration Surgical Risk Study: risk adjustment for the comparative assessment of the quality of surgical care. J Am Coll Surg. 1995;180(5):519-31. Exclude falls outside Task Order scope. [pmid: 7749526].
Kievit J. Colorectal cancer follow-up: a reassessment of empirical evidence on effectiveness. Eur J Surg Oncol. 2000;26(4):322-8. Exclude non-U.S. data. [pmid: 10873350].
Kievit J, Bruinvels DJ. Detection of recurrence after surgery for colorectal cancer. Eur J Cancer. 1995;31A(78):1222-5. Exclude non-U.S. data. [pmid: 7577026].
Kievit J, van de Velde CJ. Utility and cost of carcinoembryonic antigen monitoring in colon cancer follow-up evaluation. A Markov analysis. Cancer. 1990;65(11):2580-7. Exclude falls outside Task Order scope. [pmid: 2337875].
Killingback M, Barron P, Dent O. Elective resection and anastomosis for colorectal cancer: a prospective audit of mortality and morbidity 1976-1998. ANZ J Surg. 2002;72(10):689-98. Exclude non-U.S. data. [pmid: 12534376].
Kim SP, Feinglass J, Bennett CL, et al. Merging claims databases with a tumor registry to evaluate variations in cancer mortality: results from a pilot study of 698 colorectal cancer patients treated at one hospital in the 1990s. Cancer Invest. 2004;22(2):225-33. Exclude survival only. [pmid: 15199605].
Kingston RD, Jeacock J, Walsh S, et al. The outcome of surgery for colorectal cancer in the elderly: a 12-year review from the Trafford Database. Eur J Surg Oncol. 1995;21(5):514-6. Exclude non-U.S. data. [pmid: 7589596].
Kiran PR, Glass RE. Duration of symptoms and spread of colorectal cancer: a short history does not mean early disease. Ann R Coll Surg Engl. 2002;84(6):381-5. Exclude non-U.S. data. [pmid: 12484575].
Kjeldsen BJ, Thorsen H, Whalley D, et al. Influence of follow-up on health-related quality of life after radical surgery for colorectal cancer. Scand J Gastroenterol. 1999;34(5):509-15. Exclude non-U.S. data. [pmid: 10423068].
Klein EE, Purdy JA. Quality assurance and dosimetric evaluation for an endocavitary unit. Med Dosim. 1994;19(3):151-8. Exclude data sources. [pmid: 7818755].
Klein Kranenbarg E, van de Velde CJ. Surgical trials in oncology. the importance of quality control in the TME trial. Eur J Cancer. 2002;38(7):937-42. Exclude non-U.S. data. [pmid: 11978518].
Klimberg VS, Langston JD, Maners A, et al. Advantages of the Papillon protocol in the preoperative treatment of rectal carcinoma. Am J Surg. 1992;164(5):433-5. discussion 436. Exclude no explicit QM. [pmid: 1443366].
Kluger Y, Shiloni E, Jurim O, et al. Subtotal colectomy with primary ileocolonic anastomosis for obstructing carcinoma of the left colon: valid option for elderly high risk patients. Isr J Med Sci. 1993;29(11):726-30. Exclude non-U.S. data. [pmid: 8270407].
Kluka S, Kristjanson LJ. Development and testing of the ostomy concerns scale: measuring ostomy-related concerns of cancer patients and their partners. J Wound Ostomy Continence Nurs. 1996;23(3):166-70. Exclude non-U.S. data. [pmid: 8845906].
Ko CW, Kreuter W, Baldwin LM. Effect of Medicare coverage on use of invasive colorectal cancer screening tests. Arch Intern Med. 2002;162(22):2581-6. Exclude wrong population. [pmid: 12456230].
Knopf KB, Warren JL, Feuer EJ, et al. Bowel surveillance patterns after a diagnosis of colorectal cancer in Medicare beneficiaries. Gastrointest Endosc. 2001;54(5):563-71. Exclude results combined across modalities. [pmid: 11677471].
Ko CY, Maggard M, Livingston EH. Evaluating health utility in patients with melanoma, breast cancer, colon cancer, and lung cancer: a nationwide, population-based assessment. J Surg Res. 2003;114(1):1-5. Exclude QOL. [pmid: 13678691].
Ko CY, Rusin LC, Schoetz DJ Jr, et al. Does better functional result equate with better quality of life? Implications for surgical treatment in familial adenomatous polyposis. Dis Colon Rectum. 2000;43(6):829-35. discussion 835–7. Exclude falls outside Task Order scope. [pmid: 10859085].
Koka VK, Potti A, Fraiman GN, et al. An epidemiological study evaluating the relationship of distance from a tertiary care cancer center to early detection of colorectal carcinoma. Anticancer Res. 2002;22(4):2481-3. Exclude falls outside Task Order scope.
Kopp I, Bauhofer A, Koller M. Understanding quality of life in patients with colorectal cancer: comparison of data from a randomised controlled trial, a population based cohort study and the norm reference population. Inflamm Res 2004;53 Suppl 2(S130–5). Exclude non-U.S. data.
Kopp I, Lorenz W, Rothmund M, et al. Relation between severe illness and non-completion of quality-of-life questionnaires by patients with rectal cancer. J R Soc Med. 2003;96(9):442-8. Exclude non-U.S. data. [pmid: 12949200]. [pmcid: 539599].
Kotake K, Honjo S, Sugihara K, et al. Changes in colorectal cancer during a 20-year period: an extended report from the multi-institutional registry of large bowel cancer, Japan. [erratum appears in Dis Colon Rectum. 2004 Jun;47(6):951]. Dis Colon Rectum. 2003;46(10 Suppl):S32-43. Exclude non-U.S. data. [pmid: 14530656].
Krieger N. Overcoming the Absence of Socioeconomic Data in Medical Records: Validation and Application of a Census-Based Methodology. Am J Public Health. 1992;82(5):703-10. Exclude falls outside Task Order scope. [pmid: 1566949]. [pmcid: 1694121].
Kronborg O, Fenger C, Olsen J, et al. Randomised study of screening for colorectal cancer with faecal-occult-blood test. Lancet. 1996;348(9040):1467-71. Exclude non-U.S. data. [pmid: 8942774].
Kuhfahl J, Steinbrecher C, Wagner T, et al. Second-line treatment of advanced colorectal cancer with a weekly simultaneous 24-hour infusion of 5-fluorouracil and sodium-folinate: a multicentre phase II trial. Onkologie. 2004;27(5):449-54. Exclude falls outside Task Order scope. [pmid: 15585974].
Kurtz ME, Kurtz JC, Stommel M, et al. The influence of symptoms, age, comorbidity and cancer site on physical functioning and mental health of geriatric women patients. Women Health. 1999;29(3):1-12. Exclude falls outside Task Order scope.
Kutner JS, Vu KO, Prindiville SA, et al. Patient age and cancer treatment decisions. Patient and physician views. Cancer Pract. 2000;8(3):114-9. Exclude no explicit QM. [pmid: 11898135].
Labianca R, Pancera G, Luporini G. Factors influencing response rates for advanced colorectal cancer chemotherapy. Ann Oncol. 1996;7(9):901-6. Exclude no explicit QM. [pmid: 9006739].
Lackan NA, Ostir GV, Freeman JL, et al. Hospice use by Hispanic and non-Hispanic white cancer decedents. Health Serv Res. 2004;39(4 Pt 1):969-83. Exclude falls outside Task Order scope. [pmid: 15230937]. [pmcid: 1361047].
Lambert LA, Colacchio TA, Barth RJ Jr. Interval hepatic resection of colorectal metastases improves patient selection. Arch Surg. 2000;135(4):473-9. discussion 479–80. Exclude no explicit QM. [pmid: 10768715].
Landheer ML, Therasse P, van de Velde CJ. The importance of quality assurance in surgical oncology in the treatment of colorectal cancer. Surg Oncol Clin N Am 2001;10(4):885–914, x. Exclude non-U.S. data.
Launoy G, Le Coutour X, Gignoux M, et al. Influence of rural environment on diagnosis, treatment, and prognosis of colorectal cancer. J Epidemiol Community Health. 1992;46(4):365-7. Exclude non-U.S. data. [pmid: 1431708]. [pmcid: 1059601].
Law WL, Chan WF, Lee YM, et al. Non-curative surgery for colorectal cancer: critical appraisal of outcomes. Int J Colorectal Dis. 2004;19(3):197-202. Exclude non-U.S. data. [pmid: 14618348].
Laxamana A, Solomon MJ, Cohen Z, et al. Long-term results of anterior resection using the double-stapling technique. Dis Colon Rectum. 1995;38(12):1246-50. Exclude non-U.S. data. [pmid: 7497834].
Lee AJ, Baker CS, Gehlbach S, et al. Do black elderly Medicare patients receive fewer services? An analysis of procedure use for selected patient conditions. Med Care Res Rev. 1998;55(3):314-33. Exclude time period not specified. [pmid: 9727301].
Lee FY, Chu W, Chan R, et al. Incidence of deep vein thrombosis after colorectal surgery in a Chinese population. ANZ J Surg. 2001;71(11):637-40. Exclude non-U.S. data. [pmid: 11736821].
Lee JY, Soong SJ. Cancer mortality in the South, 1950 to 1980. South Med J. 1990;83(2):185-90. Exclude falls outside Task Order scope. [pmid: 2305299].
Lee PY, Fletcher WS, Sullivan ES, et al. Colorectal cancer in young patients: characteristics and outcome. Am Surg. 1994;60(8):607-12. Exclude falls outside Task Order scope. [pmid: 8030817].
Leighl NB, Butow PN, Tattersall MH. Treatment decision aids in advanced cancer: when the goal is not cure and the answer is not clear. J Clin Oncol. 2004;22(9):1759-62. Exclude no explicit QM. [pmid: 15118002].
Leo E, Audisio RA, Belli F, et al. Total rectal resection and colo-anal anastomosis for low rectal tumours: comparative results in a group of young and old patients. Eur J Cancer. 1994;30A(8):1092-5. Exclude non-U.S. data. [pmid: 7654436].
Lev R, Healey J. Colon polyp registries and colorectal cancer control. Cancer Detect Prev. 1999;23(6):474-8. Exclude no explicit QM. [pmid: 10571657].
Levin B, Smith RA, Feldman GE, et al. Promoting early detection tests for colorectal carcinoma and adenomatous polyps: a framework for action: the strategic plan of the National Colorectal Cancer Roundtable. [erratum appears in Cancer 2002 Dec 15;95(12):2580]. Cancer. 2002;95(8):1618-28. Exclude review. [pmid: 12365008].
Levin T, Palitz A. Flexible sigmoindoscopy: An important screening option for average-risk individuals. Gastrointest Endosc Clin N Am. 2002;12(1):23-40. Exclude no explicit QM. [pmid: 11916159].
Levin TR, Farraye FA, Schoen RE, et al. Quality in the technical performance of screening flexible sigmoidoscopy: recommendations of an international multi-society task group. Gut. 2005;54(6):807-13. Exclude no explicit QM. [pmid: 15888789]. [pmcid: 1774519].
Lewis JD, Ginsberg GG, Hoops TC, et al. Flexible sigmoidoscopy training and its impact on colorectal cancer screening by primary care physicians. Arch Fam Med. 2000;9(5):420-5. Exclude falls outside Task Order scope. [pmid: 10810946].
Liang JT, Huang KC, Cheng AL, et al. Clinicopathological and molecular biological features of colorectal cancer in patients less than 40 years of age. Br J Surg. 2003;90(2):205-14. Exclude non-U.S. data. [pmid: 12555297].
Lieberman D. How to screen for colon cancer. Ann Rev Med. 1998;49:163-72. Exclude falls outside Task Order scope. [pmid: 9509256].
Lipscomb J. The Outcomes of Cancer Outcomes Research: Implications for the Quality of Cancer Care. National Cancer Institute. Available at: http://www.copufl.edu/departments/phca/Library/1. Accessed: May 9, 2005. 2001. Exclude review.
Litle VR, Barbour S, Schrock TR, et al. The continent ileostomy: long-term durability and patient satisfaction. J Gastrointest Surg. 1999;3(6):625-32. Exclude falls outside Task Order scope. [pmid: 10554370].
Livraghi T, Solbiati L, Meloni F, et al. Percutaneous radiofrequency ablation of liver metastases in potential candidates for resection: the “test-of-time approach”. Cancer. 2003;97(12):3027-35. Exclude non-U.S. data. [pmid: 12784338].
Longo WE, Johnson FE. The preoperative assessment and postoperative surveillance of patients with colon and rectal cancer. Surg Clin North Am. 2002;82(5):1091-108. Exclude no explicit QM. [pmid: 12507211].
Longo WE, Virgo KS, Johnson FE, et al. Outcome after proctectomy for rectal cancer in Department of Veterans Affairs Hospitals: a report from the National Surgical Quality Improvement Program. Ann Surg. 1998;228(1):64-70. Exclude falls outside Task Order scope. [pmid: 9671068]. [pmcid: 1191429].
Lonneux M, Reffad AM, Detry R, et al. FDG-PET improves the staging and selection of patients with recurrent colorectal cancer. Eur J Nucl Med Mol Imaging. 2002;29(7):915-21. Exclude non-U.S. data. [pmid: 12111132].
Lopez MJ, Monafo WW. Role of extended resection in the initial treatment of locally advanced colorectal carcinoma. Surgery. 1993;113(4):365-72. Exclude review. [pmid: 7681222].
Lovig T, Andersen SN, Thorstensen L, et al. Strong HLA-DR expression in microsatellite stable carcinomas of the large bowel is associated with good prognosis. Br J Cancer. 2002;87(7):756-62. Exclude non-U.S. data. [pmid: 12232760].
Lumby J, England K. Patient satisfaction with nursing care in a colorectal surgical population. Int J Nurs Pract. 2000;6(3):140-5. Exclude non-U.S. data. [pmid: 11249412].
Lund JN, Scholefield JH, Grainge MJ, et al. Risks, costs, and compliance limit colorectal adenoma surveillance: lessons from a randomised trial. Gut. 2001;49(1):91-6. Exclude non-U.S. data. [pmid: 11413116]. [pmcid: 1728357].
Lusky K. Pilot points way to speedier cancer surveillance. CAP Today. 2005;19(2):5-6. Exclude no explicit QM.
Lyratzopoulos G, West CR, Williams EM. Socioeconomic variation in colon cancer tumour factors associated with poorer prognosis. Br J Cancer. 2003;89(5):828-30. Exclude non-U.S. data. [pmid: 12942112].
Lytwyn A, Salit IE, Raboud J, et al. Interobserver agreement in the interpretation of anal intraepithelial neoplasia. Cancer. 2005;103(7):1447-56. Exclude no explicit QM. [pmid: 15726546].
MacFarlane JK. Developing standards for the treatment of rectal cancer. Can J Surg. 1997;40(5):327-8. Exclude review. [pmid: 9336518].
MacGillivray DC, Swartz SE, Robinson AM, et al. Adenocarcinoma of the colon and rectum in patients less than 40 years of age. Surg Gynecol Obstet. 1991;172(1):1-7. Exclude survival only. [pmid: 1985333].
Mainous AG 3rd, Kern D, Hainer B, et al. The relationship between continuity of care and trust with stage of cancer at diagnosis. Fam Med. 2004;36(1):35-9. Exclude falls outside Task Order scope. [pmid: 14710327].
Mainprize KS, Mortensen NJ, Warren BF. Dukes' staging is poorly understood by doctors managing colorectal cancer. Ann R Coll Surg Engl. 2002;84(1):23-5. Exclude non-U.S. data. [pmid: 11892729]. [pmcid: 2503762].
Makela J, Kiviniemi H, Laitinen S. Prognostic factors after surgery in patients younger than 50 years old with colorectal adenocarcinoma. Hepatogastroenterology. 2002;49(46):971-5. Exclude non-U.S. data. [pmid: 12143256].
Makela JT, Laitinen SO, Kairaluoma MI. Five-year follow-up after radical surgery for colorectal cancer. Results of a prospective randomized trial. Arch Surg. 1995;130(10):1062-7. Exclude no explicit QM. [pmid: 7575117].
Malik AI, Tou S, Huang A. Waiting times for cancer treatment. J R Soc Med. 2004;97(6):311. Exclude non-U.S. data.
Mandel JS. Colorectal cancer screening. Cancer Metastasis Rev. 1997;16(34):263-79. Exclude non-U.S. data. [pmid: 9433639].
Manos D. New study shows disparities in treatment of rectal cancer. Rep Med Guidel Outcomes Res 2004;15(5):9–10, 12. Exclude no explicit QM.
Manser MD, Levine DF, Pheby DF, et al. Colorectal cancer registration: the central importance of pathology. J Clin Pathol. 2000;53(11):875-7. Exclude non-U.S. data. [pmid: 11127275]. [pmcid: 1731103].
Manus B, Adang RP, Ambergen AW, et al. The risk factor profile of recto-sigmoid adenomas: a prospective screening study of 665 patients in a clinical rehabilitation centre. Eur J Cancer Prev. 1997;6(1):38-43. Exclude non-U.S. data. [pmid: 9161811].
Manus B, Bragelmann R, Armbrecht U, et al. Screening for gastrointestinal neoplasia: efficacy and cost of two different approaches in a clinical rehabilitation centre. Eur J Cancer Prev. 1996;5(1):49-55. Exclude non-U.S. data.
Marcella S, Miller JE. Racial differences in colorectal cancer mortality. The importance of stage and socioeconomic status. J Clin Epidemiol. 2001;54(4):359-66. Exclude survival only. [pmid: 11297886].
Maroun J, Ng E, Berthelot JM, et al. Lifetime costs of colon and rectal cancer management in Canada. Chronic Dis Can. 2003;24(4):91-101. Exclude non-U.S. data. [pmid: 14733758].
Marshall T, Mohammed MA. Differences in clinical performance. Br J Surg. 2002;89(8):948-9. Exclude non-U.S. data. [pmid: 12153618].
Martling A, Cedermark B, Johansson H, et al. The surgeon as a prognostic factor after the introduction of total mesorectal excision in the treatment of rectal cancer. Br J Surg. 2002;89(8):1008-13. Exclude non-U.S. data. [pmid: 12153626].
Martling A, Singnomklao T, Holm T, et al. Prognostic significance of both surgical and pathological assessment of curative resection for rectal cancer. Br J Surg. 2004;91(8):1040-5. Exclude review. [pmid: 15286968].
Marusch F, Koch A, Schmidt U, et al. Hospital caseload andthe results achieved in patients with rectal cancer. Br J Surg. 2001;88(10):1397-402. Exclude non-U.S. data. [pmid: 11578299].
Marusch F, Koch A, Schmidt U, et al. Effect of caseload on the short-term outcome of colon surgery: results of a multicenter study. Int J Colorectal Dis. 2001;16(6):362-9. Exclude non-U.S. data. [pmid: 11760897].
Mathew J, Shankar P, Aldean IM. Audit on flexible sigmoidoscopy for rectal bleeding in a district general hospital: are we over-loading the resources. Postgrad Med J. 2004;80(939):38-40. Exclude non-U.S. data. [pmid: 14760179]. [pmcid: 1757955].
Matter SE, Campbell DR. Significance of distal polyps detected with flexible sigmoidoscopy in asymptomatic patients. Arch Intern Med. 1992;152(9):1776-80. Exclude falls outside Task Order scope. [pmid: 1520044].
Maule WF. Screening for colorectal cancer by nurse endoscopists. N Engl J Med. 1994;330(3):183-7. Exclude non-U.S. data. [pmid: 8264742].
Mayberry RM, Coates RJ, Hill HA, et al. Determinants of black/white differences in colon cancer survival. J Natl Cancer Inst. 1995;87(22):1686-93. Exclude survival only. [pmid: 7473817].
McArdle CS, Hole D. Impact of variability among surgeons on postoperative morbidity and mortality and ultimate survival. BMJ. 1991;302(6791):1501-5. Exclude non-U.S. data. [pmid: 1713087]. [pmcid: 1670196].
McArdle CS, Hole D, Hansell D, et al. Prospective study of colorectal cancer in the west of Scotland: 10-year follow-up. Br J Surg. 1990;77(3):280-2. Exclude non-U.S. data. [pmid: 1691033].
McArdle CS, Hole DJ. Influence of volume and specialization on survival following surgery for colorectal cancer. Br J Surg. 2004;91(5):610-7. Exclude non-U.S. data. [pmid: 15122614].
McBean AM, Warren JL, Babish JD. Measuring the incidence of cancer in elderly Americans using Medicare claims data. Cancer. 1994;73(9):2417-25. Exclude no explicit QM. [pmid: 8168045].
McCallion K, Mitchell RM, Wilson RH, et al. Flexible sigmoidoscopy and the changing distribution of colorectal cancer: implications for screening. Gut. 2001;48(4):522-5. . Exclude non-U.S. data. [pmid: 11247897]. [pmcid: 1728246].
McCallum J. The role of the nurse endoscopist. Hosp Med. 2003;64(6):337-9. Exclude review. [pmid: 12833826].
McCarthy EP, Burns RB, Davis RB, et al. Barriers to hospice care among older patients dying with lung and colorectal cancer. J Clin Oncol. 2003;21(4):728-35. Exclude falls outside Task Order scope. [pmid: 12586813].
McCarthy EP, Phillips RS, Zhong Z, et al. Dying with cancer: patients' function, symptoms, and care preferences as death approaches. J Am Geriatr Soc. 2000;48(5 Suppl):S110-21. Exclude falls outside Task Order scope. [pmid: 10809464].
McClish D, Penberthy L. Using Medicare data to estimate the number of cases missed by a cancer registry: a 3-source capture-recapture model. Med Care. 2004;42(11):1111-6. Exclude no explicit QM. [pmid: 15586838].
McCollum A, Catalano P, Haller D, et al. Outcomes and Toxicity in African-American and Caucasian Patients in a Randomized Adjuvant Chemotherapy Trial for Colon Cancer. J Natl Cancer Inst. 2002;94(15):1160-7. Exclude survival only. [pmid: 12165641].
McCool J, Morris J. Focus of doctor-patient communication in follow-up consultations for patients treated surgically for colorectal cancer. J Manag Med. 1999;13(23):169-77. Exclude non-U.S. data. [pmid: 10747448].
McDavid K, Schymura MJ, Armstrong L, et al. Rationale and design of the National Program of Cancer Registries' Breast, Colon, and Prostate Cancer Patterns of Care Study. Cancer Causes Control. 2004;15(10):1057-66. Exclude no explicit QM. [pmid: 15801489].
McDavid K, Tucker TC, Sloggett A, et al. Cancer survival in Kentucky and health insurance coverage. Arch Intern Med. 2003;163(18):2135-44. Exclude survival only. [pmid: 14557210].
McFall MR, Woods WG, Miles WF. Colonoscopic surveillance after curative colorectal resection: results of an empirical surveillance programme. Colorectal Dis. 2003;5(3):233-40. Exclude non-U.S. data. [pmid: 12780884].
McFall SL, Warnecke RB, Kaluzny AD, et al. Practice setting and physician influences on judgments of colon cancer treatment by community physicians. Health Serv Res. 1996;31(1):5-19. Exclude no explicit QM. [pmid: 8617610]. [pmcid: 1070100].
McGlynn E. Selecting common measures of quality and system performance. Med Care. 2003;41(1 supplement):I39-I47. Exclude review. [pmid: 12544815].
McGlynn E, Asch S, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-45. Exclude no explicit QM. [pmid: 12826639].
McGlynn EA. Choosing chronic disease measures for HEDIS: conceptual framework and review of seven clinical areas. Manag Care Q. 1996;4(3):54-77. Exclude no explicit QM. [pmid: 10159034].
McGrath DR, Leong DC, Armstrong BK, et al. Management of colorectal cancer patients in Australia: the National Colorectal Cancer Care Survey. ANZ J Surg. 2004;74(12):55-64. Exclude non-U.S. data. [pmid: 14725707].
McGrath JS, Ponich TP, Gregor JC. Screening for colorectal cancer: the cost to find an advanced adenoma. Am J Gastroenterol. 2002;97(11):2902-7. Exclude non-U.S. data. [pmid: 12425566].
McKee M, Hunter D. Mortality league tables: do they inform or mislead. Qual Health Care. 1995;4(1):5-12. Exclude non-U.S. data. [pmid: 10142037]. [pmcid: 1055259].
McLeish JA, Giles GG, Thursfield V. Investigation, follow-up and recurrence after resection of colorectal cancer. Ann N Z J Surg. 1992;62(12):931-40. Exclude non-U.S. data.
McLeod RS. Canadian Task Force on Preventive Health Care. Screening strategies for colorectal cancer: a systematic review of the evidence. Can J Gastroenterol. 2001;15(10):647-60. Exclude falls outside Task Order scope. [pmid: 11694901].
Meagher AP. Colorectal cancer: is the surgeon a prognostic factor? A systematic review. Med J Aust. 1999;171(6):308-10. Exclude review. [pmid: 10560448].
Meagher AP, Ward RL. Current evidence does not support routine adjuvant radiotherapy for rectal cancer. ANZ J Surg. 2003;73(4):252-3. Exclude non-U.S. data.
Mella J, Datta SN, Biffin A, et al. Surgeons' follow-up practice after resection of colorectal cancer. Ann R Coll Surg Engl. 1997;79(3):206-9. Exclude non-U.S. data. [pmid: 9196343]. [pmcid: 2502904].
Mettlin CJ, Menck HR, Winchester DP, et al. A comparison of breast, colorectal, lung, and prostate cancers reported to the National Cancer Data Base and the Surveillance, Epidemiology, and End Results Program. Cancer. 1997;79(10):2052-61. Exclude data sources. [pmid: 9149035].
Meyerhardt JA, Catalano PJ, Schrag D, et al. Association of hospital procedure volume and outcomes in patients with colon cancer at high risk for recurrence. [erratum appears in Ann Intern Med. 2004 Jun 15;140(12):1063]. Ann Intern Med. 2003;139(8):649-57. Exclude survival only. [pmid: 14568853].
Meyerhardt JA, Mayer RJ. Follow-up strategies after curative resection of colorectal cancer. Semin Oncol. 2003;30(3):349-60. Exclude review. [pmid: 12870136].
Michael M, Moore MJ. Assessing the impact of chemotherapy on tumor-related symptoms in advanced colorectal cancer. Oncology (Huntingt). 1998;12(8 Suppl 6):121-8. Exclude no explicit QM. [pmid: 9726104].
Miki C, Inoue Y, Toiyama Y, et al. Deficiency in systemic interleukin-1 receptor antagonist production as an operative risk factor in malnourished elderly patients with colorectal carcinoma. Crit Care Med. 2005;33(1):177-80. Exclude non-U.S. data. [pmid: 15644666].
Minardi AJ Jr, Sittig KM, Zibari GB, et al. Colorectal cancer in the young patient. Am Surg. 1998;64(9):849-53. Exclude no explicit QM. [pmid: 9731812].
Mitchell PL, White CA. Austin Bowel Cancer Consortium. Austin Bowel Cancer Consortium: changing culture in bowel cancer care. Med J Aust. 2004;180(10 Suppl):S79-82. Exclude non-U.S. data. [pmid: 15139842].
Miyakura Y, Togashi K, Konishi F, et al. Appropriate operation for elderly colorectal cancer patients based upon an assessment of preoperative risk factors. Surg Today. 2003;33(7):498-503. Exclude non-U.S. data. [pmid: 14506993].
Moertel CG, Fleming TR, Macdonald JS, et al. Levamisole and fluorouracil for adjuvant therapy of resected colon carcinoma. N Engl J Med. 1990;322(6):352-8. Exclude no explicit QM. [pmid: 2300087].
Monnet E, Boutron MC, Faivre J, et al. Influence of socioeconomic status on prognosis of colorectal cancer. A population-based study in Cote D'Or, France. Cancer. 1993;72(4):1165-70. Exclude non-U.S. data. [pmid: 8339209].
Monnet E, Faivre J, Raymond L, et al. Comparability of colorectal cancer survival data in three European population-based registries. Eur J Cancer Prev. 1998;7(2):127-34. Exclude non-U.S. data. [pmid: 9818774].
Moore J, Hewett P, Penfold JC, et al. Practice parameters for the management of colonic cancer I: surgical issues. Recommendations of the Colorectal Surgical Society of Australia. nn N Z J Surg. 1999;69(6):415-21. Exclude no explicit QM.
Morantz C. American Cancer Society. ACS guidelines for early detection of cancer. Am Fam Physician. 2004;69(8):2013. Exclude no explicit QM. [pmid: 15117023].
Morris JB, Stellato TA, Guy BB, et al. A critical analysis of the largest reported mass fecal occult blood screening program in the United States. Am J Surg. 1991;161(1):101-5. discussion 105–6. Exclude falls outside Task Order scope. [pmid: 1987842].
Mosconi P, Torri V, Cifani S, et al. The multi-centre assessment of quality of life: the Interdisciplinary Group for Cancer Care Evaluation (GIVIO) experience in Italy. Stat Med. 1998;17(57):577-85. Exclude non-U.S. data. [pmid: 9549807].
Mostafa G, Matthews BD, Norton HJ, et al. Influence of demographics on colorectal cancer. Am Surg. 2004;70(3):259-64. Exclude data sources. [pmid: 15055851].
Mulcahy HE, Patchett SE, Daly L, et al. Prognosis of elderly patients with large bowel cancer. Br J Surg. 1994;81(5):736-8. Exclude non-U.S. data. [pmid: 8044567].
Munemoto Y, Iida Y, Ohata K, et al. Significance of postoperative adjuvant immunochemotherapy after curative resection of colorectal cancers: identification of responders incorporating the age factor. Oncol Rep. 2004;11(3):623-35. Exclude falls outside Task Order scope. [pmid: 14767513].
Murakami R, Tsukuma H, Kanamori S, et al. Natural history of colorectal polyps and the effect of polypectomy on occurrence of subsequent cancer. Int J Cancer. 1990;46(2):159-64. Exclude non-U.S. data. [pmid: 2384265].
Myers AF, Nichols PH, Beck NE. Age limits for surveillance colonoscopy following colorectal cancer resection. Colorectal Dis. 2004;6(2):131-2. Exclude review. [pmid: 15008916].
Myers RE, Fishbein G, Hyslop T, et al. Measuring complete diagnostic evaluation in colorectal cancer screening. Cancer Detect Prev. 2001;25(2):174-82. Exclude falls outside Task Order scope. [pmid: 11341353].
Myers RE, Hyslop T, Gerrity M, et al. Physician intention to recommend complete diagnostic evaluation in colorectal cancer screening. Cancer Epidemiol Biomarkers Prev. 1999;8(7):587-93. Exclude no explicit QM. [pmid: 10428195].
Myers RE, Murray J, Weinberg D, et al. Analysis of colorectal cancer stage among HMO members targeted for screening. Arch Intern Med. 1997;157(17):2001-6. Exclude falls outside Task Order scope. [pmid: 9308512].
Myers RE, Turner B, Weinberg D, et al. Complete diagnostic evaluation in colorectal cancer screening: research design and baseline findings. Prev Med. 2001;33(4):249-60. Exclude no explicit QM. [pmid: 11570828].
Myers RE, Vernon SW, Tilley BC, et al. Intention to screen for colorectal cancer among white male employees. Prev Med. 1998;27(2):279-87. Exclude falls outside Task Order scope. [pmid: 9579008].
Nadalin V, Cotterchio M, McKeown-Eyssen G, et al. Agreement between proxy- and case-reported information obtained using the self- administered Ontario Familial Colon Cancer Registry epidemiologic questionnaire. Chronic Dis Can. 2003;24(1):1-8. Exclude non-U.S. data. [pmid: 12757630].
Nadel MR, Blackman DK, Shapiro JA, et al. Are people being screened for colorectal cancer as recommended? Results from the National Health Interview Survey. Prev Med. 2002;35(3):199-206. Exclude falls outside Task Order scope. [pmid: 12202061].
Nagashima I, Takada T, Matsuda K, et al. A new scoring system to classify patients with colorectal liver metastases: proposal of criteria to select candidates for hepatic resection. J Hepatobiliary Pancreat Surg. 2004;11(2):79-83. Exclude non-U.S. data. [pmid: 15127268].
Nagtegaal ID, Kranenbarg EK, Hermans J, et al. Pathology data in the central databases of multicenter randomized trials need to be based on pathology reports and controlled by trained quality managers. J Clin Oncol. 2000;18(8):1771-9. Exclude non-U.S. data. [pmid: 10764439].
Nakama H, Kamijo N, Abdul Fattah AS, et al. Validity of immunological faecal occult blood screening for colorectal cancer: a follow up study. J Med Screen. 1996;3(2):63-5. Exclude falls outside Task Order scope. [pmid: 8849761].
Nakamura T, Yoshioka H, Ohno M, et al. Clinicopathologic variables affecting survival of distal colorectal cancer patients with macroscopic invasion into the adjacent organs. Surg Today. 1999;29(3):226-32. Exclude non-U.S. data. [pmid: 10192732].
National Cancer Institute. Infrastructure needed for cancer research: NCI's challenge: quality of cancer care. Available at http://plan2003.cancer.gov/infra/quality.htm. Accessed: April 6, 2005. 2003. Exclude review.
National Institute for Clinical Excellence. Guidelines on Cancer Services: Improving Outcomes in Colorectal Cancers: Manual Update. May 2004. Exclude non-U.S. data.
National Institutes of Health (NIH). NIH consensus conference. Adjuvant therapy for patients with colon and rectal cancer. JAMA 1990;264(11):1444–50. Exclude no explicit QM.
Neff MJ. ACS. ACS releases guidelines on nutrition and physical activity during and after cancer treatment. Am Fam Physician. 2004;69(7):1803-5. Exclude falls outside Task Order scope. [pmid: 15086050].
Nelson H, Petrelli N, Carlin A, et al. Guidelines 2000 for Colon and Rectal Cancer Surgery. J Natl Cancer Inst. 2001;93(8):583-96. Exclude review. [pmid: 11309435].
Nelson RL, Dollear T, Freels S, et al. The relation of age, race, and gender to the subsite location of colorectal carcinoma. Cancer. 1997;80(2):193-7. Exclude no explicit QM. [pmid: 9217029].
Nelson RL, Persky V, Turyk M. Carcinoma in situ of the colorectum: SEER trends by race, gender, and total colorectal cancer. J Surg Oncol. 1999;71(2):123-9. Exclude no explicit QM. [pmid: 10389871].
Nesbakken A, Nygaard K, Westerheim O, et al. Audit of intraoperative and early postoperative complications after introduction of mesorectal excision for rectal cancer. Eur J Surg. 2002;168(4):229-35. Exclude non-U.S. data. [pmid: 12440761].
Ness RM, Holmes A, Klein R, et al. Outcome states of colorectal cancer: identification and description using patient focus groups. Am J Gastroenterol. 1998;93(9):1491-7. Exclude data sources. [pmid: 9732931].
Ness RM, Rex DK, Imperiale T. Translating clinical research to community-based practice: lessons from colorectal cancer screening and diagnosis. Endocsopy. 1999;31(2):170-3. Exclude review.
Nicholson WJ, Davis DL. Analyses of changes in the ratios of male-to-female cancer mortality. A hypothesis-generating exercise. Ann N Y Acad Sci. 1990;609:290-9. Exclude no explicit QM. [pmid: 2264652].
Nicoli N, Casaril A, Mangiante G, et al. Surgical treatment for liver metastases from colorectal carcinoma: results of 228 patients. Hepatogastroenterology. 2004;51(60):1810-4. Exclude falls outside Task Order scope. [pmid: 15532832].
Nilsson KR, Berenholtz SM, Dorman T, et al. Preoperative predictors of blood transfusion in colorectal cancer surgery. J Gastrointest Surg. 2002;6(5):753-62. Exclude no explicit QM. [pmid: 12399066].
Nordlinger B, Peschaud F, Malafosse R. Resection of liver metastases from colorectal cancer--how can we improve results. Colorectal Dis. 2003;5(5):515-7. Exclude non-U.S. data. [pmid: 12925092].
Northover J. Follow-up after curative surgery for colorectal cancer. Scand J Surg. 2003;92(1):84-9. Exclude non-U.S. data. [pmid: 12705555].
Norum J. Prevention of colorectal cancer: a cost-effectiveness approach to a screening model employing sigmoidoscopy. Ann Oncol. 1998;9(6):613-8. Exclude non-U.S. data. [pmid: 9681074].
Nwiloh J, Dardik H, Dardik M, et al. Changing patterns in the morbidity and mortality of colorectal surgery. Am J Surg. 1991;162(1):83-5. Exclude no explicit QM. [pmid: 2063975].
O'Bichere A, Sellu D. The quality of operation notes: can simple word processors help. Ann R Coll Surg Engl. 1997;79(5 Suppl):204-8. discussion 209. Exclude non-U.S. data. [pmid: 9496162].
O'Connell JB, Maggard MA, Ko CY. Colon cancer survival rates with the new American Joint Committee on Cancer sixth edition staging. J Natl Cancer Inst. 2004;96(19):1420-5. Exclude review. [pmid: 15467030].
Ohlsson B, Palsson B. Follow-up after colorectal cancer surgery. Acta Oncol. 2003;42(8):816-26. Exclude non-U.S. data. [pmid: 14968942].
Oliver MD. Two week rule for cancer referrals. All stages of care pathway need speeding up. BMJ. 2001;323(7317):864. Exclude non-U.S. data.
Olynyk JK, Aquilia S, Fletcher DR, et al. Flexible sigmoidoscopy screening for colorectal cancer in average-risk subjects: a community-based pilot project. Med J Aust. 1996;165(2):74-6. Exclude non-U.S. data. [pmid: 8692065].
Oppong C, Robertson N, Sherwood A, et al. The use of a proforma improves colorectal cancer pathology reporting. Ann R Coll Surg Engl. 2002;84(4):290. author reply 290. Exclude non-U.S. data. [pmid: 12215039].
Paksoy M, Ipek T, Colak T, et al. Influence of age on prognosis and management of patients with colorectal carcinoma. Eur J Surg. 1999;165(1):55-9. Exclude non-U.S. data. [pmid: 10069635].
Palitz AM, Selby JV, Grossman S, et al. The Colon Cancer Prevention Program (CoCaP): rationale, implementation, and preliminary results. HMO Pract. 1997;11(1):5-12. Exclude falls outside Task Order scope. [pmid: 10165556].
Palmer ML, Herrera L, Petrelli NJ. Colorectal adenocarcinoma in patients less than 40 years of age. Dis Colon Rectum. 1991;34(4):343-6. Exclude survival only. [pmid: 1706654].
Palmer RC, Schneider EC. Social disparities across the continuum of colorectal cancer: a systematic review. Cancer Causes Control. 2005;16(1):55-61. Exclude review. [pmid: 15750858].
Panageas KS, Schrag D, Riedel E, et al. The effect of clustering of outcomes on the association of procedure volume and surgical outcomes. Ann Intern Med. 2003;139(8):658-65. Exclude falls outside Task Order scope. [pmid: 14568854].
Papagrigoriadis S, Heyman B. Patients' views on follow up of colorectal cancer: implications for risk communication and decision making. Postgrad Med J. 2003;79(933):403-7. Exclude non-U.S. data. [pmid: 12897220]. [pmcid: 1742752].
Parry JM, Collins S, Mathers J, et al. Influence of volume of work on the outcome of treatment for patients with colorectal cancer. Br J Surg. 1999;86(4):475-81. Exclude non-U.S. data. [pmid: 10215817].
Parry JM, Scott N, Sherlock D, et al. Use of hepatic imaging techniques in the management of colorectal cancer: a survey of current practice among surgeons in the northwest of England. Ann R Coll Surg Engl. 1998;80(4):244-5. Exclude non-U.S. data. [pmid: 9771220]. [pmcid: 2503087].
Paszat LF, Brundage MD, Groome PA, et al. A population-based study of rectal cancer: permanent colostomy as an outcome. Int J Radiat Oncol Biol Phys. 1999;45(5):1185-91. Exclude non-U.S. data. [pmid: 10613311].
Paterson CA, Dozois RR. The ileal pouch-anal anastomosis: success and failure. Chirurg. 1998;123(6):545-9. Exclude falls outside Task Order scope.
Paty PB, Nash GM, Baron P, et al. Long-term results of local excision for rectal cancer. Ann Surg. 2002;236(4):522-29. discussion 529–30. Exclude survival only. [pmid: 12368681]. [pmcid: 1422607].
Pauler DK, McCoy S, Moinpour C. Pattern mixture models for longitudinal quality of life studies in advanced stage disease. Stat Med. 2003;22(5):795-809. Exclude data sources. [pmid: 12587106].
Paunescu V, Ragalie S. Factors of prediction of immediate postoperative evolution in cancer of the colon. Rom J Intern Med. 1991;29(34):155-65. Exclude non-U.S. data. [pmid: 1784944].
Paviot BT, Martin C, Clavel L, et al. From DRG databases to an epidemiological observatory for colorectal cancer in a French small area oncology network. Stud Health Technol Inform 2002;95(829–33). Exclude non-U.S. data.
Pawlega J. Survival studies: Cracow Cancer registry experience. Cancer Detect Prev. 1993;17(45):475-83. Exclude non-U.S. data. [pmid: 8242647].
Pawlson G, Scholle SH, Renner P. Pitfalls of converting practice guidelines into quality measures. JAMA. 2004;292(11):1301. author reply 1302. Exclude review.
Peeters KC, van de Velde CJ. Surgical quality assurance in breast, gastric and rectal cancer. J Surg Oncol. 2003;84(3):107-12. Exclude non-U.S. data. [pmid: 14598352].
Pennello GA, Devesa SS, Gail MH. Using a mixed effects model to estimate geographic variation in cancer rates. Biometrics. 1999;55(3):774-81. Exclude no explicit QM. [pmid: 11315006].
Persson E, Gustavsson B, Hellstrom AL, et al. Ostomy patients' perceptions of quality of care. J Adv Nurs. 2005;49(1):51-8. Exclude non-U.S. data. [pmid: 15610381].
Petrelli NJ, Nagel S, Rodriguez-Bigas M, et al. Morbidity and mortality following abdominoperineal resection for rectal adenocarcinoma. Am Surg. 1993;59(7):400-4. Exclude falls outside Task Order scope. [pmid: 8323072].
Pezze M, Gargiulo A, Catarci T, et al. A formal model for quality assurance in coloproctologic surgery. Medinfo. 1995;8(Pt 2):1037-41. Exclude non-U.S. data. [pmid: 8591362].
Pfister DG, Benson AB 3rd, Somerfield MR. Clinical practice. Surveillance strategies after curative treatment of colorectal cancer. N Engl J Med. 2004;350(23):2375-82 Exclude. falls outside Task Order scope. [pmid: 15175439].
Phillips K, Luft H. The Policy Implications of Using Hospital and Physician Volumes as “Indicators” of Quality of Care in a Changing Health Care Environment. Int J Qual Health Care. 1997;9(5):341-8. Exclude no explicit QM. [pmid: 9394202].
Phipps E, True G, Harris D, et al. Approaching the end of life: attitudes, preferences, and behaviors of African-American and white patients and their family caregivers. J Clin Oncol. 2003;21(3):549-54. Exclude no explicit QM. [pmid: 12560448].
Pickhardt P, Nugent P, Mysliwiec P, et al. Location of adenomas missed by optical colonoscopy. Ann Intern Med. 2004;141(5):352-9. Exclude wrong population. [pmid: 15353426].
Pitchforth E, Russell E, Van der Pol M. Access to specialist cancer care: is it equitable. Br J Cancer. 2002;87(11):1221-6. Exclude non-U.S. data. [pmid: 12439709].
Platell CF, Semmens JB. Review of survival curves for colorectal cancer. Dis Colon Rectum. 2004;47(12):2070-5. Exclude non-U.S. data. [pmid: 15657656].
Platz EA, Martinez ME, Grodstein F, et al. Parity and other reproductive factors and risk of adenomatous polyps of the distal colorectum (United States). Cancer Causes Control. 1997;8(6):894-903. . Exclude no explicit QM. [pmid: 9427432].
Polednak AP. Trends in late-stage breast, cervical and colorectal cancers in blacks and whites. Ethn Dis. 2000;10(1):60-8. Exclude no explicit QM. [pmid: 10764131].
Pollard CW, Nivatvongs S, Rojanasakul A, et al. Carcinoma of the rectum. Profiles of intraoperative and early postoperative complications. Dis Colon Rectum. 1994;37(9):866-74. Exclude no explicit QM. [pmid: 8076485].
Pollock AM, Benster R, Vickers N. Why did treatment rates for colorectal cancer in south east England fall between 1982 and 1988? The effect of case ascertainment and registration bias. J Public Health Med. 1995;17(4):419-28. Exclude non-U.S. data. [pmid: 8639341].
Pollock AM, Vickers N. The impact on colorectal cancer survival of cases registered by 'death certificate only': implications for national survival rates. Br J Cancer. 1994;70(6):1229-31. Exclude non-U.S. data. [pmid: 7981082].
Pollock AM, Vickers N. Reliability of data of the Thames cancer registry on 673 cases of colorectal cancer: effect of the registration process. Qual Health Care. 1995;4(3):184-9. Exclude non-U.S. data. [pmid: 10153427]. [pmcid: 1055314].
Pollock AM, Vickers N. Management of colorectal cancer in three South Thames District Health Authorities. Public Health. 1997;111(3):165-70. Exclude non-U.S. data. [pmid: 9175461].
Pollock AM, Vickers N. Trends in colorectal cancer care in southern England, 1989-1993: using HES data to inform cancer services reviews. J Epidemiol Community Health. 1998;52(7):433-8. Exclude non-U.S. data. [pmid: 9799877]. [pmcid: 1756736].
Ponz de Leon M, Benatti P, Di Gregorio C, et al. Staging and survival of colorectal cancer: are we making progress? The 14-year experience of a specialized cancer registry. Dig Liver Dis. 2000;32(4):312-7. Exclude non-U.S. data. [pmid: 11515629].
Ponz de Leon M, Benatti P, Percesepe A, et al. Epidemiology of cancer of the large bowel--the 12-year experience of a specialized registry in northern Italy. Ital J Gastroenterol. 1999;31(1):10-8. Exclude non-U.S. data.
Porter GA, Soskolne CL, Yakimets WW, et al. Surgeon-related factors and outcome in rectal cancer. Ann Surg. 1998;227(2):157-67. Exclude non-U.S. data. [pmid: 9488510]. [pmcid: 1191229].
Potosky AL, Riley GF, Lubitz JD, et al. Potential for cancer related health services research using a linked Medicare-tumor registry database. Med Care. 1993;31(8):732-48. Exclude review. [pmid: 8336512].
Prajapati DN, Saeian K, Binion DG, et al. Volume and yield of screening colonoscopy at a tertiary medical center after change in medicare reimbursement. Am J Gastroenterol. 2003;98(1):194-9. Exclude falls outside Task Order scope. [pmid: 12526957].
Prandi M, Lionetto R, Bini A, et al. Prognostic evaluation of stage B colon cancer patients is improved by an adequate lymphadenectomy: results of a secondary analysis of a large scale adjuvant trial. Ann Surg. 2002;235(4):458-63. Exclude non-U.S. data. [pmid: 11923600]. [pmcid: 1422459].
Prior P, Woodman CB, Collins S. International differences in survival from colon cancer: more effective care versus less complete cancer registration. Br J Surg. 1998;85(1):101-4. Exclude non-U.S. data. [pmid: 9462395].
Provenzale D, Gray RN. Colorectal cancer screening and treatment: review of outcomes research. J Natl Cancer Inst Monogr 2004;(33):45–55. Exclude QOL.
Prystowsky J, Bordage G, Feinglass J. Patient outcomes for segmental colon resection according to surgeon's training, certification, and experience. Surgery. 2002;132(4):663-72. Exclude wrong population. [pmid: 12407351].
Rabeneck L, El-Serag HB, Davila JA, et al. Outcomes of colorectal cancer in the United States: no change in survival (1986-1997). Am J Gastroenterol. 2003;98(2):471-7. Exclude survival only. [pmid: 12591071].
Rahusen FD, Cuesta MA, Borgstein PJ, et al. Selection of patients for resection of colorectal metastases to the liver using diagnostic laparoscopy and laparoscopic ultrasonography. Ann Surg. 1999;230(1):31-7. Exclude non-U.S. data. [pmid: 10400033]. [pmcid: 1420841].
Ramakrishnan K. Technical competency in flexible sigmoidoscopy. J Am Board Fam Pract. 2002;15(2):173. Exclude review. [pmid: 12002205].
Ramakrishnan K, Scheid DC. Predictors of incomplete flexible sigmoidoscopy. J Am Board Fam Pract. 2003;16(6):478-84. Exclude falls outside Task Order scope. [pmid: 14963074].
Ramsey SD, Berry K, Etzioni R. Lifetime cancer-attributable cost of care for long term survivors of colorectal cancer. Am J Gastroenterol. 2002;97(2):440-5. Exclude no explicit QM. [pmid: 11866285].
Ransohoff DF, Lang CA. Screening for colorectal cancer with the fecal occult blood test: a background paper. American College of Physicians. Ann Intern Med. 1997;126(10):811-22. Exclude falls outside Task Order scope. [pmid: 9148658].
Rao BR, Sandilya S, Niculescu R, et al. Mining time-dependent patient outcomes from hospital patient records. Proc AMIA Symp 2002;632–6. Exclude no explicit QM.
Rao RS, Graubard BI, Breen N, et al. Understanding the factors underlying disparities in cancer screening rates using the Peters-Belson approach: results from the 1998 National Health Interview Survey. Med Care. 2004;42(8):789-800. Exclude falls outside Task Order scope. [pmid: 15258481].
Raraty MG, Winstanley JH. Variation in the staging of colorectal carcinomas: a survey of current practice. Ann R Coll Surg Engl. 1998;80(3):188-91. Exclude non-U.S. data. [pmid: 9682641]. [pmcid: 2503027].
Ray-Coquard I, Philip T, Lehmann M, et al. Impact of a clinical guidelines program for breast and colon cancer in a French cancer center. JAMA. 1997;278(19):1591-5. Exclude non-U.S. data. [pmid: 9370505].
Rayson D. Witness. J Clin Oncol. 2005;23(10):2429-30. Exclude falls outside Task Order scope. [pmid: 15800337].
Redmond K. Assessing patients' needs and preferences in the management of advanced colorectal cancer. Br J Cancer. 1998;77(Suppl 2):5-7. Exclude non-U.S. data. [pmid: 9579849].
Reeve T. Implementing guidelines about colorectal cancer: a national survey of target groups. ANZ J Surg. 2001;71(3):137-8. Exclude non-U.S. data. [pmid: 11277140].
Reinbach DH, McGregor JR, Murray GD, et al. Effect of the surgeon's specialty interest on the type of resection performed for colorectal cancer. Dis Colon Rectum. 1994;37(10):1020-3. Exclude non-U.S. data. [pmid: 7924708].
Reinus JF. Guidelines for clinical practice. Management of colorectal polyps. Dig Dis Sci. 1994;39(10):2282-4. Exclude review. [pmid: 7924756].
Renehan A, O'Dwyer S. Letters to the Editor. Ann Surg. 1999;229(3):442-3. Exclude non-U.S. data.
Renehan A, O'Dwyer ST. A selective policy in follow-up for bowel cancer. Lancet. 1998;351(9119):1891. Exclude no explicit QM.
Renehan AG, Egger M, Saunders MP, et al. Mechanisms of improved survival from intensive followup in colorectal cancer: a hypothesis. Br J Cancer. 2005;92(3):430-3. Exclude non-U.S. data. [pmid: 15685236].
Renwick AA, Bokey EL, Chapuis PH, et al. Effect of supervised surgical training on outcomes after resection of colorectal cancer. Br J Surg. 2005;92(5):631-6. Exclude non-U.S. data. [pmid: 15810050].
Retchin SM, Penberthy L, Desch C, et al. Perioperative management of colon cancer under Medicare risk programs. Arch Intern Med. 1997;157(16):1878-84. Exclude wrong population. [pmid: 9290548].
Rex D, Bond J, Winawer S, et al. Quality in the technical performance of colonoscopy and the continuous quality improvement process for colonoscopy: recommendations of the U.S. Multi-Society Task Force on Colorectal Cancer. Am J Gastroenterol. 2002;97(6):1296-308. Exclude review. [pmid: 12094842].
Rex DK. Colonoscopy turning the focus on quality. Dig Liver Dis. 2002;34(12):831-2. Exclude review. [pmid: 12643289].
Rex DK, Cutler CS, Lemmel GT, et al. Colonoscopic miss rates of adenomas determined by back-to-back colonoscopies. Gastroenterology. 1997;112(1):24-8. Exclude no explicit QM. [pmid: 8978338].
Rex DK, Ness RM. Disease-specific outcomes assessment for diagnosis of colorectal neoplasia: from clinical trials to community practice. Gastrointest Endosc Clin N Am 1999;9(4):697–704, ix. Exclude review.
Rex DK, Rawl SM, Rabeneck L, et al. Colorectal cancer in African Americans. Rev Gastroenterol Disord. 2004;4(2):60-5. Exclude review. [pmid: 15184825].
Rex DK, Rahmani E, Haseman J, et al. Relative sensitivity of colonoscopy and barium enema for detection of colorectal cancer in clinical practice. Gastroenterology. 1997;112:17-23. Exclude data sources. [pmid: 8978337].
Reynolds T. Why randomized surgical oncology trials are so scarce. J Natl Cancer Inst. 1999;91(14):1182-3. Exclude review. [pmid: 10413409].
Richards RJ, Minocha A. Screening interval for colorectal cancer with colonoscopy: the long and short of it. Am J Gastroenterol. 1997;92(5):904-5. . Exclude review. [pmid: 9149217].
Rickert RR, Compton CC. Protocol for the examination of specimens from patients with carcinomas of the anus and anal canal: a basis for checklists. Cancer Committee of the College of American Pathologists. Arch Pathol Lab Med. 2000;124(1):21-5. Exclude falls outside Task Order scope. [pmid: 10629126].
Riesewyk C, Hawyard C, Enser V, et al. Referral and diagnostic process in suspected colorectal cancer needs to be improved to achieve two week target. BMJ. 2000;321(7275):1527. Exclude non-U.S. data.
Rigby K, Brown SR, Lakin G, et al. The use of a proforma improves colorectal cancer pathology reporting. Ann R Coll Surg Engl. 1999;81(6):401-3. Exclude non-U.S. data. [pmid: 10655894]. [pmcid: 2503311].
Robinson MH, Marks CG, Farrands PA, et al. Screening for colorectal cancer with an immunological faecal occult blood test: 2-year follow-up. Br J Surg. 1996;83(4):500-1. Exclude falls outside Task Order scope.
Rodney WM, Dabov G, Cronin C. Evolving colonoscopy skills in a rural family practice: the first 293 cases. Fam Pract Res J. 1993;13(1):43-52. Exclude falls outside Task Order scope. [pmid: 8484340].
Roetzheim RG, Gonzalez EC, Ramirez A, et al. Primary care physician supply and colorectal cancer. J Fam Pract. 2001;50(12):1027-31. Exclude no explicit QM. [pmid: 11742602].
Roh MS. Expanding the indications for hepatic resection in patients with colorectal liver metastases. Ann Surg Oncol. 2004;11(3):238-9. Exclude no explicit QM. [pmid: 14993015].
Rollins G. PET scans improve management decisions, reduce unnecessary surgery in recurrent colorectal cancer. Rep Med Guidel Outcomes Res. 2002;13(9):7-9. Exclude falls outside Task Order scope.
Roman S, Cenni JC, Roy P, et al. Value of rectal ultrasound in predicting staging and outcome in patients with rectal adenocarcinoma. Dis Colon Rectum. 2004;47(8):1323-30. Exclude no explicit QM. [pmid: 15484346].
Rose JH, O'Toole EE, Dawson NV, et al. Age differences in care practices and outcomes for hospitalized patients with cancer. J Am Geriatr Soc. 2000;48(5 Suppl):S25-32. Exclude falls outside Task Order scope. [pmid: 10809453].
Rosen C, Nagorney D, Taswell H, et al. Perioperative Blood Transfusion and Determinants of Survival after liver resection for metastatic colorectal carcinoma. Ann Surg. 1992;216(4):493-505. Exclude no explicit QM. [pmid: 1417198]. [pmcid: 1242658].
Rosen L, Stasik JJ Jr, Reed JF 3rd, et al. Variations in colon and rectal surgical mortality. Comparison of specialties with a state-legislated database. Dis Colon Rectum. 1996;39(2):129-35. Exclude survival only. [pmid: 8620777].
Rothenberger D. The American Cancer Society guidelines for colorectal cancer screening: have we gone too far (or not far enough)?. Gastroenterology. 1998;114(6):1341-3. Exclude no explicit QM. [pmid: 9618655].
Rothenberger DA. Evidence-based practice requires evidence. Br J Surg. 2004;91(11):1387-8. Exclude no explicit QM. [pmid: 15499647].
Rothenberger DA, Akbari R, Baxter NN. Are we overtreating some patients with rectal cancer?. Oncology (Huntingt). 1799;18(14):1789-96. discussion 1796. Exclude falls outside Task Order scope.
Rothenberger D, Garcia-Aguilar J. Management of cancer in a polyp. In: Saltz L, ed. Colorectal cancer: multimodality management. New Jersey: Saunders. 2002;325–35. Exclude review.
Rozmovits L, Rose P, Ziebland S. In the absence of evidence, who chooses? A qualitative study of patients' needs after treatment for colorectal cancer. J Health Serv Res Pol. 2004;9(3):159-64. Exclude no explicit QM.
Ruo L, Cellini C, La-Calle JP Jr,, et al. Limitations of family cancer history assessment at initial surgical consultation. Dis Colon Rectum. 2001;44(1):98-103. discussion 103–4. Exclude falls outside Task Order scope. [pmid: 11805570].
Sahay TB, Gray RE, Fitch M. A qualitative study of patient perspectives on colorectal cancer. Cancer Pract. 2000;8(1):38-44. . Exclude non-U.S. data. [pmid: 10732538].
Salkeld G, Solomon M, Short L, et al. A matter of trust-patient's views on decision-making in colorectal cancer. Health Expect. 2004;7(2):104. Exclude non-U.S. data. [pmid: 15117385].
Sanchez KM, Richardson JL, Mason HR. The return to work experiences of colorectal cancer survivors. AAOHN J. 2004;52(12):500-10. Exclude falls outside Task Order scope. [pmid: 15635931].
Sant M, Capocaccia R, Verdecchia A, et al. Comparisons of colon-cancer survival among European countries: The Eurocare Study. Int J Cancer. 1995;63(1):43-8. Exclude non-U.S. data. [pmid: 7558450].
Sargent DJ, Goldberg RM, Jacobson SD, et al. A pooled analysis of adjuvant chemotherapy for resected colon cancer in elderly patients. N Engl J Med. 2001;345(15):1091-7. Exclude no explicit QM. [pmid: 11596588].
Sarli L, Pietra N, Costi R, et al. Adenocarcinoma of the colon and rectum: some reflections on the immediate and long-term results of surgery. Ital J Gastroenterol. 1998;30(6):641-7. Exclude non-U.S. data.
Sato T, Konishi F, Endoh N, et al. Long-term outcomes of a neo-anus with a pudendal nerve anastomosis contemporaneously reconstructed with an abdominoperineal excision of the rectum. Surgery. 2005;137(1):8-15. Exclude non-U.S. data. [pmid: 15614275].
Sauer R, Becker H, Hohenberger W, et al. Preoperative versus postoperative chemoradiotherapy for rectal cancer. N Engl J Med. 2004;351(17):1731-40. Exclude no explicit QM. [pmid: 15496622].
Schag CA, Ganz PA, Heinrich RL. CAncer Rehabilitation Evaluation System--short form (CARES-SF). A cancer specific rehabilitation and quality of life instrument. Cancer. 1991;68(6):1406-13. Exclude no explicit QM. [pmid: 1873793].
Scheidbach H, Schneider C, Hugel O, et al. Oncological quality and preliminary long-term results in laparoscopic colorectal surgery. Surg Endosc. 2003;17(6):903-10. Exclude no explicit QM. [pmid: 12632133].
Schiowitz M. Letters to the Editor. Ann Surg. 1999;229(3):442-3. Exclude no explicit QM.
Schmidt CE, Bestmann B, Kuchler T, et al. Impact of age on quality of life in patients with rectal cancer. World J Surg. 2005;29(2):190-7. . Exclude non-U.S. data. [pmid: 15654662].
Schmidt CE, Bestmann B, Kuchler T, et al. Prospective evaluation of quality of life of patients receiving either abdominoperineal resection or sphincter-preserving procedure for rectal cancer. Ann Surg Oncol. 2005;12(2):117-23. Exclude non-U.S. data. [pmid: 15827791].
Schmidt CE, Bestmann B, Kuchler T, et al. Ten-year historic cohort of quality of life and sexuality in patients with rectal cancer. Dis Colon Rectum. 2005;48(3):483-92. Exclude non-U.S. data. [pmid: 15747079].
Schneider E, Epstein A, Malin J, et al. Developing a System to Assess the Quality of Cancer Care: ASCO's National Initiative on Cancer Care Quality. J Clin Oncol. 2004;22(15):2985-91. Exclude no explicit QM. [pmid: 15284249].
Schoemaker D, Black R, Giles L, et al. Yearly colonoscopy, liver CT, and chest radiography do not influence 5-year survival of colorectal cancer patients. Gastroenterology. 1998;114(1):7-14. Exclude no explicit QM. [pmid: 9428212].
Schoenfeld PS, Cash B, Kita J, et al. Effectiveness and patient satisfaction with screening flexible sigmoidoscopy performed by registered nurses. Gastrointest Endosc. 1999;49(2):158-62. . Exclude falls outside Task Order scope. [pmid: 9925692].
Schoetz DJ Jr,, Bockler M, Rosenblatt MS, et al. “Ideal” length of stay after colectomy: whose ideal?. Dis Colon Rectum. 1997;40(7):806-10. . Exclude no explicit QM. [pmid: 9221857].
Scholefield JH, Steele RJ. British Society For Gastroenterology, et al. Guidelines for follow up after resection of colorectal cancer. Gut. 2002;51(Suppl 5):V3-5. Exclude non-U.S. data. [pmid: 12221030].
Schorr M, Siebeck M, Hohenbleicher F, et al. Colorectal cancer: A rational follow-up program adapted to patient's individual risk of recurrence and review of the literature. Eur J Med Res. 1999;4(7):275-82. Exclude no explicit QM. [pmid: 10425265].
Schrag D. Communication and coordination: the keys to quality. Jl Clin Oncol. 2005;23(27):tbd. Exclude no explicit QM.
Schroy PC 3rd, Wilson S, Afdhal N. Feasibility of high-volume screening sigmoidoscopy using a flexible fiberoptic endoscope and a disposable sheath system. Am J Gastroenterol. 1996;91(7):1331-7. Exclude falls outside Task Order scope. [pmid: 8677989].
Schwartz KL, Crossley-May H, Vigneau FD, et al. Race, socioeconomic status and stage at diagnosis for five common malignancies. Cancer Causes Control. 2003;14(8):761-6. Exclude no explicit QM. [pmid: 14674740].
Schwartz MH, Tartter PI. Decreased length of stay for patients with colorectal cancer: implications of DRG use. J Healthc Qual. 1998;20(4):22-5. Exclude falls outside Task Order scope. [pmid: 10181902].
Schwenk W, Neudecker J, Haase O, et al. Comparison of EORTC quality of life core questionnaire (EORTC-QLQ-C30) and gastrointestinal quality of life index (GIQLI) in patients undergoing elective colorectal cancer resection. Int J Colorectal Dis. 2004;19(6):554-60. Exclude QOL. [pmid: 15205989].
Secco GB, Fardelli R, Gianquinto D, et al. Efficacy and cost of risk-adapted follow-up in patients after colorectal cancer surgery: a prospective, randomized and controlled trial. Eur J Surg Oncol. 2002;28(4):418-23. Exclude non-U.S. data. [pmid: 12099653].
Seeff LC, Shapiro JA, Nadel MR. Are we doing enough to screen for colorectal cancer? Findings from the 1999 Behavioral Risk Factor Surveillance System. J Fam Pract. 2002;51(9):761-6. Exclude falls outside Task Order scope. [pmid: 12366896].
Seitz U, Bohnacker S, Seewald S, et al. Long-term results of endoscopic removal of large colorectal adenomas. Endocsopy. 2003;35(8):S41-4. Exclude no explicit QM.
Senagore AJ, Warmuth AJ, Delaney CP, et al. POSSUM, p-POSSUM, and Cr-POSSUM: implementation issues in a United States health care system for prediction of outcome for colon cancer resection. Dis Colon Rectum. 2004;47(9):1435-41. . Exclude no explicit QM. [pmid: 15486738].
Seymour MT, Stenning SP, Cassidy J. Attitudes and practice in the management of metastatic colorectal cancer in Britain. Colorectal Cancer Working Party of the UK Medical Research Council. Clin Oncol (R Coll Radiol). 1997;9(4):248-51. Exclude non-U.S. data. [pmid: 9315400].
Shankar A, Taylor I. Treatment of colorectal cancer in patients aged over 75. Eur J Surg Oncol. 1998;24(5):391-5. Exclude non-U.S. data. [pmid: 9800966].
Shavers VL, Brown ML. Racial and ethnic disparities in the receipt of cancer treatment. J Natl Cancer Inst. 2002;94(5):334-57. Exclude review. [pmid: 11880473].
Shaw JW, Johnson JA, Coons SJ. US Valuation of the EQ-5D Health States:development and testing of the D1 valuation model. Med Care. 2005;43(3):203-20. Exclude QOL. [pmid: 15725977].
Shepherd NA, Quirke P. Colorectal cancer reporting: are we failing the patient. J Clin Pathol. 1997;50(4):266-7. Exclude non-U.S. data. [pmid: 9215136]. [pmcid: 499869].
Shibata S, Shiroma T, Tsukiji M, et al. Report of colon cancer detection in mass surveys using immunological occult blood test (Latex method). J Med Syst. 1993;17(34):153-6. Exclude falls outside Task Order scope. [pmid: 8254258].
Simon JB. Should all people over the age of 50 have regular fecal occult-blood tests? Postpone population screening until problems are solved. N Engl J Med. 1998;338(16):1151-2. discussion 1154–5. Exclude falls outside Task Order scope. [pmid: 9545367].
Simons BD, Morrison AS, Lev R, et al. Relationship of polyps to cancer of the large intestine. J Natl Cancer Inst. 1992;84(12):962-6. Exclude no explicit QM. [pmid: 1629917].
Simunovic M, To T, Baxter N, et al. Hospital procedure volume and teaching status do not influence treatment and outcome measures of rectal cancer surgery in a large general population. J Gastrointest Surg. 2000;4(3):324-30. Exclude non-U.S. data. [pmid: 10769097].
Singer RB. Fecal occult blood testing and the incidence of colorectal cancer. J Insur Med. 2002;34(2):89-91. Exclude falls outside Task Order scope. [pmid: 15305783].
Singh GK, Miller BA, Hankey BF. Changing area socioeconomic patterns in U.S. cancer mortality, 1950-1998: Part II--Lung and colorectal cancers. J Natl Cancer Inst. 2002;94(12):916-25. Exclude no explicit QM. [pmid: 12072545].
Singh SM, Paszat LF, Li C, et al. Association of socioeconomic status and receipt of colorectal cancer investigations: a population-based retrospective cohort study. CMAJ. 2004;171(5):461-5. Exclude non-U.S. data. [pmid: 15337726]. [pmcid: 514642].
Siu AL, McGlynn EA, Morgenstern H, et al. Choosing quality of care measures based on the expected impact of improved care on health. Health Serv Res. 1992;27(5):619-50. Exclude no explicit QM. [pmid: 1464537]. [pmcid: 1069903].
Sloan J, Loprinzi C, Kuross S, et al. Randomized Comparison of Four Tools Measuring Overall Quality of Life in Patients with Advanced Cancer. J Clin Oncol. 1998;16(11):3662-73. . Exclude QOL. [pmid: 9817289].
Smith J, King P, Lane R, et al. Evidence of the effect of specialization on the management, surgical outcome and survival form colorectal cancer in Wessex. Br J Surg. 2003;90:583-92. . Exclude non-U.S. data. [pmid: 12734867].
Smith JJ, Lee J, Burke C, et al. Major colorectal cancer resection should not be denied to the elderly. Eur J Surg Oncol. 2002;28(6):661-6. Exclude non-U.S. data. [pmid: 12359205].
Smith LE, Ko ST, Saclarides T, et al. Transanal endoscopic microsurgery. Initial registry results. Dis Colon Rectum. 1996;39(10 Suppl):S79-84. Exclude no explicit QM. [pmid: 8831552].
Smith TJ, Hillner BE, Bear HD. Taking action on the volume-quality relationship: how long can we hide our heads in the colostomy bag?. J Natl Cancer Inst. 2003;95(10):695-7. Exclude no explicit QM. [pmid: 12759377].
Solomon MJ, Pager CK, Keshava A, et al. What do patients want? Patient preferences and surrogate decision making in the treatment of colorectal cancer. Dis Colon Rectum. 2003;46(10):1351-7. Exclude non-U.S. data. [pmid: 14530674].
Solomon MJ, Pager CK, Young JM, et al. Patient entry into randomized controlled trials of colorectal cancer treatment: factors influencing participation. Surgery. 2003;133(6):608-13. Exclude no explicit QM. [pmid: 12796726].
Solomon MJ, Thomas RJ, Gattellari M, et al. Does type of surgeon matter in rectal cancer surgery? Evidence, guideline consensus and surgeons' views. ANZ J Surg. 2001;71(12):711-4. . Exclude non-U.S. data. [pmid: 11906384].
Soloway G, Reinus JF. Flexible sigmoidoscopy may be ineffective for secondary prevention of colorectal cancer in asymptomatic, average-risk men. Gastrointest Endosc. 1992;38(2):205-6. . Exclude falls outside Task Order scope. [pmid: 1568629].
Sorensen HT, Ejlersen E, Moller-Petersen J, et al. Overall use of proctoscopy in general practice and possible relation to the stage of rectal cancer. Fam Pract. 1992;9(2):145-8. Exclude non-U.S. data. [pmid: 1505700].
Soybel DI. Surgeon-related factors and outcome in rectal cancer. Gastroenterology. 1999;116(1):220-1. Exclude review. [pmid: 9869624].
Spatz H, Engel J, Holzel D, et al. The surgical discharge summary: a lack of substantial clinical information may affect the postop treatment of rectal cancer patients. Langenbecks Arch Surg. 2001;386(5):350-6. Exclude non-U.S. data. [pmid: 11685566].
Sprangers MA. Quality-of-life assessment in colorectal cancer patients: evaluation of cancer therapies. Semin Oncol. 1999;26(6):691-6. Exclude review. [pmid: 10606262].
Sprangers MA, te Velde A, Aaronson NK. The construction and testing of the EORTC colorectal cancer-specific quality of life questionnaire module (QLQ-CR38). European Organization for Research and Treatment of Cancer Study Group on Quality of Life. Eur J Cancer. 1999;35(2):238-47. Exclude non-U.S. data. [pmid: 10448266].
Staib L, Link KH, Blatz A, et al. Surgery of colorectal cancer: surgical morbidity and five- and ten-year results in 2400 patients--monoinstitutional experience. World J Surg. 2002;26(1):59-66. . Exclude non-U.S. data. [pmid: 11898035].
Staib L, Schirrmeister H, Reske SN, et al. Is (18)F-fluorodeoxyglucose positron emission tomography in recurrent colorectal cancer a contribution to surgical decision making. Am J Surg. 2000;180(1):1-5. . Exclude non-U.S. data. [pmid: 11036130].
Steele G. National Cancer Database: Annual review of patient care, 1993. Atlanta, Ga. American Cancer Society 1993;20–36. Exclude publication duplicate.
Stevenson G. Radiology in the detection and prevention of colorectal cancer. Eur J Cancer. 1995;31A(78):1121-6. Exclude non-U.S. data. [pmid: 7577005].
Stewart BT, Keck JO, Duncan AV, et al. Difficult or incomplete flexible sigmoidoscopy: implications for a screening programme. Ann N Z J Surg. 1999;69(1):19-21. Exclude non-U.S. data.
Stewart SL, King JB, Thompson TD, et al. Cancer mortality surveillance--United States, 1990-2000. MMWR Surveill Summ. 2004;53(3):1-108. Exclude survival only.
Stiggelbout AM, de Haes JC, Vree R, et al. Follow-up of colorectal cancer patients: quality of life and attitudes towards follow-up. Br J Cancer. 1997;75(6):914-20. Exclude non-U.S. data. [pmid: 9062416].
Stockton D, Davies T. Multiple cancer site comparison of adjusted survival by hospital of treatment: an East Anglian study. Br J Cancer. 2000;82(1):208-12. Exclude non-U.S. data. [pmid: 10638991].
Sugarman JR, Dennis LK, White E. Cancer survival among American Indians in western Washington State (United States). Cancer Causes Control. 1994;5(5):440-8. Exclude survival only. [pmid: 7999966].
Summerhayes M. Choice of chemotherapy regimen for advanced colorectal cancer. Clin Oncol (R Coll Radiol). 2002;14(6):520-1. Exclude non-U.S. data. [pmid: 12512977].
Swanson RS. Palliation of rectal cancer: expertise and selection are the keys. Ann Surg Oncol. 2002;9(10):937-8. Exclude review. [pmid: 12464582].
Swanson RS, Compton CC, Stewart AK, et al. The prognosis of T3N0 colon cancer is dependent on the number of lymph nodes examined. Ann Surg Oncol. 2003;10(1):65-71. Exclude no explicit QM. [pmid: 12513963].
Swedish Revtal Cancer Trial. Improved survival with preoperative radiotherapy in resectable rectal cancer. N Engl J Med 1997;336(14):980–7. Exclude no explicit QM.
Tagore KS, Lawson MJ, Yucaitis JA, et al. Sensitivity and specificity of a stool DNA multitarget assay panel for the detection of advanced colorectal neoplasia. Clin Colorectal Cancer. 2003;3(1):47-53. Exclude falls outside Task Order scope. [pmid: 12777192].
Taylor I. Quality of follow-up of the cancer patient affecting outcome. Surg Oncol Clin N Am 2000;9(1):21–5, vi. Exclude non-U.S. data.
Taylor KL, Shelby R, Gelmann E, et al. Quality of life and trial adherence among participants in the prostate, lung, colorectal, and ovarian cancer screening trial. J Natl Cancer Inst. 2004;96(14):1083-94. Exclude falls outside Task Order scope. [pmid: 15265970].
Taylor P. One stop to the best patient care. Interview by Charlotte Alderman. Nurs Stand. 1998;12(52):28-30. Exclude falls outside Task Order scope.
Tekkis P, Poloniecki J, Thompson M, et al. Operative Mortality in colorectal cancer: prospective national study. Br Med J. 2003;327(7425):1196-201. Exclude non-U.S. data. [pmid: 14630754]. [pmcid: 274053].
Tekkis PP, Senagore AJ, Delaney CP, et al. Evaluation of the learning curve in laparoscopic colorectal surgery: comparison of right-sided and left-sided resections. Ann Surg. 2005;242(1):83-91. Exclude falls outside Task Order scope. [pmid: 15973105]. [pmcid: 1357708].
Temple LK, Bacik J, Savatta SG, et al. The development of a validated instrument to evaluate bowel function after sphincter-preserving surgery for rectal cancer. Dis Colon Rectum. 2005;48(7):1353-65. Exclude QOL. [pmid: 15868235].
Tepper JE, O'Connell MJ, Niedzwiecki D, et al. Impact of number of nodes retrieved on outcome in patients with rectal cancer. J Clin Oncol. 2001;19(1):157-63. Exclude no explicit QM. [pmid: 11134208].
Termuhlen PM, Kemeny MM. Surgery in the older patient. Oncology (Huntingt). 2002;16(2):183-9. discussion 194–6, 199. Exclude review. [pmid: 11866135].
Thompson GA, Cocks JR, Collopy BT, et al. Clinical indicators in colorectal surgery. J Qual Clin Pract. 1996;16(4):229-30. Exclude non-U.S. data. [pmid: 9010822].
Thompson GA, Cocks JR, Collopy BT, et al. Colorectal resection in Victoria:a comparison of hospital based and individual audit. Ann N Z J Surg. 1996;66(8):520-4. Exclude non-U.S. data.
Thompson W. Wessex regional radiology audit: barium enema in colo-rectal carcinoma. Clin Radiol. 1996;51(7):525. Exclude non-U.S. data.
Tilney HS, Trickett JP, Edwards DP. A novel indicator for surveillance colonoscopy following colorectal cancer resection. Colorectal Dis. 2003;5(3):270. author reply 271. Exclude falls outside Task Order scope.
Toby G, Bowman H, Tielsch J, et al. Statewide Regionalization of Pancreaticoduodenectomy and its Effect on In-Hospital Mortality. Ann Surg. 1998;228(1):71-8. Exclude falls outside Task Order scope. [pmid: 9671069]. [pmcid: 1191430].
Topham C, Moore J. Patient preferences for chemotherapy schedules used in the treatment of advanced colorectal cancer--a pilot study. Eur J Cancer Care (Engl). 1997;6(4):291-4. Exclude non-U.S. data. [pmid: 9460348].
Torfs K, Pocceschi S. A retrospective study of resource utilisation in the treatment of advanced colorectal cancer in Europe. Eur J Cancer. 1996;32A(Suppl 5):S28-31. Exclude non-U.S. data. [pmid: 8958040].
Towler B, Irwig L, Glasziou P, et al. A systematic review of the effects of screening for colorectal cancer using the faecal occult blood test, hemoccult. BMJ. 1998;317(7158):559-65. Exclude review. [pmid: 9721111]. [pmcid: 28648].
Triantafillidis JK, Papatheodorou K, Kogevinas M, et al. Prognostic factors affecting the survival of operated patients with colorectal cancer: significance of delayed hypersensitivity skin reactions and nutritional status. Ital J Gastroenterol. 1995;27(8):419-24. Exclude non-U.S. data. [pmid: 8775467].
Triantafyllou K, Papatheodoridis GV, Paspatis GA, et al. Predictors of the early development of advanced metachronous colon adenomas. Hepatogastroenterology. 1997;44(14):533-8. Exclude non-U.S. data. [pmid: 9164533].
Trillet-Lenoir V, Freyer G, Kaemmerlen P, et al. Assessment of tumour response to chemotherapy for metastatic colorectal cancer: accuracy of the RECIST criteria. Br J Radiol. 2002;75(899):903-8. Exclude non-U.S. data. [pmid: 12466256].
Trimble EL, Carter CL, Cain D, et al. Representation of older patients in cancer treatment trials. Cancer. 1994;74(7 Suppl):2208-14. Exclude falls outside Task Order scope. [pmid: 8087794].
Troxel AB. A comparative analysis of quality of life data from a Southwest Oncology Group randomized trial of advanced colorectal cancer. Stat Med. 1998;17(57):767-79. Exclude data sources. [pmid: 9549822].
Tsalic M, Bar-Sela G, Beny A, et al. Severe toxicity related to the 5-fluorouracil/leucovorin combination (the Mayo Clinic regimen): a prospective study in colorectal cancer patients. Am J Clin Oncol. 2003;26(1):103-6. Exclude non-U.S. data. [pmid: 12576935].
Tulsky JA. Beyond advance directives: importance of communication skills at the end of life. JAMA. 2005;294(3):359-65. . Exclude falls outside Task Order scope. [pmid: 16030281].
Turner B, Myers RE, Hyslop T, et al. Physician and patient factors associated with ordering a colon evaluation after a positive fecal occult blood test. J Gen Intern Med. 2003;18(5):357-63. . Exclude no explicit QM. [pmid: 12795734]. [pmcid: 1494867].
Tveit KM. ESMO Guidelines Task Force. ESMO Minimum Clinical Recommendations for diagnosis, treatment and follow-up of rectal cancer. Ann Oncol. 2003;14(7):1006-7. Exclude non-U.S. data. [pmid: 12853337].
Tyldesley S, Zhang-Salomons J, Groome PA, et al. Association between age and the utilization of radiotherapy in Ontario. Int J Radiat Oncol Biol Phys. 2000;47(2):469-80. Exclude non-U.S. data. [pmid: 10802375].
Ubhi SS, Kent SJ. Which surgeons in a district general hospital should treat patients with carcinoma of the rectum. J R Coll Surg Edinb. 1995;40(1):52-4. Exclude non-U.S. data. [pmid: 7738900].
UK Department of Health. Manual of quality measures for cancer peer review 2004-draft for consultation: (manual for cancer services assessment). Available at: http://www.dh.gov.uk/policyandguidance/healthandsocialcaretopics/cancer/cancerarticle. Accessed April 6, 2005. 2004. Exclude review.
Ulander K, Jeppsson B, Grahn G. Quality of life and independence in activities of daily living preoperatively and at follow-up in patients with colorectal cancer. Support Care Cancer. 1997;5(5):402-9. Exclude non-U.S. data. [pmid: 9322353].
Urbach DR, Bell CM, Austin PC. Differences in operative mortality between high- and low-volume hospitals in Ontario for 5 major surgical procedures: estimating the number of lives potentially saved through regionalization. CMAJ. 2003;168(11):1409-14. Exclude non-U.S. data. [pmid: 12771069]. [pmcid: 155956].
Urban M, Rosen HR, Holbling N, et al. MR imaging for the preoperative planning of sphincter-saving surgery for tumors of the lower third of the rectum: use of intravenous and endorectal contrast materials. Radiology. 2000;214(2):503-8. Exclude no explicit QM. [pmid: 10671600].
Valentini V, Genovesi D, Polico C, et al. Quality assurance procedures in radiotherapy of rectal neoplasms. Rays. 1996;21(4):649-62. Exclude non-U.S. data. [pmid: 9122450].
van den Brink M, van den Hout WB, Stiggelbout AM, et al. Cost measurement in economic evaluations of health care: whom to ask. Med Care. 2004;42(8):740-6. Exclude non-U.S. data. [pmid: 15258475].
van Harten WH, van Noort O, Warmerdam R, et al. Assessment of rehabilitation needs in cancer patients. Int J Rehabil Res. 1998;21(3):247-57. Exclude non-U.S. data. [pmid: 9812254].
Vanchieri C. Colon cancer update triggers changes in practice. J Natl Cancer Inst. 1990;82(11):898. Exclude falls outside Task Order scope. [pmid: 2342121].
Vaughn DJ, Haller DG. Adjuvant therapy for colorectal cancer: past accomplishments, future directions. Cancer Invest. 1997;15(5):435-47. Exclude review. [pmid: 9316626].
Verma S, Giaffer MH. Open-access versus hospital-initiated flexible sigmoidoscopy: a comparative audit of efficacy. Eur J Gastroenterol Hepatol. 2001;13(6):655-8. Exclude non-U.S. data. [pmid: 11434590].
Vernava AM 3rd, Longo WE, Virgo KS, et al. Current follow-up strategies after resection of colon cancer. Results of a survey of members of the American Society of Colon and Rectal Surgeons. Dis Colon Rectum. 1994;37(6):573-83. Exclude falls outside Task Order scope. [pmid: 8200237].
Verne JE, Aubrey R, Love SB, et al. Population based randomized study of uptake and yield of screening by flexible sigmoidoscopy compared with screening by faecal occult blood testing. BMJ. 1998;317(7152):182-5. Exclude non-U.S. data. [pmid: 9665902]. [pmcid: 28612].
Vernon SW. Participation in colorectal cancer screening: a review. J Natl Cancer Inst. 1997;89(19):1406-22. Exclude review. [pmid: 9326910].
Vernon SW, Hughes JI, Heckel VM. HMO versus fee for service practice: a four-year retrospective analysis of colorectal cancer diagnosis and treatment. Is there a difference in quality of care. Prog Clin Biol Res. 1990;339:341-50. Exclude no explicit QM. [pmid: 2392430].
Vernon SW, Meissner H, Klabunde C, et al. Measures for ascertaining use of colorectal cancer screening in behavioral, health services, and epidemiologic research. Cancer Epidemiol Biomarkers Prev. 2004;13(6):898-905. Exclude falls outside Task Order scope. [pmid: 15184243].
Vickers N, Pollock A. Incompleteness and retrieval of case notes in a case note audit of colorectal cancer. Qual Health Care. 1993;2(3):170-4. Exclude non-U.S. data. [pmid: 10131461]. [pmcid: 1055123].
Vincenzi B, Cesa AL, Santini D, et al. Predictive factors for response to chemotherapy in colorectal cancer patients. Crit Rev Oncol Hematol. 2004;52(1):45-60. Exclude non-U.S. data. [pmid: 15363466].
Violi V, Pietra N, Grattarola M, et al. Curative surgery for colorectal cancer: long-term results and life expectancy in the elderly. Dis Colon Rectum. 1998;41(3):291-8. Exclude non-U.S. data. [pmid: 9514423].
Virgo KS, Vernava AM, Longo WE, et al. Cost of patient follow-up after potentially curative colorectal cancer treatment. JAMA. 1995;273(23):1837-41. Exclude no explicit QM. [pmid: 7776499].
Virgo KS, Wade TP, Longo WE, et al. Surveillance after curative colon cancer resection: practice patterns of surgical subspecialists. Ann Surg Oncol. 1995;2(6):472-82. Exclude falls outside Task Order scope. [pmid: 8591076].
Vironen JH, Sainio P, Husa AI, et al. Complications and survival after surgery for rectal cancer in patients younger than and aged 75 years or older. Dis Colon Rectum. 2004;47(7):1225-31. Exclude non-U.S. data. [pmid: 15164247].
Vukasin P, Ortega AE, Greene FL, et al. Wound recurrence following laparoscopic colon cancer resection. Results of the American Society of Colon and Rectal Surgeons Laparoscopic Registry. Dis Colon Rectum. 1996;39(10 Suppl):S20-3. Exclude no explicit QM. [pmid: 8831542].
Wagman RT, Minsky BD. Conservative management of rectal cancer with local excision and adjuvant therapy. Oncology (Huntingt) 2001;15(4):513–9, 524;discussion 524–8. Exclude review.
Wakefield SE, Baigrie RJ, MacLeod AJ, et al. Colorectal cancer surgery in a district general hospital. J R Coll Surg Edinb. 1996;41(6):374-8. Exclude non-U.S. data. [pmid: 8997022].
Walker MS, Ristvedt SL, Haughey BH. Patient care in multidisciplinary cancer clinics: does attention to psychosocial needs predict patient satisfaction?. Psychooncology. 2003;12(3):291-300. Exclude no explicit QM.
Walsh JM, Terdiman JP. Colorectal cancer screening: scientific review. JAMA. 2003;289(10):1288-96. Exclude falls outside Task Order scope. [pmid: 12633191].
Walsh S, Bruce C, Bennington S, et al. The fourteen-day rule and colorectal cancer. Ann R Coll Surg Engl. 2002;84(6):386-8. Exclude non-U.S. data. [pmid: 12484576].
Walter LC, Davidowitz NP, Heineken PA, et al. Pitfalls of converting practice guidelines into quality measures: lessons learned from a VA performance measure. JAMA. 2004;291(20):2466-70. Exclude no explicit QM. [pmid: 15161897].
Wanebo HJ, Chu QD, Vezeridis MP, et al. Patient selection for hepatic resection of colorectal metastases. Arch Surg. 1996;131(3):322-9. Exclude no explicit QM. [pmid: 8611099].
Ward WL, Hahn EA, Mo F, et al. Reliability and validity of the Functional Assessment of Cancer Therapy-Colorectal (FACT-C) quality of life instrument. Qual Life Res. 1999;8(3):181-95. Exclude data sources. [pmid: 10472150].
Warren JL, Harlan LC. Can cancer registry data be used to study cancer treatment. Med Care. 2003;41(9):1003-5. Exclude review. [pmid: 12972839].
Warren JL, Harlan LC, Fahey A, et al. Utility of the SEER-Medicare data to identify chemotherapy use. Med Care 2002;40(8 Suppl):IV–55–61. Exclude data sources.
Warsi AA, White S, McCulloch P. Completeness of data entry in three cancer surgery databases. Eur J Surg Oncol. 2002;28(8):850-6. Exclude non-U.S. data. [pmid: 12477477].
Weeks J, Nelson H, Gelber S, et al. Short-term quality of life outcomes following laparoscopic-assisted colectomy vs open colectomy for colon cancer: a randomized trial. JAMA. 2002;287(3):321-8. Exclude QOL. [pmid: 11790211].
Weeks JC. Preferences of older cancer patients: can you judge a book by its cover?. J Natl Cancer Inst. 1994;86(23):1743-4. Exclude review. [pmid: 7966406].
Wei EK, Ryan CT, Dietrich AJ, et al. Improving colorectal cancer screening by targeting office systems in primary care practices: disseminating research results into clinical practice. Arch Intern Med. 2005;165(6):661-6. Exclude wrong population. [pmid: 15795343].
Weissfeld JL, Ling BS, Schoen RE, et al. Adherence to repeat screening flexible sigmoidoscopy in the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial. Cancer. 2002;94(10):2569-76. Exclude falls outside Task Order scope. [pmid: 12173322].
Wexner SD, Forde KA, Sellers G, et al. How well can surgeons perform colonoscopy. Surg Endosc. 1998;12(12):1410-4. Exclude falls outside Task Order scope. [pmid: 9822468].
Wexner SD, Rotholtz NA. Surgeon influenced variables in resectional rectal cancer surgery. Dis Colon Rectum. 2000;43(11):1606-27. Exclude review. [pmid: 11089603].
Whittle J, Steinberg EP, Anderson GF, et al. Accuracy of Medicare claims data for estimation of cancer incidence and resection rates among elderly Americans. Med Care. 1991;29(12):1226-36. Exclude data sources. [pmid: 1745080].
Whynes DK, Frew EJ, Manghan CM, et al. Colorectal cancer, screening and survival: the influence of socio-economic deprivation. Public Health. 2003;117(6):389-95. Exclude non-U.S. data. [pmid: 14522153].
Whynes DK, Neilson AR. Symptoms before and after surgery for colorectal cancer. Qual Life Res. 1997;6(1):61-6. Exclude non-U.S. data. [pmid: 9062443].
Wibe A, Eriksen MT, Syse A, et al. Total mesorectal excision for rectal cancer--what can be achieved by a national audit. Colorectal Dis. 2003;5(5):471-7. Exclude non-U.S. data. [pmid: 12925083].
Wibe A, Moller B, Norstein J, et al. A national strategic change in treatment policy for rectal cancer--implementation of total mesorectal excision as routine treatment in Norway. A national audit. Dis Colon Rectum. 2002;45(7):857-66. Exclude non-U.S. data. [pmid: 12130870].
Wichmann MW, Muller C, Hornung HM, et al. Gender differences in long-term survival of patients with colorectal cancer. Br J Surg. 2001;88(8):1092-8. Exclude non-U.S. data. [pmid: 11488795].
Widder J, Sedlmayer F, Stanek C, et al. Quality assurance in preoperative radiotherapy of rectal cancer: evaluation of a pre-trial dummy-run. Radiother Oncol. 2000;56(3):341-7. Exclude non-U.S. data. [pmid: 10974384].
Wiggers T, van de Velde CH. Reduction “by half”. The need for standardised surgical technique in studies of radiotherapy for rectal cancer. Eur J Surg. 1999;165(5):407-9. Exclude no explicit QM. [pmid: 10391154].
Wils J. Adjuvant treatment of colon cancer. A plea for a large-scale European trial. Neth J Med. 1994;44(2):37-40. Exclude non-U.S. data. [pmid: 8208322].
Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. 2003;124(2):544-60. Exclude falls outside Task Order scope. [pmid: 12557158].
Winawer SJ. Appropriate intervals for surveillance. Gastrointest Endosc. 1999;49(3 Pt 2):S63-6. . Exclude review. [pmid: 10049451].
Winawer SJ, Zauber A, O'Brien M, et al. Randomized comparison of surveillance intervals after colonoscopie removal of newly diagnosed adenomatous polyps. N Engl J Med. 1993;328:901-6. Exclude no explicit QM. [pmid: 8446136].
Winchester DP, Stewart AK, Bura C, et al. The National Cancer Data Base: a clinical surveillance and quality improvement tool. J Surg Oncol. 2004;85(1):1-3. Exclude review. [pmid: 14696080].
Wolf DC. Coding for screening and surveillance of colorectal cancer in the Medicare population. Inflamm Bowel Dis. 1998;4(3):255-6. Exclude falls outside Task Order scope. [pmid: 9741032].
Wolters U, Isenberg J, Stutzer H. Colorectal carcinoma--aspects of surgery in the elderly. Anticancer Res. 1997;17(2B):1273-6. Exclude non-U.S. data. [pmid: 9137484].
Womack C, Thornton-Holmes J, Wells AD. Colorectal cancer reporting. J Clin Pathol. 1997;50(10):881-2. Exclude non-U.S. data. [pmid: 9462280]. [pmcid: 500279].
Wong RK, Gafni A, Whelan T, et al. Defining patient-based minimal clinically important effect sizes: a study in palliative radiotherapy for painful unresectable pelvic recurrences from rectal cancer. Int J Radiat Oncol Biol Phys. 2002;54(3):661-9. Exclude non-U.S. data. [pmid: 12377316].
Woolf SH. Shared decision-making: the case for letting patients decide which choice is best. J Fam Pract. 1997;45(3):205-8. Exclude review. [pmid: 9299998].
Worthington TR, Wilson T, Padbury R. Case for postoperative surveillance following colorectal cancer resection. ANZ J Surg. 2004;74(12):43-5. Exclude non-U.S. data. [pmid: 14725705].
Wulf J, Kramer K, van Aaken C, et al. Outcome of postoperative treatment for rectal cancer UICC stage II and III in day-to-day clinical practice. Results from a retrospective quality control analysis in six institutions in North Bavaria (Germany). Strahlenther Onkol. 2004;180(1):5-14. Exclude non-U.S. data. [pmid: 14704839].
Wullenweber HP, Sutter C, Autschbach F, et al. Evaluation of Bethesda guidelines in relation to microsatellite instability. Dis Colon Rectum. 2001;44(9):1281-9. Exclude non-U.S. data. [pmid: 11584201].
Yabroff KR, Klabunde CN, Myers R, et al. Physician recommendations for follow-up of positive fecal occult blood tests. Med Care Res Rev. 2005;62(1):79-110. Exclude no explicit QM. [pmid: 15643030].
Yabroff KR, Washington KS, Leader A, et al. Is the promise of cancer-screening programs being compromised? Quality of follow-up care after abnormal screening results. Med Care Res Rev. 2003;60(3):294-331. Exclude review. [pmid: 12971231].
Yamamoto S, Akasu T, Fujita S, et al. Postsurgical surveillance for recurrence of UICC stage I colorectal carcinoma: is follow-up by CEA justified. Hepatogastroenterology. 2005;52(62):444-9. Exclude falls outside Task Order scope. [pmid: 15816454].
Yamamoto S, Watanabe M, Hasegawa H, et al. Prospective evaluation of laparoscopic surgery for rectosigmoidal and rectal carcinoma. Dis Colon Rectum. 2002;45(12):1648-54. Exclude non-U.S. data. [pmid: 12473889].
Yancik R, Wesley M, Ries L, et al. Comorbidity and Age s Predictors of Risk for Early Mortality of Male and Female Colon Carcinoma Patients. Cancer. 1998;82(11):2123-34. Exclude survival only. [pmid: 9610691].
Yancik R, Wesley MN, Ries LA, et al. Comorbidity and age as predictors of risk for early mortality of male and female colon carcinoma patients: a population-based study. Cancer. 1998;82(11):2123-34. Exclude no explicit QM. [pmid: 9610691].
Yee J. Screening CT colonography. Semin Ultrasound CT MR. 2003;24(1):12-22. Exclude review. [pmid: 12708640].
Yoong KK, Heymann T. Colonoscopy in the very old: why bother. Postgrad Med J. 2005;81(953):196-7. Exclude falls outside Task Order scope. [pmid: 15749799]. [pmcid: 1743224].
Zauber AG. Quality control for flexible sigmoidoscopy: which polyps count. Gastroenterology. 2004;126(5):1474-7. Exclude falls outside Task Order scope. [pmid: 15131808].
Zauber AG, Winawer SJ. Initial management and follow-up surveillance of patients with colorectal adenomas. Gastroenterol Clin North Am. 1997;26(1):85-101. Exclude review. [pmid: 9119442].
Zealley IA, Skehan SJ, Rawlinson J, et al. Selection of patients for resection of hepatic metastases: improved detection of extrahepatic disease with FDG pet. Radiographics. 2001;21(Spec No):S55-69. Exclude non-U.S. data. [pmid: 11598248].
Zelek L, Piedbois P, Buyse M. Contribution of meta-analyses to the evaluation of treatments for advanced colorectal cancer. Expert Rev Anticancer Ther. 2002;2(4):417-25. Exclude review. [pmid: 12647985].
Zenni GC, Abraham K, Harford FJ, et al. Characteristics of rectal carcinomas that predict the presence of lymph node metastases: implications for patient selection for local therapy. J Surg Oncol. 1998;67(2):99-103. Exclude no explicit QM. [pmid: 9486780].
Zielinski SL. Last decade brought new guidelines, detection methods for colon cancer screening. J Natl Cancer Inst. 2004;96(21):1575. Exclude review. [pmid: 15523085].
Zieren HU, Muller JM, Zieren J. Resection of colorectal liver metastases in old patients. Hepatogastroenterology. 1994;41(1):34-7. Exclude non-U.S. data. [pmid: 8175111].
Zieren HU, Muller JM, Zieren J, et al. The impact of patient's age on surgical therapy of colorectal liver metastases. Int Surg. 1993;78(4):288-91. Exclude non-U.S. data. [pmid: 8175253].
Ziogas A, Anton-Culver H. Validation of family history data in cancer family registries. Am J Prev Med. 2003;24(2):190-8. Exclude no explicit QM. [pmid: 12568826].
Zorcolo L, Covotta L, Carlomagno N, et al. Safety of primary anastomosis in emergency colo-rectal surgery. Colorectal Dis. 2003;5(3):262-9. Exclude non-U.S. data. [pmid: 12780890].