# Appendix B: Exact Search String

Database: Ovid MEDLINE(R) <1966 to January Week 1 2005> Search Strategy:

1 exp colorectal neoplasms/ or colonic neoplasms/ (83,325)
2 exp *“Quality of Health Care”/ (286,107)
3 exp *“Patient care management”/ (162,883)
4 exp *“Organization and Administration”/ (326,572)
5 exp *“health care quality, access, and evaluation”/ (521,870)
6 or/72,82,85,87 (810,834)
7 95 or age factors/ or african americans/ or specialties, surgical/ (1,067,364)
8 99 and 68 (5742)
9 limit 100 to (human and english language and yr=1990-2005) (3644)