# Appendix A: Quality of Life

## Methods of Assessing Quality of Life for Patients With Colorectal Cancer

When measuring quality of life for persons with colorectal cancer (CRC), most authors recommend the use of several instruments including a general instrument (e.g., SF-36, EQ-5D) that allows benchmarking against other conditions and a cancer-specific instrument that focuses on those aspects that are most salient to cancer. Ideally, the cancer-specific instrument would appropriately account for those aspects that are unique to CRC. Sprangers ^1^ and Provenzale and Gray ^2^ provide excellent reviews of the overall topic of how to assess quality of life in patients with CRC.

We describe various instruments that have been used in patients with CRC, including general health measures, cancer-specific measures, and CRC-specific measures. The general health measures and cancer-specific measures are listed and/or given only a very brief description. The CRC-specific measures are described, any validation efforts are noted, and the measures are rated.

## General Health Status Measures

Various American researchers (e.g., Anthony et al. ^3^ ) have tended to characterize the general health status of CRC patients using the Medical Outcome Study Short Form Health Survey (SF-36). ^4^ European researchers have also used the EQ-5D (e.g., Johnson et al. ^5^ ). Other general health status measures, such as the Sickness Impact Profile and the Nottingham Health Profile, have also been used from time to time. ^1^ Various studies (e.g., Weeks et al. ^6^ ) also use a single-item global measure of quality of life (e.g., “On a scale of 0–100, how do you rate your quality of life today?”), this latter measurement having the advantages of minimal respondent burden and being easily translated into a utility value usable within a cost-effectiveness analysis.

By design, it can reasonably be presumed that the validation efforts of these general health status instruments apply equally well to patients with CRC. For example, the eight dimensions of the SF-36 are physical functioning, physical role, pain, general health, vitality, social functioning, emotional role, and mental health, all of which are relevant to patients with CRC. Although it is helpful for many reasons to include a generic assessment of health-related quality of life, for the purposes of quality measurement its connection with the process of care is likely to be weaker than would be the corresponding connection with a measure that is more specific to CRC.

## Cancer-Related Measures

Sprangers ^1^ notes that among the cancer-specific measures most commonly applied to patients with CRC are the Functional Living Index-Cancer (FLIC), ^7^ the Rotterdam Symptom Checklist (RSCL), ^8^ and the European Organization for Research and Treatment of Cancer (EORTC) Core Quality of Life Questionnaire (QLQ-C30), ^9^ these latter two measures tending to be used in Europe and, as documented by Provenzale and Gray, ^2^ the most commonly used in practice. Additional cancer-specific measures include the Symptom Distress Scale, ^6^ the Quality of Life Index, ^6^ and the Functional Assessment of Cancer Therapy-General (FACT-G). ^10^

As an illustration of the nature of typical cancer-specific instruments, the 13-item Symptom Distress Scale ^6^ measures symptom frequency and distress in the domains of nausea, appetite, insomnia, pain, fatigue, bowel function, concentration, appearance, breathing, outlook, and cough, all with five response categories and a summary score using all items. The 5-item Quality of Life Index ^6^ measures quality of life in the domains of activity, daily living, health, support and outlook, all with three response categories, and a summary score using all items. The 22-item FLIC instrument ^7^ addresses physical well-being, social well-being, hardship due to cancer and nausea (all items are coded on a 1–7 scale). The FACT-G ^10^ is subdivided into seven items on physical well-being, seven items on social well-being, six items on emotional well-being, and seven items on functional well-being.

Chapman et al. ^11^ measured quality of life for 2,202 patients with ileal pouch-anal anastomosis (not all from cancer-related surgery) and applied a reasonable but not formally validated instrument to measure quality of life. The instrument measures constructs (sexual life, social, sports and work activities, family relationships) not on an absolute scale, but relative to the patient's status before surgery.

Ayanian et al. ^12^ conducted phone interviews of CRC patients obtained from a cancer registry in northern California using a 34-item instrument addressing emotional, social, physical and functional well-being. The instrument, with the exception of one question pertaining to bowel function, appears to be equally applicable to other cancer patients. The instrument successfully measures differences in satisfaction with care according to age, race, and sex, among other factors. With the possible exception of the instrument from which the candidate items were originally derived, the current version of this instrument has not been validated outside the context of this study.

As above, it can reasonably be presumed that the validation efforts of these cancer-specific quality-of-life instruments apply equally well to patients with CRC. It can also be presumed that the connection between quality of life as measured by these instruments and process of care is stronger than would be the case for general health instruments, but weaker than would be the case for CRC-specific instruments.

## CRC-Related Measures

Most investigators have adopted what Spangers ^1^ terms the “modular approach” to CRC-specific measures; that is, beginning with a general cancer-specific scale and adding items relevant to CRC. The most noteworthy examples are the FACT-C and the QLQ-CR38.

The FACT-C begins with the 27-item FACT-G scale (described in brief above), then adds a 9-item Colorectal Cancer Subscale (CCS). Two of the nine CCS items pertain to ostomy appliances and thus are not relevant to most CRC patients. In many applications, only the remaining seven items are used. Thus, the usual version of the FACT-C has 34 items (27 from the FACT-G and 7 from the CCS). Ward et al. ^10^ describe the validation of the FACT-C in 60 patients with advanced CRC and 156 patients with CRC but without distant metastases, these patients being sub-divided into 63 English-speakers and 93 Spanish-speakers. Separate analyses were also performed on the 29 patients in this latter sample. Standard techniques of psychometric analysis were applied, including an examination of internal consistency, convergent validity, divergent validity, the ability to distinguish among known groups, and sensitivity to change. Overall, the results strongly support the validity of the FACT-C.

The QLQ-CR38 uses the QLQ-C30 (discussed above), and adds 38 CRC-specific questions. Nineteen of these questions are answered by all respondents, and 19 depend on circumstances. Items are combined into sub-scales of micturition problems, gastrointestinal symptoms, side effects of chemotherapy, bowel problems, stoma-related problems, sexual problems, body image, and future-looking orientation. Validation was performed on 117 Dutch patients with CRC, and an English version is available. Overall, the results strongly support the validity of the instrument.

Schwenk et al. ^13^ compared results from the EORTC QLQ-C30 and the Gastrointestinal Quality of Life Index (GIQLI). Although the research was performed outside the United States (116 German patients undergoing surgery for CRC), to our knowledge this is the first formal comparison between the scales. The level of agreement between the instruments was low; the EORTC QLQ-C30 was found to be more sensitive in the detection of impairment of quality of life in the early post-operative period, causing the authors to recommend the EORTC QLQ-C30 as the preferred instrument.

Gupta et al. ^14^ validated the use of the subjective global assessment (SGA), a clinical technique that combines data from subjective and objective aspects of medical history and physical examination, in stage III and IV colorectal cancer patients, finding those with poorer SGA also had poorer survival.

Temple et al. ^15^ report on the development and initial validation of an instrument to evaluate bowel function after sphincter-preserving surgery for rectal cancer. Elements of validation, as applied to 184 patients undergoing sphincter-preserving surgery, included internal consistency, discriminant and construct validity, test-retest, and reliability. This 18-item, 5-response-category scale shows promising psychometric properties.

In addition to these formal CRC-related measures, various investigators have applied the above module-based thinking on an ad hoc basis. For example, Caffo et al. ^16^ created a self-administered diary card, recorded daily by 32 patients with rectal cancer, consisting of 10 clinically derived questions, nine of which (e.g., “Did you feel any nausea today?”) are coded on a scale of 1 to 4; the final question (“How many times have you had bowel movements today?”) is coded as an integer. Results were analyzed at the item level, and there was no total score. No formal validation of the measure was provided.

In a study comparing the quality-of-life experience of 44 patients undergoing surgery for benign colonic disease, 61 patients with CRC undergoing surgery alone, and 53 CRC patients undergoing both surgery and adjuvant therapy, Anthony et al. ^3^ added five CRC-specific questions to the SF-36, asking about appetite, weight, bowel function, urinary function, and whether the patient would repeat the same therapy as before. No formal validation was provided.

## Ratings

Rating only those measures that were formally developed in order assess CRC-related quality of life, both the FACT-C and the QLQ-CR38 can be rated as Importance 4, Usability 4, and Validity 4. Regarding importance, the salience of the items to quality of life with CRC is clear, the only negative for the purpose of quality measurement being the possibly weak link between process of care and quality of life. All measures are usable, except for very sick patients for whom respondent burden is a major issue, in which case a single-item general health scale might be preferred. In both cases, the validation of the parent measure has been extensive, and the validation of the CRC-related subscale less comprehensive but nevertheless quite encouraging.

## References for Appendix A

1 Sprangers MA. Quality-of-life assessment in colorectal cancer patients: evaluation of cancer therapies. Semin Oncol. 1999;26(6):691-6. [pmid: 10606262].
2 Provenzale D, Gray RN. Colorectal cancer screening and treatment: review of outcomes research. J Natl Cancer Inst Monogr 2004;(33):45–55.
3 Anthony T, Jones C, Antoine J, et al. The effect of treatment for colorectal cancer on long-term health-related quality of life. Ann Surg Oncol. 2001;8(1):44-9. [pmid: 11206224].
4 Ware JE, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992;30(6):473-83. [pmid: 1593914].
5 Johnson J, Luo N, Shar J, et al. Valuations of EQ-5D Health States: Are the United States and United Kingdon Different?. Med Care. 2005;43(3):221-8. [pmid: 15725978].
6 Weeks J, Nelson H, Gelber S, et al. Short-term quality of life outcomes following laparoscopic-assisted colectomy vs open colectomy for colon cancer: a randomized trial. JAMA. 2002;287(3):321-8. [pmid: 11790211].
7 Schipper H, Clinch J, McMurray A, et al. Measuring the quality of life of cancer patients: The Functional Living Index-Cancer: development and validation. J Clin Oncol. 1984;2(5):472-83. [pmid: 6374052].
8 de Haes JC, van Knippenberg FC, Neijt JP. Measuring psychological and physical distress in cancer patients: structure and application of the Rotterdam Symptom Checklist. Br J Cancer. 1990;62(6):1034-8. [pmid: 2257209].
9 Aaronson NK, Ahmedzai S, Bergman B, et al. The EORTC QLQ-C30: a quality-of-life instrument for use in international clinical trials in oncology. J Natl Cancer Inst. 1993;85(5):365-76. [pmid: 8433390].
10 Ward WL, Hahn EA, Mo F, et al. Reliability and validity of the Functional Assessment of Cancer Therapy-Colorectal (FACT-C) quality of life instrument. Qual Life Res. 1999;8(3):181-95. [pmid: 10472150].
11 Chapman JR, Larson DW, Wolff BG, et al. Ileal pouch-anal anastomosis: does age at the time of surgery affect outcome?. Arch Surg. 2005;140(6):534-9. discussion 539–40. [pmid: 15967900].
12 Ayanian JZ, Zaslavsky AM, Guadagnoli E, et al. Patient perceptions of quality of care for colorectal cancer by race, ethnicity, and language. J Clin Oncol 2005;23(27):TBD.
13 Schwenk W, Neudecker J, Haase O, et al. Comparison of EORTC quality of life core questionnaire (EORTC-QLQ-C30) and gastrointestinal quality of life index (GIQLI) in patients undergoing elective colorectal cancer resection. Int J Colorectal Dis. 2004;19(6):554-60. [pmid: 15205989].
14 Gupta D, Lammersfeld CA, Vashi PG, et al. Prognostic significance of Subjective Global Assessment (SGA) in advanced colorectal cancer. Eur J Clin Nutr. 2005;59(1):35-40. [pmid: 15252422].
15 Temple LK, Bacik J, Savatta SG, et al. The development of a validated instrument to evaluate bowel function after sphincter-preserving surgery for rectal cancer. Dis Colon Rectum. 2005;48(7):1353-65. [pmid: 15868235].
16 Caffo O, Amichetti M, Romano M, et al. Evaluation of toxicity and quality of life using a diary card during postoperative radiotherapy for rectal cancer. Dis Colon Rectum. 2002;45(4):459-65. discussion 465–7. [pmid: 12006925].