# Appendixes

Appendix A: Quality of Life

Appendix B: Exact Search String

Appendix C: List of Excluded Studies

Appendix D: Sample Data Abstraction Forms

Appendix E: Evidence Tables

Appendix F: Criteria Used To Assign Ratings to Quality Measures