# References Cited in the Evidence Report

1 American Cancer Society. Cancer facts & figures 2004. available at URL: http://www.cancer.org;docroot/STT/stt_0.asp. Accessed 7/10/2005.
2 McGlynn EA. Applying the strategic framework board's model to select national goals and core measures for stimulating improved care for cancer. 2002;RAND Health.
3 Jemal A, Clegg LX, Ward E, et al. Annual report to the nation on the status of cancer, 1975-2001, with a special feature regarding survival. Cancer. 2004;101(1):3-27. [pmid: 15221985].
4 Higginson IJ, Rajasekaran M, Davies E, Harding R, Gysels M. Improving supportive and palliative care for adults with cancer: research evidence manual. Accessed 7/10/2005.
5 Multinational association of supportive care in cancer. Accessed 7/10/2005.
6 WHO definition of palliative care. Accessed 7/10/2005.
7 Carr DB, Goudas LC, Balk EM, et al. Evidence report on the treatment of pain in cancer patients. J Natl Cancer Inst Monogr. 2004;(32):23-31.
8 Cleeland CS, Gonin R, Hatfield AK, et al. Pain and its treatment in outpatients with metastatic cancer. N Engl J Med. 1994;330(9):592-6. [pmid: 7508092].
9 de Rond M, de Wit R, van Dam F. The implementation of a Pain Monitoring Programme for nurses in daily clinical practice: results of a follow-up study in five hospitals. J Adv Nurs. 2001;35(4):590-8. [pmid: 11529959].
10 Carr D, Goudas L, Lawrence D, et al. Management of cancer symptoms: pain, depression, and fatigue. Rockville, MD: Agency for Healthcare Research and Quality. 2002.
11 Anderson KO, Richman SP, Hurley J, et al. Cancer pain management among underserved minority outpatients: perceived needs and barriers to optimal control. Cancer. 2002;94(8):2295-304. [pmid: 12001130].
12 Spector N, Klein D. Chronic critically ill dyspneic patients: mechanisms and clinical measurement. AACN Clinical Issues: Advanced Practice in Acute and Critical Care. 2001;12(2):220-33.
13 Silvestri GA. Palliation for the dying patient with lung cancer. Respir Care. 2000;45(12):1490-6. discussion 1497–500. [pmid: 11107215].
14 Dudgeon DJ, Lertzman M. Dyspnea in the advanced cancer patient. J Pain Symptom Manage. 1998;16(4):212-9. Comment in: J Pain Symptom Manage. 1999 Nov;18(5):313–5. PMID: 10584452. [pmid: 9803048].
15 Sorenson HM. Dyspnea assessment. Respir Care. 2000;45(11):1331-8. discussion 1338–41. [pmid: 11063521].
16 O'Driscoll M, Corner J, Bailey C. The experience of breathlessness in lung cancer. Eur J Cancer Care (Engl). 1999;8(1):37-43. [pmid: 10362952].
17 Dudgeon DJ, Kristjanson L, Sloan JA, et al. Dyspnea in cancer patients: prevalence and associated factors. Journal of Pain & Symptom Management. 2001;21(2):95-102. [pmid: 11226761].
18 Ahmedzai SH, Muers MFe. Supportive care in respiratory disease. Oxford University Press; 2005.
19 Hollen PJ, Gralla RJ, Kris MG, et al. Normative data and trends in quality of life from the Lung Cancer Symptom Scale (LCSS). Support Care Cancer. 1999;7(3):140-8. [pmid: 10335932].
20 Mancini I, Body JJ. Assessment of dyspnea in advanced cancer patients. Support Care Cancer. 1999;7(4):229-32. [pmid: 10423048].
21 Lorenz K, Lynn J, Morton SC, et al. End-of-life care and outcomes. Evid Rep Technol Assess (Summ). 2004;(110):1-6.
22 Polsky D, Doshi JA, Marcus S, et al. Long-term risk for depressive symptoms after a medical diagnosis. Arch Intern Med. 2005;165(11):1260-6. [pmid: 15956005].
23 Aukst-Margetic B, Jakovljevic M, Margetic B, et al. Religiosity, depression and pain in patients with breast cancer. Gen Hosp Psychiatry. 2005;27(4):250-5. [pmid: 15993256].
24 Koenig HG, George LK, Peterson BL. Religiosity and remission of depression in medically ill older patients. Am J Psychiatry. 1998;155(4):536-42. [pmid: 9546001].
25 Fehring RJ, Miller JF, Shaw C. Spiritual well-being, religiosity, hope, depression, and other mood states in elderly people coping with cancer. Oncol Nurs Forum. 1997;24(4):663-71. [pmid: 9159782].
26 Johnson KS, Elbert-Avila KI, Tulsky JA. The influence of spiritual beliefs and practices on the treatment preferences of African Americans: a review of the literature. J Am Geriatr Soc. 2005;53(4):711-9. [pmid: 15817022].
27 Teno JM, Lynn J. Putting advance-care planning into action. J Clin Ethics. 1996;7(3):205-13. [pmid: 8981191].
28 Fisher ES, Wennberg DE, Stukel TA, et al. The implications of regional variations in Medicare spending. Part 1: the content, quality, and accessibility of care. Ann Intern Med. 2003;138(4):273-87. [pmid: 12585825].
29 Fisher ES, Wennberg DE, Stukel TA, et al. The implications of regional variations in Medicare spending. Part 2: health outcomes and satisfaction with care. Ann Intern Med. 2003;138(4):288-98. [pmid: 12585826].
30 Wennberg JE, Fisher ES, Stukel TA, et al. Use of hospitals, physician visits, and hospice care during last six months of life among cohorts loyal to highly respected hospitals in the United States. BMJ. 2004;328(7440):607. [pmid: 15016692]. [pmcid: 381130].
31 Steinhauser KE, Christakis NA, Clipp EC, et al. Factors considered important at the end of life by patients, family, physicians, and other care providers. JAMA. 2000;284(19):2476-82. [pmid: 11074777].
32 Donabedian A. The criteria and standards for quality. Chicago, IL: Health Administration Press. 1981.
33 Merrian-Webster online. available at URL: www.mirriam-webster.com. Accessed 7/13/2005 (http://www.mirriam-webster.com).
34 World Health Organization (WHO). Cancer pain relief and palliative care in children. 1998.
35 Chodosh J, Buckwalter JG, Blazer DG, et al. How the question is asked makes a difference in the assessment of depressive symptoms in older persons. Am J Geriatr Psychiatry. 2004;12(1):75-83. [pmid: 14729562].
36 Lorenz KA, Shapiro MF, Asch SM, et al. Associations of symptoms and health-related quality of life: findings from a national study of persons with HIV infection. Ann Intern Med. 2001;134(9 Pt 2):854-60. [pmid: 11346321].
37 Sackett DL. The rational clinical examination. A primer on the precision and accuracy of the clinical examination. JAMA. 1992;267(19):2638-44. [pmid: 1573753].
38 Walter LC, Davidowitz NP, Heineken PA, et al. Pitfalls of converting practice guidelines into quality measures: lessons learned from a VA performance measure. JAMA. 2004;291(20):2466-70. [pmid: 15161897].
39 Dubey S, Brown RL, Esmond SL, et al. Patient preferences in choosing chemotherapy regimens for advanced non-small cell lung cancer. J Support Oncol. 2005;3(2):149-54. [pmid: 15796447].
40 Ferrell BA, Ferrell BR, Rivera L. Pain in cognitively impaired nursing home patients. J Pain Symptom Manage. 1995;10(8):591-8. [pmid: 8594119].
41 Emanuel EJ, Fairclough DL, Emanuel LL. Attitudes and desires related to euthanasia and physician-assisted suicide among terminally ill patients and their caregivers. JAMA. 2000;284(19):2460-8. [pmid: 11074775].
42 Ditto PH, Smucker WD, Danks JH, et al. Stability of older adults' preferences for life-sustaining medical treatment. Health Psychol. 2003;22(6):605-15. [pmid: 14640858].
43 Danis M, Garrett J, Harris R, et al. Stability of choices about life-sustaining treatments. Ann Intern Med. 1994;120(7):567-73. [pmid: 8116994].
44 Dept. of Clinical Quality Improvement. Clinical practice guidelines directory. Chicago, IL: American Medical Association. 1999.
45 U.S. Preventive Services Task Force. Guide to clinical and preventive services. Alexandria, VA: International Medical Pub. 1996.
46 Committee on Performance Measurement. HEDIS 2005: Health plan employer data & information set. Washington, DC: National Committee for Quality Assurance. 2005.
47 1998 The medical outcomes and guidelines sourcebook. New York, NY: Faulkner & Gray; 1997.
48 Clinical process and outcomes measurement directory, 1999 edition. Chicago, IL: American Medical Association; 1999.
49 Behavioral outcomes and guidelines sourcebook, 2000 ed. New York, NY: Faulkner & Gray; 1999.
50 Appraisal of guidelines research & evaluation. available at URL: www.agreecollaboration.org. Accessed 6/30/2005.
51 Shaneyfelt TM, Mayo-Smith MF, Rothwangl J. Are guidelines following guidelines? The methodological quality of clinical practice guidelines in the peer-reviewed medical literature. JAMA. 1999;281(20):1900-5. [pmid: 10349893].
52 McGlynn EA, Malin J. Selecting national goals and core measures of cancer care quality (Background paper #2). RAND 2002.
53 Connor SR, Teno J, Spence C, et al. Family evaluation of hospice care: results from voluntary submission of data via website. J Pain Symptom Manage. 2005;30(1):9-17. [pmid: 16043002].
54 Ryndes T, Connor S, Cody C, Merriman M, Bruno S, Fine P, et al. Report on the alpha and beta pilots of end result outcome measures constructed by the outcomes forum.
55 National Cancer Policy Board (NCPB). Assessing the quality of cancer care: an approach to measurement in Georgia.: The National Academies Press. 2005.
56 Greenberg A, Angus H, Sullivan T, et al. Development of a set of strategy-based system-level cancer care performance indicators in Ontario, Canada. Int J Qual Health Care 2005.
57 Cancer Care Ontario. Cancer system quality index: satisfaction with pain management. Ontario, Canada: Cancer Care Ontario. 2005.
58 Chodosh J, Solomon DH, Roth CP, et al. The quality of medical care provided to vulnerable older patients with chronic pain. J Am Geriatr Soc. 2004;52(5):756-61. [pmid: 15086657].
59 Wenger NS, Rosenfeld K. Quality indicators for end-of-life care in vulnerable elders. Ann Intern Med. 2001;135(8 Pt 2):677-85. [pmid: 11601950].
60 Saliba D, Solomon D, Rubenstein L, et al. Feasibility of quality indicators for the management of geriatric syndromes in nursing home residents. J Am Med Dir Assoc. 2004;5(5):310-9. [pmid: 15357888].
61 Erdek MA, Pronovost PJ. Improving assessment and treatment of pain in the critically ill. Int J Qual Health Care. 2004;16(1):59-64. [pmid: 15020561].
62 Pronovost PJ , Berenholtz SM. A practical guide to measuring performance in the intensive care unit.: VHA. 2002.
63 National Hospice and Palliative Care Organization (NHPCO). Instructions for use of the six measures.
64 In: Asch SM, Kerr EA, Hamilton EG, Reifel JL, McGlynn EA. Quality of care for oncologic condition and HIV: a review of the literature and quality indicators. RAND; 2000.
65 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-45. [pmid: 12826639].
66 Asch SM, McGlynn EA, Hogan MM, et al. Comparison of quality of care for patients in the Veterans Health Administration and patients in a national sample. Ann Intern Med. 2004;141(12):938-45. [pmid: 15611491].
67 Maxwell T, Cuny J. The UHC palliative care benchmarking project. University Health System Consortium 2004;1–35.
68 VHA. Transformation of the Intensive Care Unit. Palliative Care Bundle: Care and Communication Measurement Guide. 2005.
69 Clinical practice guidelines for quality palliative care.: National Consensus Project for Quality Palliative Care. 2004.
70 Kress JP, Pohlman AS, O'Connor MF, et al. Daily interruption of sedative infusions in critically ill patients undergoing mechanical ventilation. N Engl J Med. 2000;342(20):1471-7. [pmid: 10816184].
71 Neuss MN, Desch CE, McNiff KK, et al. A process for measuring the quality of cancer care: the Quality Oncology Practice Initiative. J Clin Oncol. 2005;23(25):6233-9. [pmid: 16087948].
72 Wenger NS, Solomon DH, Roth CP, et al. The quality of medical care provided to vulnerable community-dwelling older patients. Ann Intern Med. 2003;139(9):740-7. [pmid: 14597458].
73 McNicol E, Horowicz-Mehler N, Fisk RA, et al. Management of opioid side effects in cancer-related and chronic noncancer pain: a systematic review. J Pain. 2003;4(5):231-56. [pmid: 14622694].
74 Gordon DB, Dahl JL, Miaskowski C, et al. American pain society recommendations for improving the quality of acute and cancer pain management: American Pain Society Quality of Care Task Force. Arch Intern Med. 2005;165(14):1574-80. [pmid: 16043674].
75 Wu JS, Wong R, Johnston M, Bezjak A, Whelan T, Laetsch N , et al. Radiotherapy fractionation for the palliation of uncomplicated painful bone metastases.: Program in Evidence-Based Care. 2003.
76 Sze WM, Shelley MD, Held I, et al. Palliation of metastatic bone pain: single fraction versus multifraction radiotherapy--a systematic review of randomised trials. Clin Oncol (R Coll Radiol). 2003;15(6):345-52. [pmid: 14524489].
77 Grunfeld E, et al. Nova Scotia and Ontario quality end of life indicators project. 2005.
78 Roque M, Martinez MJ, Alonso P, et al. Radioisotopes for metastatic bone pain. Cochrane Database Syst Rev 2003;(4):CD003347.
79 Connor SR, Tecca M, LundPerson J, et al. Measuring hospice care: the National Hospice and Palliative Care Organization National Hospice Data Set. J Pain Symptom Manage. 2004;28(4):316-28. [pmid: 15471649].
80 National Comprehensive Cancer Network (NCCN). Cancer pain. Clinical Practice Guidelines in Oncology 2004;(1)
81 Maasilta P. Palliative treatment of a patient with lung cancer. EBM Guidelines. Duodecim Medical Publications 2004.
82 Oncology Nursing Society. Cancer pain management. 2004.
83 Quality improvement guidelines for the treatment of acute pain and cancer pain. American Pain Society Quality of Care Committee. JAMA 1995;274(23):1874–80.
84 NIH State-of-the-Science Statement on symptom management in cancer: pain, depression, and fatigue. NIH Consens State Sci Statements 2002;19(4):1–29.
85 Rhodes DJ, Koshy RC, Waterfield WC, et al. Feasibility of quantitative pain assessment in outpatient oncology practice. J Clin Oncol. 2001;19(2):501-8. [pmid: 11208844].
86 Cleeland CS, Gonin R, Baez L, et al. Pain and treatment of pain in minority patients with cancer. The Eastern Cooperative Oncology Group Minority Outpatient Pain Study. Ann Intern Med. 1997;127(9):813-6. [pmid: 9382402].
87 Bernabei R, Gambassi G, Lapane K, et al. Management of pain in elderly patients with cancer. SAGE Study Group. Systematic Assessment of Geriatric Drug Use via Epidemiology. JAMA. 1998;279(23):1877-82. [pmid: 9634258].
88 Green CR, Anderson KO, Baker TA, et al. The unequal burden of pain: confronting racial and ethnic disparities in pain. Pain Med. 2003;4(3):277-94. [pmid: 12974827].
89 Stolee P, Hillier LM, Esbaugh J, et al. Instruments for the assessment of pain in older persons with cognitive impairment. J Am Geriatr Soc. 2005;53(2):319-26. [pmid: 15673359].
90 Duhn LJ, Medves JM. A systematic integrative review of infant pain assessment tools. Adv Neonatal Care. 2004;4(3):126-40. [pmid: 15273943].
91 Morrison RS, Magaziner J, Gilbert M, et al. Relationship between pain and opioid analgesics on the development of delirium following hip fracture. J Gerontol A Biol Sci Med Sci. 2003;58(1):76-81. [pmid: 12560416].
92 Lloyd-Williams M, Dennis M, Taylor F. A prospective study to determine the association between physical symptoms and depression in patients with advanced cancer. Palliat Med. 2004;18(6):558-63. [pmid: 15453627].
93 Gordon DB, Pellino TA, Miaskowski C, et al. A 10-year review of quality improvement monitoring in pain management: recommendations for standardized outcome measures. Pain Manag Nurs. 2002;3(4):116-30. [pmid: 12454804].
94 Allard P, Maunsell E, Labbe J, et al. Educational interventions to improve cancer pain control: a systematic review. J Palliat Med. 2001;4(2):191-203. [pmid: 11441627].
95 Marinangeli F, Ciccozzi A, Leonardis M, et al. Use of strong opioids in advanced cancer pain: a randomized trial. J Pain Symptom Manage. 2004;27(5):409-16. [pmid: 15120769].
96 Jacox A, Carr DB, Payne R, et al. Management of cancer pain. Clinical practice guideline 9. Rockville, MD: US Department of Health and Human Services, Public Health Service, AHRQ. 1994.
97 American Geriatrics Society Clinical Practice C. Management of cancer pain in older patients. Journal of the American Geriatrics Society. 1997;45(10):1273-1276. URL http//www.blackwell-science.com/~cgilib/bsinc.bin?Journal=geriatrics. [pmid: 9329493].
98 Foster RL, Varni JW. Measuring the quality of children's postoperative pain management: initial validation of the Child/Parent Total Quality Pain Management (TQPM) instruments. Journal of Pain and Symptom Management. 2002;23(3):201-10. [pmid: 11888718].
99 Taddio A, Soin HK, Schuh S, et al. Liposomal lidocaine to improve procedural success rates and reduce procedural pain among children: a randomized controlled trial. CMAJ. 2005;172(13):1691-5. [pmid: 15967972]. [pmcid: 1150261].
100 Faber-Langendoen K. The clinical management of dying patients receiving mechanical ventilation. A survey of physician practice. Chest. 1994;106(3):880-8. [pmid: 8082372].
101 Wenger NS, Belamy PE, Phillips RS, et al. Variation in withdrawing the ventilator from dying patients. J Gen Intern Med. 1997;12(Suppl 1):105.
102 Brody H, Campbell ML, Faber-Langendoen K, et al. Withdrawing intensive life-sustaining treatment -- recommendations for compassionate clinical management. N Engl J Med. 1997;336(9):652-7. [pmid: 9032053].
103 Campbell ML. Forgoing life-sustaining therapy. Aliso Viejo, CA: AACN Critical Care Publication. 1998.
104 Anonymous. Withholding and withdrawing lifesustaining therapy: this official statement of the American Thoracic Society was adopted by the ATS Board of Directors, March 1991. Am Rev Respir Dis 1991;144(3 Pt 1):726–31.
105 Faber-Langendoen K, Lanken PN. Dying patients in the intensive care unit: forgoing treatment, maintaining care. Ann Intern Med. 2000;133(11):886-93. [pmid: 11103059].
106 Malin JL, Asch SM, Kerr EA, et al. Evaluating the quality of cancer care: development of cancer quality indicators for a global quality assessment tool. Cancer. 2000;88(3):701-7. [pmid: 10649266].
107 Golomb B. Chronic obstructive pulmonary disease. In: Kerr EA, Asch SM, Hamilton EG, McGlynn EA. Quality of care for cardiopulmonary conditions: a review of the literature and quality indicators. RAND; 2000. p. 91–109.
108 Booth S, Wade R, Johnson M, et al. The use of oxygen in the palliation of breathlessness. A report of the expert working group of the Scientific Committee of the Association of Palliative Medicine. Respir Med. 2004;98(1):66-77. [pmid: 14959816].
109 Dyspnea. Mechanisms, assessment, and management: a consensus statement. American Thoracic Society. Am J Respir Crit Care Med 1999;159( 1):321–40.
110 Kvale PA, Simoff M, Prakash UB. Lung cancer. Palliative care. Chest. 2003;123(1 Suppl):284S-311S. [pmid: 12527586].
111 Ferguson GT, Enright PL, Buist AS, et al. Office spirometry for lung health assessment in adults: a consensus statement from the National Lung Health Education Program. Chest. 2000;117(4):1146-61. [pmid: 10767253].
112 Jennings AL, Davies AN, Higgins JP, et al. Opioids for the palliation of breathlessness in terminal illness. Cochrane Database Syst Rev 2001;(4):CD002066.
113 Pfister DG, Johnson DH, Azzoli CG, et al. American Society of Clinical Oncology treatment of unresectable non-small-cell lung cancer guideline: update 2003. J Clin Oncol. 2004;22(2):330-53. [pmid: 14691125].
114 Socinski MA, Morris DE, Masters GA, et al. Chemotherapeutic management of stage IV non-small cell lung cancer. Chest. 2003;123(1 Suppl):226S-243S. [pmid: 12527582].
115 Lacasse Y, Brosseau L, Milne S, et al. Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database Syst Rev 2002;(3):CD003793 .
116 Jennings A-L, Davies AN, Higgins JPT, et al. A systematic review of the use of opioids in the management of dyspnea. Thorax. 2002;(57):939-44.
117 Nakajima GA, Wenger NS. Quality indicators for the care of depression in vulnerable elders. RAND.
118 Chow TW, MacLean CH. Quality indicators for dementia in vulnerable community-dwelling and hospitalized elders. Ann Intern Med. 2001;135(8 Pt 2):668-76. [pmid: 11601949].
119 Cancer Care Ontario. Cancer system quality index: patterns of end-of-life care. Ontario, Canada: Cancer Care Ontario. 2005.
120 Cancer Care Ontario. Cancer system quality index: hospital resources used during each phase of cancer care. Ontario, Canada: Cancer Care Ontario. 2005.
121 Hanson LC, Tulsky JA, Danis M. Can clinical interventions change care at the end of life?. Ann Intern Med. 1997;126(5):381-8. [pmid: 9054283].
122 Fisher GS, Tulsky JA, Rose MR, et al. Patient knowledge and physician predictions of treatment preferences after discussion of advance directives. J Gen Intern Med. 1998;13:447-54. [pmid: 9686710]. [pmcid: 1496983].
123 White DB, Luce JM. Palliative care in the intensive care unit: barriers, advances, and unmet needs. Crit Care Clin 2004;20(3):329–43, vii.
124 Wenger NS, Phillips RS, Teno JM, et al. Physician understanding of patient resuscitation preferences: insights and clinical implications. J Am Geriatr Soc. 2000;48(5 Suppl):S44-51. [pmid: 10809456].
125 Teno JM, Hakim RB, Knaus WA, et al. A prospective study of advance directives for life-sustaining care. N Engl J Med. 1991;324:882-8. [pmid: 2000110].
126 Danis M, Southerland LI, Garrett JM, et al. A prospective study of advance directives for life-sustaining care. N Engl J Med. 1991;324(13):882-8. [pmid: 2000110].
127 Blasi ZV, Hurley AC, Volicer L. End-of-life care in dementia: a review of problems, prospects, and solutions in practice. Journal of the American Medical Directors Association. 2002;3(2):57-65. [pmid: 12807540].
128 Sulmasy DP, Dwyer M, Marx E. Do the ward notes reflect the quality of end-of-life care?. J Med Ethics. 1996;22(6):344-8. [pmid: 8961119]. [pmcid: 1377116].
129 Cherry DL, Vickrey BG, Schwankovsky L, et al. Interventions to improve quality of care: the Kaiser Permanente-alzheimer's Association Dementia Care Project. Am J Manag Care. 2004;10(8):553-60. [pmid: 15352531].
130 Prendergast TJ, Luce JM. Increasing incidence of withholding and withdrawal of life support from the critically ill. Am J Respir Crit Care Med. 1997;155(1):15-20. [pmid: 9001282].
131 National Comprehensive Cancer Network (NCCN). Palliative care. Clinical Practice Guidelines in Oncology 2004;(1).
132 Cook DJ, Guyatt G, Rocker G, et al. Cardiopulmonary resuscitation directives on admission to intensive-care unit: an international observational study. Lancet. 2001;358(9297):1941-5. [pmid: 11747918].
133 Teno JM, Fisher E, Hamel MB, et al. Decision-making and outcomes of prolonged ICU stays in seriously ill patients. J Am Geriatr Soc. 2000;48(5 Suppl):S70-4. [pmid: 10809459].
134 Treece PD, Engelberg RA, Crowley L, et al. Evaluation of a standardized order form for the withdrawal of life support in the intensive care unit. Crit Care Med. 2004;32(5):1141-8. [pmid: 15190964].
135 Lilly CM, De Meo DL, Sonna LA, et al. An intensive communication intervention for the critically ill. Am J Med. 2000;109(6):469-75. [pmid: 11042236].
136 Azoulay E, Pochard F, Chevret S, et al. Impact of a family information leaflet on effectiveness of information provided to family members of intensive care unit patients: a multicenter, prospective, randomized, controlled trial. Am J Respir Crit Care Med. 2002;165(4):438-42. [pmid: 11850333].
137 Volicer L. Management of severe Alzheimer's disease and end-of-life issues. Clin Geriatr Med. 2001;17(2):377-91. [pmid: 11375141].
138 Sulmasy DP, Sood JR, Ury WA. The quality of care plans for patients with do-not-resuscitate orders. Arch Intern Med. 2004;164(14):1573-8. [pmid: 15277292].
139 Prendergast TJ. Advance care planning: pitfalls, progress, promise. Crit Care Med. 2001;29(2 Suppl):N34-9. [pmid: 11228571].
140 Bradley EH, Hallemeier AG, Fried TR, et al. Documentation of discussions about prognosis with terminally ill patients. Am J Med. 2001;111(3):218-23. [pmid: 11530033].
141 Song MK. Effects of end-of-life discussions on patients' affective outcomes. Nurs Outlook. 2004;52(3):118-25. [pmid: 15197360].
142 Virmani J, Schneiderman LJ, Kaplan RM. Relationship of advance directives to physician-patient communication. Arch Intern Med. 1994;154(8):909-13. [pmid: 8154954].
143 Goodman MD, Tarnoff M, Slotman GJ. Effect of advance directives on the management of elderly critically ill patients. Crit Care Med. 1998;26(4):701-4. [pmid: 9559607].
144 Gregory JJ, Dunn D. Implementation of the Patient Self-Determination Act in a community hospital. N J Med. 1995;92(7):438-42. [pmid: 7659304].
145 Morrison RS, Olson E, Mertz KR, et al. The inaccessibility of advance directives on transfer from ambulatory to acute care settings. JAMA. 1995;274(6):478-82. [pmid: 7629957].
146 Earle CC, Park ER, Lai B, et al. Identifying potential indicators of the quality of end-of-life cancer care from administrative data. J Clin Oncol. 2003;21(6):1133-38. [pmid: 12637481].
147 Hawryluck LA, Harvey WR, Lemieux-Charles L, et al. Consensus guidelines on analgesia and sedation in dying intensive care unit patients. BMC Med Ethics. 2002;3(1):E3. [pmid: 12171602].
148 Clarke EB, Curtis JR, Luce JM, et al. Quality indicators for end-of-life care in the intensive care unit. Crit Care Med. 2003;31(9):2255-62. [pmid: 14501954].
149 A controlled trial to improve care for seriously ill hospitalized patients. The study to understand prognoses and preferences for outcomes and risks of treatments (SUPPORT). The SUPPORT Principal Investigators. JAMA 1995;274(20):1591–8.
150 Earle CC, Neville BA, Landrum MB, et al. Evaluating claims-based indicators of the intensity of end-of-life cancer care.
151 Teno J, Lynn J, Wenger N, et al. Advance directives for seriously ill hospitalized patients: effectiveness with the patient self-determination act and the SUPPORT intervention. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Am Geriatr Soc. 1997;45(4):500-7. Comment in: J Am Geriatr Soc. 1997 Apr;45(4):519–20. PMID: 9100724. [pmid: 9100721].
152 Dokken DL, Heller KS, Levetown M, et al. Quality domains, goals and indicators for family-centered care of children living with life-threatening conditions. Education Development Center, Inc. 2002.
153 Widger KA, Wilkins K. What are the key components of quality perinatal and pediatric end-of-life care? A literature review. J Palliat Care. 2004;20(2):105-12. [pmid: 15332475].
154 Masera G, Spinetta JJ, Jankovic M, et al. Guidelines for assistance to terminally ill children with cancer: a report of the SIOP Working Committee on psychosocial issues in pediatric oncology. Med Pediatr Oncol. 1999;32(1):44-8. [pmid: 9917752].
155 American Academy of Pediatrics. Committee on Bioethics and Committee on Hospital Care. Palliative care for children. Pediatrics. 2000;106(2 Pt 1):351-7. [pmid: 10920167].
156 Standards and Quality Committee. Standards for palliative care provision. Australia. 1999.
157 Mitchell SL, Berkowitz RE, Lawson FME, et al. A cross-national survey of tube-feeding decisions in cognitively impaired older persons. Journal of the American Geriatrics Society. 2000;48(4):391-7. [pmid: 10798465].
158 Connor SR, Teno J, Spence C, Smith N. Family evaluation of hospice care: results from voluntary submission of data over website.
159 Fortner BV, Okon TA, Ashley J, et al. The Zero Acceptance of Pain (ZAP) Quality Improvement Project: evaluation of pain severity, pain interference, global quality of life, and pain-related costs. J Pain Symptom Manage. 2003;25(4):334-43. [pmid: 12691685].
160 Cleeland CS, Reyes-Gibby CC, Schall M, et al. Rapid improvement in pain management: the Veterans Health Administration and the institute for healthcare improvement collaborative. Clin J Pain. 2003;19(5):298-305. [pmid: 12966255].
161 Mittman BS. Creating the evidence base for quality improvement collaboratives. Ann Intern Med. 2004;140(11):897-901. [pmid: 15172904].
162 Ljubisavljevic V, Kelly B. Risk factors for development of delirium among oncology patients. Gen Hosp Psychiatry. 2003;25(5):345-52. [pmid: 12972226].
163 Gagnon P, Allard P, Masse B, et al. Delirium in terminal cancer: a prospective study using daily screening, early diagnosis, and continuous monitoring. J Pain Symptom Manage. 2000;19(6):412-26. [pmid: 10908822].
164 Lawlor PG, Gagnon B, Mancini IL, et al. Occurrence, causes, and outcome of delirium in patients with advanced cancer: a prospective study. Arch Intern Med. 2000;160(6):786-94. [pmid: 10737278].
165 Johnson VM, Teno JM, Bourbonniere M, et al. Palliative care needs of cancer patients in U.S. nursing homes. J Palliat Med. 2005;8(2):273-9. [pmid: 15890038].
166 Taylor LJ, Harris J, Epps CD, et al. Psychometric evaluation of selected pain intensity scales for use with cognitively impaired and cognitively intact older adults. Rehabil Nurs. 2005;30(2):55-61. [pmid: 15789697].
167 Scherder E, Oosterman J, Swaab D, et al. Recent developments in pain in dementia. BMJ. 2005;330(7489):461-4. [pmid: 15731144]. [pmcid: 549660].
168 National Center for Health Statistics. Deaths, percentage of total deaths, and death rates for the 10 leading causes of death in selected age groups by race and sex: United States, 2002. available at URL: http://www.cdc.gov/nchs/fastats/pdf/nvsr53_17t1.pdf. Accessed 7/21/2005.
169 Wolfe J, Grier HE, Klar N, et al. Symptoms and suffering at the end of life in children with cancer. N Engl J Med. 2000;342(5):326-33. [pmid: 10655532].
170 Klopfenstein KJ, Hutchison C, Clark C, et al. Variables influencing end-of-life care in children and adolescents with cancer. J Pediatr Hematol Oncol. 2001;23(8):481-6. [pmid: 11878774].
171 Levetown M, Dokken D, Heller KS, et al. A Pediatric Palliative Care Institutional Self-Assessment Tool (ISAT). Education Development Center, Inc 2002.
172 Beal AC, Co JP, Dougherty D, et al. Quality measures for children's health care. Pediatrics. 2004;113(1 Pt 2):199-209. [pmid: 14702502].
173 Hooke C, Hellsten MB, Stutzer C, et al. Pain management for the child with cancer in end-of-life care: APON position paper. Journal of Pediatric Oncology Nursing. 2002;19(2):43-7. [pmid: 11973705].
174 Treadwell MJ, Franck LS, Vichinsky E. Using quality improvement strategies to enhance pediatric pain assessment. Int J Qual Health Care. 2002;14(1):39-47. [pmid: 11871628].
175 American Pain Society (APS). Guideline for the management of cancer pain in adults and children. 2005.
176 Agency for Healthcare Research and Quality. List of Measures: National Healthcare Quality Report 2004. available at URL: http://www.qualitytools.ahrq.gov/qualityreport/browse/browse.aspx. Accessed 7/21/2005.