# Executive Summary

## Overview

Cancer is a common, costly problem that affects many Americans and their families. Approximately 9.6 million Americans who were alive in January 2000 were estimated to be living with a previous diagnosis of cancer, and approximately 1.4 million cases of cancer were diagnosed in 2004. Direct medical expenditures on cancer exceeded $180 billion in 2000. The most common malignancies include lung, breast, colorectal, and prostate, for which 2003 estimates of 5-year survival rates varied from 15% (lung) to 99% (prostate).

Cancer imposes its burdens from diagnosis to death, and even survivors live with substantial impairments; therefore, supportive care is an important consideration of all phases of management. Supportive care addresses the direct and treatment-related impacts of cancer including, pain, and symptom management; the psychosocial context, including spirituality; and caregiving. Supportive approaches focus on assisting patients and caregivers to maximize well-being and can ameliorate many of the debilitating consequences of living with a cancer diagnosis, regardless of cancer stage. As early diagnosis and more effective treatment extend the experience of living with cancer, seamless integration of supportive principles and approaches becomes even more imperative.

In spite of the prevalence of cancer and its enormous costs, little effort has been made to systematize the assessment of the quality of palliative cancer care. AHRQ and a collaborative of Federal Partners, including the Centers for Disease Control and Prevention (CDC), the Centers for Medicare & Medicaid Services (CMS), and the National Cancer Institute (NCI), requested a systematic review of quality measures for supportive cancer care. This report, prepared by the Southern California Evidence-Based Practice Center, is intended to assist the National Quality Forum (NQF) by describing quality measures in the areas of pain, dyspnea, depression, and advance care planning (ACP) and to identify priorities for a quality measurement research agenda.

### Reporting the Evidence

This report addressed the following questions:

- 1. What quality-of-care measures are available and what evidence supports those measures to assess pain, depression, dyspnea, and advance care planning for patients with cancer, including:
  - a. Patient assessment,
  - b. Intervention and appropriate management, and
  - c. Timeliness and effectiveness of intervention.
- 2. What gaps in knowledge about quality measurement are evident from the currently available literature, including absence of measures or measures lacking evidence of their scientific soundness, whether for the population of cancer patients as a whole or for specific subpopulations?

## Methodology

In consultation with the AHRQ Task Order Officer (TOO) and the NQF, we created a Technical Expert Panel (TEP) of leading scientists and clinicians with expertise in oncology and palliative medicine and a broad knowledge of research and policy issues in the field of oncology and palliative care in the United States to guide the evidence report. Project staff worked closely with AHRQ, NQF, and the TEP to refine the research questions and focus on the relevant outcomes. Drs. Karl Lorenz and Joanne Lynn met with the NQF and members of their Steering Committee in December 2004 to discuss the task order question and plans for the systematic review.

Originally, Question 1 specified focusing on “measures to assess pain, depression, distress, and advance care planning.” However, the Committee indicated that distress had been incorporated in order to address broad psychosocial and spiritual concerns. However, the group expressed concerns relative to the feasibility of conducting a systematic review of distress. They also agreed that the broader spiritual and psychosocial concerns could be taken into account in conducting the literature review of depression measures. Because dyspnea is an important symptom among cancer patients and a recent systematic review found promising evidence related to its treatment, the Committee recommended that RAND should add dyspnea as a topic. After consulting with the AHRQ Task Order Officer, the review team agreed to focus on pain, depression, dyspnea, and advance care planning.

The first of a series of calls was held on February 9, 2005 with our TOO and the TEP. An important issue that arose for discussion during our initial conference call with the TOO and TEP in February 2005 was the extent to which searches should be restricted to cancer. Limiting the search logic to cancer provided an extremely limited number of references, particularly for ACP and dyspnea quality measures. Our TEP advised that measures that were applied to the care of symptoms and advance planning in other disease states would also be relevant to cancer; thus, for those two topics, we broadened the search to include conditions other than cancer. However, because our initial searches indicated that the literature on pain and depression was extensive, we restricted our review of these citations to cancer only.

### Literature Search and Review

We searched MEDLINE^®^, CINAHL^©^, and PsycINFO^©^ for English language literature (January 1995 - February 2005) using terms for pain, dyspnea, depression, and ACP combined with terms for cancer, quality assessment or improvement, and palliative care. Because our previous experience identified limitations in the indexing of quality measures in scientific databases, we used pre-specified terms to search the Internet for evidence-based standards or quality measures that had been developed by healthcare organizations or specialty societies. (February to March 2005). We directly contacted developers of all measures or measure sets we identified and sought additional information using a ‘contact form.’

### Study Selection and Abstraction

Six reviewers, with clinical backgrounds in internal medicine and nursing, and research careers in palliative care, organized into four teams by domain, each reviewed documents independently, resolving disagreement by consensus. We applied the following inclusion and exclusion criteria at both the title/abstract and article screening phases. Study reports or other documents were accepted only if they contained either indicators or measures. An indicator was defined as “a descriptive statement with a normative relationship to quality that includes a numerator and denominator and that is expressed as a measurable standard.” A measure is an indicator fully specified for measurement, including data elements, the data collection approach, data sources, analysis, and presentation.

Documents were excluded if they:

- Were non-Western (i.e., not United States, Canada, Australia, New Zealand, Great Britain, or European),
- Were published in a non-English language,
- Focused exclusively on a disease other than cancer UNLESS they were on the topic of pain or depression, or
- Focused on cancer but considered only a topic other than ACP, depression, dyspnea, or pain,
- Addressed only specific types of cancer and/or processes of care that were not generalizable across the most common cancer conditions (e.g., particular pain syndromes for tumor subtypes),
- Guidelines were excluded if they did not contain any description of their methods or how they were developed.

For the domains of pain and depression, if a measure or indicator was developed for populations (e.g., hospice) that generally include cancer patients, but the development or field testing for the indicator did not explicitly include cancer patients, we did not exclude the document or citation.

Articles accepted at the screening stage were subjected to full abstraction using standardized forms. Some studies or documents described only indicator or measure development, whereas others described testing or use in an actual population. Detailed information on the attributes of these tools was abstracted.

### The Report

In general, the review was organized around fundamental domains of symptom management—assessment, treatment, and follow-up. Assessment includes all activities related to evaluating the presence of a symptom. Treatment includes all activities subsequent to identification related to mitigating the symptom. Follow-up includes re-assessment and/or re-treatment of the symptom. For consistency, ACP was also organized around these domains since they are reasonably analogous, although for ACP, the task of ‘assessment’ is to evaluate goals and preferences, ‘treatment’ is the application of advance care plans, and ‘follow-up’ refers to actual implementation.

### Peer Review

We received comments from eight peer reviewers and eleven TEP members who reviewed our draft report. We compiled the comments and made appropriate changes to the report.

## Findings

### Literature Review

The literature search identified 4,580 titles. We identified an additional 389 articles from the database we had assembled for a systematic review of research on End-of-Life Care and Outcomes. Our web search identified 105 guidelines. An additional 109 articles were suggested from by the project members. Four additional articles were suggested by our TEP upon review of the draft version of this evidence report. In total, the RAND reviewers examined 5,187 titles.

Of the 5,187 possibly relevant titles, 4,599 were excluded at abstract review, leaving 588. Repeat review by one principal investigator (KL) excluded an additional 51 titles, leaving 537 reports and guidelines.

Of the 537 articles ordered, we retrieved 536 prior to the cut-off date (June 10, 2005). Screening resulted in the exclusion of 485 articles: 347 included no indicator; 113 had no domain of interest; 8 considered a disease other than cancer; 5 were guidelines with no methods; 6 originated in a non-Western location; 2 presented duplicate data; 2 were duplicate articles; and 2 were useful for background only.

Of the remaining 51 articles, 25 that contained measures and/or indicators and described their methods were reviewed in detail. Potential indicators were identified by each team based on their working knowledge of research literature and prioritized based on each team's opinion of the most important gaps in measurement. The remaining 26 articles contained only potential indicators. As one article can report on multiple topics and may include multiple measures and/or indicators/potential indicators the numbers in the domain boxes in Figure 1 represent the numbers of measures, indicators or potential indicators that were abstracted into the Evidence Tables and not the actual number of articles.

Figure 1. Article flow

### Pain - Measures and Indicators

This category addressed the general conceptual areas of pain assessment (five measures, two indicators) with numeric or nonspecific scales; treatment (two measures, two indicators), including timely intervention; side effect/constipation prophylaxis; radiotherapy; and follow-up (four measures, one indicator) including timely relief, satisfaction, and degree of relief (Table 2). Assessment measures and indicators specifically focused on cancer addressed routine pain assessment using numeric or non-specific scales in inpatient, intensive care, outpatient, and unspecified settings.

Table 2 Overview of identified measure sets

Indicators
QA Tools | RAND Health developed the QA Tools system as a comprehensive, clinically based system for assessing the overall quality of care for children and adults. Each QA Tools indicator is based on a focused review of the scientific literature and on the ratings of a panel of experts in the field (based on the “RAND appropriateness method”). The QA tools system includes 46 clinical areas and all four functions of medicine: screening, diagnosis, treatment, and follow-up. It also covers a variety of modes of providing care, including history, physical examination, laboratory study, medication, and other interventions and contacts.
| Relevant to supportive cancer care, QA Tools identified indicators for the following:
| 1 Pain assessment
ACOVE | Assessing the Care Of Vulnerable Elders (called ACOVE) was intended to comprehensively address quality measurement for this population because vulnerable elders are at risk for serious declines in health and function from poor quality care and use health care resources disproportionately. ACOVE developed a method of identifying a community-based sample of vulnerable elders, selected clinical conditions for quality measurement, and developed an evidence-based set of 236 ACOVE-1 quality-of-care process indicators to evaluate the care provided to vulnerable elders. The indicators are categorized into 22 clinical conditions of importance to vulnerable elders. Most of these quality indicators require only data from medical record review, though some require interviews or administrative data only. Relevant to supportive cancer care, ACOVE indicators addressed the following:
| 1 Pain assessment and management (although these indicators excluded patients with cancer and therefore were ineligible for the current review); 2 Depression; 3 Advance care planning (as part of dementia and end-of-life care); 4 End-of-life care in general (including dyspnea)
Dana-Farber | The Dana-Farber Cancer Institute at Harvard University has pursued an effort to develop a set of administrative data-based indicators for palliative cancer care as part of its recent research agenda.
| These measures focus on utilization as an outcome and address the following general aspects of supportive cancer care:
| 1 Utilization-based intensity of service use (late chemotherapy, emergency, hospital/ICU use, site of death); 2 Use of hospice
CCNS | Cancer Care Nova Scotia (CCNS) is a Canadian provincial organization established to improve the delivery of cancer services across Nova Scotia. CCNS is actively refining a quality measure set for palliative cancer care with the aim of determining which quality indicators are measurable from administrative datasets. The project has two phases:
| - Qualitative - The project systematically reviewed end-of-life quality indicators for cancer (generic indicators) and breast cancer (unique indicators). It also drew from a general literature review (project identified 90 potential indicators at this stage) and assessed the feasibility of measurement with administrative data (i.e., good communication, having advance directives - not measurable using local resources). In addition, the project conducted focus groups with patients living with metastatic cancer and bereaved caregivers, and expert panels (modified Delphi) with multidisciplinary providers. This process yielded a set of final indicators for testing.; - Quantitative - The project has defined a cohort of all women whose cause of death was related to breast CA over five years (1998-2002f) in Nova Scotia and in Ontario, a true population-based cohort; linked all available datasets that describe this population where feasible; and programmed measurable indicators. The project plans to validate the final indicator set by a detailed review of 100 charts in both provinces, assessing reliability using a 2^nd^set of abstractions.
| The project identified 19 palliative cancer indicators on these topics:
| 1 Pain management; 2 Nausea and vomiting; 3 Advance directives; 4 Utilization-based intensity of service use (site of death, hospital/ICU care, emergency, late chemotherapy use, and others); 5 Hospice and multidisciplinary service use; 6 Transitions and coordination among settings and providers of care
CCO | Cancer Care Ontario (CCO) is a Canadian provincial organization whose primary mission includes the effort to drive system quality, availability, and innovation. CCO developed a set of quality measures for a range of uses organized around measures of access to care, outcomes, evidence-based practice, efficient practice, and the data gathering performance of the cancer care system. Within these areas, individual clinical indicators address aspects of prevention, early detection, treatment, and palliative care. Measures relevant to palliative cancer care include those that address the following:
| 1 Pain management (satisfaction); 2 Utilization-based intensity of service use (site of death, emergency, and home-based services)
GCC | The Georgia Cancer Coalition (GCC) was created in 2001 as a legacy of the tobacco industry's Master Settlement Agreement with 50 states. GCC contracted with the Institute of Medicine (IOM) to develop a set of quality measures for evaluating and improving cancer care in Georgia. Efforts were guided by the principles and selection criteria of the National Quality Forum's Strategic Framework Board in recommending a set of 52 cancer care measures. GCC focused its 2003 review on potential measures that could be used to evaluate care for the most common cancers in Georgia and the United States as a whole - breast, colorectal, prostate, and lung cancer. GCC used various sources for measures including accreditation organizations, Federal agencies, provider and professional groups, State cancer control programs, and other sources (RAND Health, FAACT, NQF). GCC appointed an expert panel using the RAND appropriateness method to winnow an initial pool of more than 80 candidate measures. The final set included four items addressing the following:
| 1 Pain assessment and management; 2 Use of hospice care
VHA | In 2001, VHA, Inc initiated a rapid-cycle quality improvement program, the Transforming the Intensive Care Unit (TICU) initiative. Phase 1.0, which included 23 hospitals, focused on safety and 2 pain measures shown to be effective in pilot studies at Johns Hopkins. At the request of the participating ICUs, a key portion of phase 3.0, to be implemented in the Fall 2005, will be a palliative care bundle, which includes the pain measures and eight additional performance measures.
| The measure set was developed using information from the Critical Care Peer Workgroup of Promoting Excellence in End-of-Life Care, the National Consensus Project for Quality Palliative Care, JCAHO standards, and other evidence. The measure set is currently undergoing small-scale pilot testing. It will be implemented and tested in the TICU ICUs. As with other TICU projects, outcomes will be defined and abstracted for evidence of impact from sources such as administrative data, chart review, and satisfaction surveys.
| The palliative care bundle measures are as follows:
| Day 1: | Day 3: | Day 5:
| - Identify decisionmaker; - Address advance directive status; - Address CPR status; - Distribute information leaflet; - Assess pain regularly; - Manage pain optimally | - Offer social work support; - Offer spiritual support | - Family meeting
UHC | The University Health Consortium (UHC), formed in 1984, is an alliance of academic health centers situated in the United States. The 2004 Palliative Care Benchmarking Project was conducted within the Clinical Process Improvement (CPI) division of the benchmarking program. The Benchmarking program provides members with the unique opportunity to evaluate and compare their clinical and operational practices with the finest university hospitals in the country. The UHC staff conducted an extensive literature review and assembled an expert panel of constituent members to choose final indicators based on the review and expert opinion. UHC collected data on a set of palliative care quality indicators from December 2003-February 2004. UHC employed its members' Clinical Data Base (CDB) to select a retrospective cohort defined on the basis of adult status, several serious chronic conditions (HIV, cancer, pulmonary disease, congestive heart failure), and mortality risk (e.g., multiple recent admissions). The charts of these patients were subjected to review (40 patient records/each of 35 participating sites). A total of 1,596 charts were included in the evaluation. Quality measures included the following:
| 1 Pain assessment and treatment; 2 Dyspnea assessment and treatment; 3 Psychosocial care; 4 Care coordination/discharge planning
NHPCO | The National Hospice and Palliative Care Organization (NHPCO), founded in 1978, is the largest nonprofit membership organization that represents hospice and palliative care programs and professionals in the United States. NHPCO has developed standards for hospice care from its inception. In 1998, NHPCO began to develop the National Data Set (NDS) to establish national benchmarks for hospice practice. Development was led by an expert group that included hospice and State government representatives and researchers; this group decided to focus on outcome measures. The measurement set underwent two sets of pilot testing. Data submission is currently voluntary, but enough hospices have submitted data (78 hospices in 2002) that published benchmarks are available.^53^
| Quality measures included the following:^54^
| 1 Comfortable dying; 2 Self-determined life closure; 3 Safe dying; 4 Effective grieving; 5 Family evaluation of hospice care

### Dyspnea - Measures and Indicators

Dyspnea measures and indicators addressed the general conceptual areas of routine assessment (one measure) with a numeric scale; treatment (three indicators), which included any treatment, terminal treatment, and addressing hypoxia; and follow-up (one measure), addressing timely relief.

### Depression - Measures and Indicators

Depression measures and indicators addressed the general conceptual areas of assessment (one measure, one indicator), including psychosocial, spiritual assessment, treatment (two measures) including regular assessment or treatment.

### ACP - Measures and Indicators

ACP measures and indicators addressed the general conceptual areas of assessment (1 measures, 4 indicators), including surrogate identification, preference evaluation, patient/family participation, and timely planning; ACP application (2 measures), addressing documentation across venues and evaluation of specific life sustaining preferences; and ACP follow-up (10 measures, 1 indicators), which addressed preference-treatment consistency, hospice admission, late life utilization of hospital or intensive care settings, emergency care, and chemotherapy.

## Recommendations for Future Research

We identified priorities for future research in a number of important areas:

### Field Testing in Relevant Populations

Many of the measures may be useful now for local quality assessment and improvement, but most measures lack even basic published evidence of reliability and validity. Before these measures are deployed at higher levels of the health care system, information about their ability to discriminate quality performance and responsiveness to change will be required. Furthermore, health care systems must consider the cost and feasibility of data collection and must be assured that measures are at low risk for perverse incentives and that they can provide timely feedback.

### The Need for Measures To Address Impaired Self-Report

None of the indicators address how to evaluate symptoms among individuals with impaired self-report, which can be due to either temporary (e.g., delirium) or durable factors (e.g., dementia, brain metastasis). There is no doubt that delirium is common among cancer patients, although its incidence and prevalence are not well studied. Some recent reports noted a prevalence of 18–50% among patients with cancer in general, and observed rates are even higher in certain treatment settings such as the intensive care unit or the nursing home, where almost 60% of the population is also living with dementia.

### The Lack of Pediatric Measures

We noted the complete absence of pediatric measures or indicators. Cancer represents the second leading cause of death among children ages 5 to 15 in the United States, and serious deficiencies in the care of pediatric cancer cases have been noted. It is insufficient to propose that adult measures or indicators could simply be adopted for pediatric care, as the kinds of disease, challenges of symptom reporting and intervention, and basic approach to care differ so significantly between pediatric and adult oncology care.

### Defining the “End-of-Life”

The lack of consensus on definitions of “end-of-life” presents what has been called the “denominator” problem. Many of the indicators define end-of-life retrospectively (e.g., last six months of life). This definition does not provide guidance on important clinical service, and retrospective analyses may introduce a number of biases, since the timing of death is often not predictable. Prospective indicators would account for patient preferences but will require methodological work to define which cancer patients (those with certain types that are usually fatal, those at advanced stage) should be in the denominator.

### The Publication Gap for Quality Measurement

An important finding of our report was that much of the evidence on the measures that we identified was unpublished. Additional information that might be available to inform the evidence base for these measures was likely collected by non-academic organizations and is probably unpublished. Much of the actual experience with measures and measurement has probably been reported in an anecdotal rather than an archival form. Those who conduct future systematic reviews should be aware of this important issue and make an explicit effort to capture this unpublished information. Methods for systematically compiling and analyzing this type of data might help to improve the evidence base for quality measurement.

### Strengthening Quality Measurement of Depression in Cancer

Given the recognized prevalence of depression among cancer patients, surprisingly few indicators have been evaluated depression in cancer. Indicators developed for other settings may be appropriate but have not been tested in this population. For late-stage disease, more fundamental clinical research is needed, for example to assess the optimal approach to screening and the usefulness of short term treatment.

### Building an Evidence Base To Compare Population Subgroups

We found insufficient evidence to comment on population differences. An important priority for future research is evaluating measures in important sub-populations (e.g., those that differ by race/ethnicity, language, or gender). It is also important to define subgroups of cancer by stage of illness and to understand the performance of indicators among major subgroups, including disease type and settings of care. Fewer indicators are available for outpatient than for inpatient care evaluation, even though the majority of patient care over time occurs in the outpatient setting.