# Acknowledgments

We acknowledge the important contributions of Rena Hasenfeld Garland, B.A., who conducted all Internet searches (for guidelines and of relevant professional associations).