# Discussion

We identified a remarkable number of measures or indicators that address aspects of pain, dyspnea, depression, and advance care planning. However, in all domains, we found very few items that had been developed for and tested specifically in a cancer population and none for pediatric care. We also found few that were developed for or had been tested across the full trajectory of cancer care. Early stage indicators or measures were particularly lacking. With regard to settings of care, the fewest measures were found for outpatient care, even though patients receive most of their care in that setting. For all symptom domains, the evidence base for measurement is certainly strongest in the area of assessment, with relative shortcomings in treatment and follow-up. Our systematic review should have also uncovered evidence that these measures promote quality assessment and improvement, but there has been little investment in implementing these measures. For example, although a few carefully conducted trials have been conducted for control of pain in seriously ill or cancer patients, only one has used quality indicators as the mechanism for quality improvement,^62^ and the generalizability of other studies to routine practice and to a cancer population^159,^ ^160^ is unclear, although these studies were effective in reducing the severity of pain in a population and do include potential indicators.

An important limitation of our report is that, for the topics of pain and depression, we did not search for indicators for conditions other than cancer. The ability to use indicators or measures developed generically for these conditions and apply them to patients with cancer rests on the assumptions that the physiologic processes of pain and depression are essentially similar across disease conditions and that there are no particular measurement challenges in translating them from one population to another. This assumption requires certain caveats, such as the short time frames available for treatment in palliative care when these indicators or measures are applied to late-phase disease, and the fact that generic indicators or measures may not address short-term interventions. While these are empirically testable propositions, health care systems instituting measures for these conditions should be aware that they may not want to limit themselves to the disease-specific indicator or measures we have identified. NQF in particular has reviewed a large number of mental health indicators that may be readily applied to palliative conditions.

## Future Research

### Field Testing in Relevant Populations

The lack of reported experience with these tools may not be surprising, as the measures or indicators we identified were largely developed in the last five years, reflecting the newness of the field of supportive cancer care.^21^ In addition, the science of quality improvement in particular has suffered from confusion about optimal methodological approaches.^161^ It is encouraging that some of the measures or indicators that we identified have been recently implemented or will be implemented in the near future for monitoring and improving population care (e.g., in Georgia, Ontario, Nova Scotia, and in the VHA system), which should offer opportunities for nurturing a fundamental knowledge base to foster improving the delivery of supportive or palliative cancer care. An especially important endeavor to foster progress in measurement would be to apply the better- developed general measure and indicator sets (e.g., ACOVE) to supportive or palliative care populations with cancer.

An important objective of future testing is to obtain more robust information about the performance characteristics of the strongest measures. Even given limitations, many of them may be useful now for institutional-level quality assessment and improvement activities. However, most of these measures lack even basic published information about reliability and validity. Before they are deployed at higher levels of the health care system, information about their ability to discriminate quality performance and responsiveness to change will be required. In addition, testing in a variety of settings and institutions may also be needed. Differences in instrumentation, data source, and data collection protocols may significantly affect the performance and feasibility of measures, and research on these methodological issues and how they affect palliative care evaluation is needed. Furthermore, health care systems must consider the cost and feasibility of data collection and must be assured that measures are low risk for perverse incentives and that they can provide timely feedback on performance so that measurement can contribute to operational decisionmaking.

### The Need for Measures To Address Impaired Self-Report

None of the indicators address how to evaluate symptoms among individuals with impaired self-report, which can be due to either temporary (e.g., delirium) or durable factors (e.g., dementia, brain metastasis). There is no doubt that delirium is common among cancer patients, although its incidence and prevalence are not well studied. Some recent reports noted a prevalence of 18–50% among patients with cancer in general, ^162^–^164^ and observed rates are even higher in certain treatment settings such as the intensive care unit or in the nursing home, where almost 60% of the population is also living with dementia. The clinical needs of these populations are undoubtedly profound; a recent description of the clinical profile of cancer patients in US nursing homes reveals that, of the 190,976 cases, 51% of cases surviving more than one assessment had persistent pain, 25% of all cases were using oxygen, only 45% had DNR orders, and only 29% of those who were defined as “terminally ill” received hospice services.^165^ A major effort to expand basic research in this area and ultimately address it through quality measurement would benefit many people at the end of life.^166,^ ^167^

Considering the example of pain, health professionals' estimates of patient's pain correlate poorly with patient self-reports, and discrepancies between patients and physicians in perceptions of pain severity are predictive of inadequate management.^8^ Without regular screening for pain, many patients with significant pain do not have pain documented in the medical record and do not receive analgesia.^85^ Patient vulnerability makes data collection challenging even among patients capable of self-report, yet many patients who need palliative care are incapable of self-report at least part of the time, often at times when they are also at great risk of pain. Research that addresses methodological challenges of obtaining patient reports and methods that allow monitoring of pain without self-report are an urgent need. All of the pain quality improvement interventions identified in this review that succeeded in reducing population pain intensity in different settings also included increasing the frequency of pain assessment as a key component of the intervention.^62,^ ^159,^ ^160^

### The Lack of Pediatric Measures

A related and obvious shortcoming we noted is the complete absence of pediatric measures or indicators. As in the case of many adults, care assessment in young children is challenged by their inability to self report. Cancer represents the second leading cause of death among children ages 5–15 in the United States.^168^ However, profound challenges and serious deficiencies in the care of pediatric cancer cases have been noted.^169,^ ^170^ It is insufficient to propose that adult measures or indicators could simply be adopted for pediatric care, as the kinds of disease, challenges of symptom reporting and intervention, and basic approach to care differ so significantly between pediatric and adult oncology care. Many but not all of the adult measures have potentially useful analogues in the pediatric population,^171^ but substantial basic research will be needed to translate such efforts into useful pediatric tools. A comprehensive review in 2003 found only 22 research studies and 6 guideline statements in the area,^153^ and most of this limited literature addresses pain, to the exclusion of other symptoms or experiences.^152^ In addition, a systematic review of measure and indicator sets relevant to pediatrics found no measures or indicators for end-of-life care.^34,^ ^172^–^175^

### Defining the “End-of-Life”

The lack of consensus on definitions of “end-of-life” presents what has been called the “denominator” problem. Of central importance is the continuing challenge of establishing a consistent and accepted definition of end-of-life that is not confined to that of the “imminently” dying. The correct definition of the end-of-life may well depend upon what use is to be made of the definition. For the measures reviewed, many of the indicators explicitly define end-of-life retrospectively (e.g., last six months of life). While appropriate for evaluating “aggressive treatment” in the last days before death, this definition does not provide guidance on important clinical services such as pain prevention or the timing of advance care planning. In addition, retrospective analyses may introduce a number of biases, since the timing of death is often not predictable. Prospective indicators, such as the quality of the discussion about whether the patient wants chemotherapy, would account for patient preferences. The ACOVE indicators come closer to a prospective method by identifying “vulnerable community-dwelling elders” for which the identification and documentation of life-sustaining treatment decisions may be most appropriate. Prospective analyses for cancer will require methodological work to define which cancer patients (certain types that are usually fatal, those at advanced stage) should be in the denominator for measures of the aggressiveness of care.

### The Publication Gap for Quality Measurement

An important finding of our report was that much of the evidence on the measures that we identified was unpublished. Additional information that might inform the evidence base for these measures, (i.e., from local quality assessment and improvement efforts) probably exists but is likely unpublished and compiled by non-academic organizations. Further, much of the actual experience with measures and measurement probably exists in an anecdotal rather than archival form. We found that a strategy that consisted of an Internet search coupled with networking widely with organizations and individuals in the fields of oncology and supportive or palliative care was relatively effective for identifying such information. Future systematic reviews should be aware of this important issue and make an explicit effort to capture this unpublished information. Methods for systematically compiling and analyzing this type of data might help to improve the evidence base for quality measurement. Methods or other strategies to better promote the use of candidate measures in quality improvement work or to otherwise link measurement development work to quality improvement projects in cancer, such as the Veterans Administration Collaborative,^160^ might help to provide the information on measure responsiveness that is needed.

### Strengthening Quality Measurement of Depression in Cancer

Given the strength of the literature on measurement in mental health in general and the recognized importance of depression in the care of cancer patients, surprisingly few indicators have been evaluated for depression in advanced cancer. This lack of indicators is striking because indicators for mental health are well represented within available measure sets in general. Indicators developed for other settings may be appropriate but have not been tested in this population. Furthermore, depression is widely recognized to be an important influence on the experience of cancer. Certainly, many of the drugs used to treat depression are relevant within the scope of cancer care, especially for earlier stage disease. More fundamental clinical research is needed to address late stage disease - such as the optimal approach to screening and the usefulness of short-term treatment, which has not, for the most part, been addressed by this literature.^21^ Further research on similarities between measurements in cancer populations and those in non-cancer populations might allow elements of this work to be used as supporting evidence for particular measures. This effort may be particularly important for areas where there is significant non-cancer-related evidence, such as in patients with cognitive impairment.

### Building an Evidence Base To Compare Population Subgroups

We found insufficient evidence to comment on important differences by population. This finding is not surprising, as the tools for examining these differences are limited by the lack of basic knowledge.^21^ However, an important priority for future research is evaluating measures in important sub-populations (i.e., by race/ethnicity, age, language, and gender). With regard to pain, members of minority groups with cancer have higher rates of inadequate pain assessment and treatment than others.^86,^ ^87^ A recent nonsystematic review of the topic of cancer pain found that differences in pain management persist for both assessment and treatment, across multiple settings and types of pain.^88^ Older cancer patients^8^ and cancer patients in nursing homes^87^ are also less likely to receive adequate pain treatment. This issue was addressed in some of the guidelines we reviewed (e.g., the Oncology Nursing Society Position in Cancer Pain Management)^82^ but has not been operationalized into indicators. It is important to define subgroups of cancer by stage of illness and to understand the performance of indicators among major subgroups.

Durable improvement in symptom assessment will require measures that are capable of being implemented with other routine metrics of performance in important care settings. For example, improvements in pain management often decay over time. In one study to increase daily pain assessment, performance on the indicator was 82% after an educational intervention but decreased to 59% over a seven-month period.^9^ Evaluations of the use of pain assessment in clinical settings have shown good feasibility with minimal burden for staff.^9^ However, in one study with a high prevalence of unreported pain, training of home health aides to document pain scores resulted in a large increase in screening; however, physician documentation increased by only 5- to 8%.^85^ In addition, although most of the indicators or measures that we identified were focused on the inpatient setting, much routine cancer care occurs in the ambulatory setting, and we found fewer indicators or measures to address outpatient performance.

## Conclusions

Over time, measures should become available for an increasing number of areas of clinical performance in supportive or palliative cancer care. Research is needed to ensure that valid and reliable measures are available to address the full spectrum of palliative domains, including the most important symptoms that patients face: spiritual well-being and caregiver burdens, including bereavement. Measures are needed for the major settings where patients receive care (i.e., the outpatient setting) as well as those that follow patients across care venues. More patient-centered measures that address the actual processes important to high quality symptom control and care planning are needed. Especially in terms of treatment, current indicators do not fully reflect progress in adult supportive or palliative care, particularly with regard to pain, dyspnea, and depression care.^21^ However, a thoughtful application of existing measurement will ensure that some palliative measures are useful now for most (adult) cancer patients.

Unlike other tools for quality evaluation where incentives are relatively strong in the private sector for improved quality management (e.g., those for prevention or treatment of hypertension or diabetes), the adoption of quality metrics for supportive and palliative care is particularly dependent on federal endorsement. Almost all elder care is the ultimate responsibility of the federal government through Medicare, Medicaid, or the VA systems. The absence of supportive or palliative measures within the recent National Healthcare Quality Report is particularly notable in that regard.^176^ Strong federal leadership of both research and the application of measurement in clinical care will be needed to make progress in this important area. However, the number of measures and indicators that we have identified and the recency of progress in this area suggest that now is a promising time to initiate these efforts within our health care system.