# Appendix F4. Quality Measures and Indicators for Supportive Cancer Care: Advanced Care Planning

No. | Measure or Indicator Set/Reference / Year | Description of measure or indicator | Denominator | Numerator | Disease | Patient Characteristics | Setting | Data Source,Reliability, and Validity
Assessment
1 | ACOVE End of Life | (Measure) Regular identification of a surrogate in the outpatient setting. | All vulnerable elderly patients in an outpatient setting. | Number of vulnerable elderly patient's with documentation in their medical record of their proxy or surrogate decision-maker's name and contact information, or of a discussion with patient of who would be surrogate, or documentation of a search for a surrogate, or an indication that there is no identified surrogate. | Mixed disease | Adult | Home care | Patient interview / survey
| Wenger, N.S.^1^ | All vulnerable elders should have in their outpatient chart one of the following: 1) an advance directive indicating the patient's surrogate/proxy decision-maker, 2) documentation of a discussion about who would be a surrogate decision maker or a search for a surrogate, or 3) indication that there is no identified surrogate upon entry to facility or transfer to new unit or site. | | | | 36% Male | Hospice | Chart
| Wenger, N.S.^2^ | | | | | Average age is 81.0 | Ambulatory / outpatient care | Reliability / Validity not reported
| | | | | | | Hospital (non-ICU)
| | | | | | | Hospital (ICU)
| | | | | | | Home
| | | | | | | Community
2 | ACOVE End of Life | (Measure) Regular identification of a surrogate among hospital admissions with impaired cognition. | All vulnerable elders with dementia, coma, or altered mental status admitted to the hospital. | Number of vulnerable elders with dementia, coma, or altered mental status admitted to a hospital with documentation within 48 hours of admission of 1) an advance directive indicating the patient's surrogate decision maker, 2) a discussion about who would be a surrogate decision maker or a discussion about a search for a surrogate, or 3) indicate that there is no identified surrogate. | Mixed disease | Adult | Ambulatory / outpatient care | Patient interview / survey
| Wenger, N.S.^1^ | IF a vulnerable elder with dementia, coma, or altered mental status is admitted to the hospital, THEN within 48 hours of admission the medical record should 1) contain an advance directive indicating the patient's surrogate decision maker, 2) document a discussion about who would be a surrogate decision maker or a discussion about a search for a surrogate, or 3) indicate that there is no identified surrogate. | | | | 36% Male | Hospital (non-ICU) | Chart
| Wenger, N.S.^2^ | | | | | Average age is 81.0 | Hospital (ICU) | Reliability / Validity not reported
3 | ACOVE End-of Life | (Measure) Regular assessment of preferences among inpatients with dementia. | All vulnerable elders with severe dementia admitted to a hospital and surviving 48 hours. | Number of vulnerable elders with severe dementia admitted to a hospital and surviving 48 hours with documentation that the patient's prior preferences for care have been considered or that these preferences could not be elicited or are unknown. | Mixed disease | Adult | Hospice | Patient interview / survey
| Wenger, N.S.^1^ | IF a vulnerable elder has a diagnosis of severe dementia is admitted to the hospital and survives 48 hours, THEN within 48 hours of admission, the medical record should document that the patient's the patient's prior preferences for care have been considered or that these preferences for care could not be elicited or are unknown. | | | | 36% Male | Ambulatory / outpatient care | Chart
| Wenger, N.S.^2^ | | | | | Average age is 81.0 | Hospital (non-ICU) | Reliability / Validity not reported
| | | | | | | Hospital (ICU)
| | | | | | | Home
4 | ACOVE End of Life | (Measure) Regular assessment of preferences in an ICU. | All vulnerable elderly patients admitted directly to the ICU from an outpatient or ER setting and surviving 48 hours. | Number of vulnerable elders admitted directly to the intensive care unit from an outpatient or ER setting and surviving 48 hours with documentation in the medical record that the patient's preferences for care have been considered or that these preferences could not be elicited or are unknown within 48 hours of admission. | Mixed disease | Adult | Hospice | Patient interview / survey
| Wenger, N.S.^1^ | IF a vulnerable elder is admitted directly to the intensive care unit from an outpatient or ER setting and survives 48 hours, THEN within 48 hours of admission, the medical record should document that the patient's preferences for care have been considered or that these preferences could not be elicited or are unknown. | | | | 36% Male | Ambulatory / outpatient care | Chart
| Wenger, N.S.^2^ | | | | | Average age is 81.0 | Hospital (non-ICU) | Reliability / Validity not reported
| | | | | | | Hospital (ICU)
5 | Ryndes, T^3^. | (Measure) Regular assessment of preferences in hospice. | All patients admitted to hospice. | Number of hospice patients with documentation in their medical record that they were assessed upon admission including physical, functional, emotional and spiritual needs and preferences with full autonomy to make decisions about how the remainder of their life is to be spent; any living will or advance directive information, and/or an assigned power of attorney for health care. | Mixed disease | Adult | Home | Chart
| National Hospice and Palliative Care Organization (NHPCO)^4^ | | | | | | | Construct validity
| | | | | | | | Discriminant validity
| | | | | | | | Other validity
| | | | | | | | Reliability / Validity not reported
6 | ACOVE End of | (Measure) Regular patient participation in decisions to limit treatment. | All vulnerable elderly patients in the hospital or nursing home with written orders to withdraw or withhold a LST. | Number of vulnerable elderly patients with decision-making capacity with written orders to withhold or withdraw a particular LST with documentation in the medical record of 1) patient participation in the decision or 2) why the patient did not participate in the decision. | Mixed disease | Adult | Hospital (non-ICU) | Patient interview / survey
| LifeWenger, N.S.^1^ | IF a vulnerable elder with decision-making capacity has orders written in the hospital or the nursing home to withhold or withdraw a particular treatment (e.g., a do-not-resuscitate order or an order not to initiate dialysis), THEN the medical record should document 1) patient participation in the decision or 2) why the patient did not participate in the decision. | | | | 36% Male | Hospital (ICU) | Chart
| Wenger, N.S.^2^ | | | | | Average age is 81.0
7 | UHC | (Measure) Regular family meetings among hospitalized patients. | All adults admitted to the hospital. | Number of adults admitted to the hospital with documentation in the medical record that the health care team conducted a patient/family meeting within 1 week of admission that included discussion of the patient's treatment preferences and/or a plan for discharge disposition. | Mixed disease | Adult | Hospital (non-ICU) | Chart
| Maxwell, T.^5^ | | | | | | Hospital (ICU) | Reliability / Validity not reported
8 | UHC | (Measure) Timely and effective discharge planning. | All adults admitted to the hospital. | Number of adults admitted to the hospital with documentation in the medical record of a plan for discharge disposition within 4 days of admission. | Mixed disease | Adult | Hospital (non-ICU) | Chart
| Maxwell, T.^5^ | | | | | | Hospital (ICU) | Reliability / Validity not reported
9 | VHA Update March 2005^6^ | (Indicator) Regular identification of a surrogate in the ICU. | Total number of patients with an ICU length of stay > 24 hours. | Number of ICU patients with documentation in the chart of status of identification of a health care proxy (or other appropriate surrogate decision-maker) including one or more of the following: 1) documentation that the patient has a health care proxy, 2) documentation that the patient declined to appoint a health care proxy, 3) documentation that the care team discussed health care proxy appointment with the patient and/or family, 4) documentation that the patient has an appropriate surrogate decision-maker other than a health care proxy. | Not Reported | Adult | Hospital (ICU) | Chart
| | | | | | | | Reliability / Validity not reported
10 | VHA Update March 2005^6^ | (Indicator) Regular assessment of advance directives for ICU patients. | Total number of patients with an ICU length of stay > than 24 hours. | Number of patients admitted to the ICU with documentation of the patient's advance directive (written or oral instructions from the patient specifying the type of medical treatment that is desired if the patient becomes incapacitated, including a living will, durable power of attorney (note state-specific status) or any document that state law recognizes as an “advance directive”) entered in the medical record within 24 hours following admission. | Not Reported | Adult | Hospital (ICU) | Chart
| | | | | | | | Reliability / Validity not reported
11 | VHA Update March 2005^6^ | (Indicator) Regular assessment of specific resuscitation preferences in the ICU. | Total number of patients with an ICU length of stay > than 24 hours. | Number of patients admitted to the ICU with resuscitation status including one or more of the following: 1) documentation of a directive to attempt resuscitation in the event of an arrest, 2) documentation of a directive to forego attempts to resuscitate in the event of an arrest, 3) documentation that the care team discussed resuscitation status with the patient and/or family) documented in the medical record within 24 hours of admission. | Not Reported | Adult | Hospital (ICU) | Chart
| | | | | | | | Reliability / Validity not reported
12 | VHA Update March 2005^6^ | (Indicator) Regular clinician-patient-family communication in the ICU. | Total number of patients with an ICU length of stay > than 120 hours. | Number of patients admitted to the ICU who survive > than 5 days (120 hours) with documentation in the medical record that an interdisciplinary team meeting (with at least the attending physician (primary care or ICU attending) and a nurse) and the patient and/or family was conducted within 120 hours of ICU admission and involved a discussion addressing each of the following topics: 1) the patient's condition (diagnosis and prognosis), 2) goals of treatment; 3) the patient's and family's needs and preferences, 4) the patient's and family's understanding of the patient's condition and goals of treatment at the conclusion of the meeting. | Not Reported | Adult | Hospital (ICU) | Chart
| | | | | | | | Reliability / Validity not reported
Application
13 | ACOVE End of Life | (Measure) Documentation of care preferences across venues. | All vulnerable elderly patients with existing advance directives in another setting admitted to an outpatient, inpatient, or nursing home setting. | Number of vulnerable elderly patients admitted to the outpatient, inpatient, or nursing home and reporting the existence of an advance directive in another setting with documentation in their medical record of 1) the existing advance directive or 2) documentation acknowledging the existing advance directive, it contents, and the reason that it is not included in the medical record. | Mixed disease | Adult | Home care | Patient interview / survey
| Wenger, N.S.^1^ | IF a vulnerable elder has an advance directive in the outpatient, inpatient, or nursing home medical record or the patient reports the existence of an existing advance directive in an interview, and the patient receives care in a second venue, THEN 1) the existing advance directive should be present in the patient's medical record in the second venue or 2) documentation should acknowledge its existence, its contents, and the reason that it is not in the current medical record. | | | | 36% Male | Hospice | Chart
| Wenger, N.S.^2^ | | | | | Average age is 81.0 | Ambulatory / outpatient care | Reliability / Validity not reported
| | | | | | | Hospital (non-ICU)
| | | | | | | Hospital (ICU)
| | | | | | | Home
| | | | | | | Community
14 | ACOVE End of Life | (Measure) Documentation of specific life sustaining preferences. | All vulnerable elders in any setting. | Number of vulnerable elders in any setting indicating that he/she would rather die than live permanently comatose, ventilated, or tube fed with one of the following documented in their medical record: 1) a discussion of life-sustaining treatment preferences, 2) an advance directive, or 3) that the patient discussed this topic with the physician or does not wish to discuss this topic. | Mixed disease | Adult | Home care | Patient interview / survey
| Wenger, N.S.^1^ | IF a vulnerable elder indicates (during an interview) that he/she would rather die than live permanently comatose, ventilated, or tube fed, THEN 1) the chart should document a discussion of life-sustaining treatment preferences, 2) the chart should contain an advance directive, or 3) the patient should indicate (during the interview) that he/she discussed these topics with the physician or does not wish to discuss the topics. | | | | 36% Male | Hospice | Chart
| Wenger, N.S.^2^ | | | | | Average age is 81.0 | Ambulatory / outpatient care | Reliability / Validity not reported
| | | | | | | Hospital (non-ICU)
| | | | | | | Hospital (ICU)
| | | | | | | Home
| | | | | | | Community
Follow-up
15 | ACOVE End of Life | (Measure) Consistency of preferences with use of ventilatory support. | All hospitalized vulnerable elders requiring mechanical ventilation (except short-term and post operative mechanical ventilation). | Number of hospitalized vulnerable elders requiring mechanical ventilation (except short-term and post operative mechanical ventilation) with documentation in the patient record of the goals of care and the patient's decision for mechanical ventilation or why this information is unavailable. | Mixed disease | Adult | Hospital (non-ICU) | Patient interview / survey
| Wenger, N.S.^1^ | IF a vulnerable elder requires mechanical ventilation during a hospitalization (except short-term and post operative mechanical ventilation), THEN within 48 hours of the initiation of mechanical ventilation the medical record should document the goals of care for the patient and the patient's preference for mechanical ventilation or why this information is unavailable. | | | | 36% Male | Hospital (ICU) | Chart
| Wenger, N.S.^2^ | | | | | Average age is 81.0 | | Reliability / Validity not reported
16 | Earle, C.C.^7^ | (Measure) Late life hospital use. | All deceased cancer patients. | Number of dying cancer patients with > 1 hospital admission in the last month of life. | Mixed cancer | Adult | Hospital (non-ICU) | Administrative
| Earle, C.C.^8^ | | | | | Grunfeld, E.: All patients in the population with cancer | Hospital (ICU) | Chart
| Grunfeld, E.^9^ | | | | | | | Other
| | | | | | | | Grunfeld, E.: Cancer registry, administrative claim data, hospital discharge abstract
17 | Earle, C.C.^7^ | (Measure) Late life ICU use. | All deceased cancer patients. | Number of dying cancer patients with 1 ICU admission in the last month of life. | Mixed cancer | Adult | Hospice | Administrative
| Earle, C.C.^8^ | | | | | Grunfeld, E.: All patients in the population with cancer | | Chart
| Grunfeld, E.^9^ | | | | | | | Other
| | | | | | | | Grunfeld, E.: Cancer registry, administrative claim data, hospital discharge abstract
18 | Dana Farber Cancer Center | (Measure) Late life rate of emergency care. | All deceased cancer patients. | Number of dying cancer patients with > 1 emergency room visit in the last month of life. | Mixed cancer | Adult | Hospital (non-ICU) | Administrative
| Earle, C.C.^7^ | | | | | Grunfeld, E.: All patients in the population with cancer | Hospital (ICU) | Chart
| Earle, C.C.^8^ | | | | | | | Other
| Grunfeld, E.^9^ | | | | | | | Reliability / Validity not reported
| Cancer Care Ontario^10^ | | | | | | | Grunfeld, E.: Cancer registry, administrative claim data, hospital discharge abstract
19 | Earle, C.C.^7^ | (Measure) New chemotherapy regimen in last 30 days of life. | All deceased cancer patients. | Number of dying cancer patients started on a new chemotherapy regimen in the last 30 days of life,. | Mixed cancer | Adult | Ambulatory / outpatient care | Administrative
| Earle, C.C.^8^ | | | | | Grunfeld, E.: All patients in the population with cancer | Hospital (non-ICU)) | Chart
| Grunfeld, E.^9^ | | | | | | Hospital (ICU | Other
| | | | | | | | Reliability / Validity not reported
| | | | | | | | Grunfeld, E.: Cancer registry, administrative claim data, hospital discharge abstract
20 | Earle, C.C.^7^ | (Measure) Chemotherapy in last 14 days of life. | All deceased cancer patients. | Number of dying cancer patients receiving chemotherapy in the last 14 days of life. | Mixed cancer | Adult | Hospital (non-ICU) | Administrative
| Earle, C.C.^8^ | | | | | Grunfeld, E.: All patients in the population with cancer | Hospital (ICU) | Chart
| Grunfeld, E.^9^ | | | | | | | Other
| Cancer Care Ontario^11^ | | | | | | | Reliability / Validity not reported
| | | | | | | | Grunfeld, E.: Cancer registry, administrative claim data, hospital discharge abstract
21 | Earle, C.C.^7^ | (Measure) Admission to hospice. | All deceased cancer patients. | Number of cancer patients who die in the hospital. | Mixed cancer | Adult | Hospice | Administrative
| Earle, C.C.^8^ | | | | | Grunfeld, E.: All patients in the population with cancer | | Chart
| Grunfeld, E.^9^ | | | | | | | Other
| Cancer Care Ontario^11^ | | | | | | | Reliability / Validity not reported
| National Cancer Policy Board (NCPB)^9^ | | | | | | | Grunfeld, E.: Cancer registry, administrative claim data, hospital discharge abstract
22 | Earle, C.C.^7^ | (Measure) Late referral to hospice. | All deceased cancer patients. | IF a dying cancer patients referred to hospice or palliative care < 3 days before death. | Mixed cancer | Adult | Hospice | Administrative
| Earle, C.C.^8^ | | | | | Grunfeld, E.: All patients in the population with cancer | | Chart
| Grunfeld, E.^9^ | | | | | | | Other
| National Cancer Policy Board (NCPB)^9^ | | | | | | | Reliability / Validity not reported
| | | | | | | | Grunfeld, E.: Cancer registry, administrative claim data, hospital discharge abstract
23 | Earle, C.C.^7^ | (Measure) Site of death. | All deceased cancer patients. | Number of cancer patients who die in the hospital. | Mixed cancer | Adult | Hospital (non-ICU) | Administrative
| Earle, C.C.^8^ | | | | | Grunfeld, E.: All patients in the population with cancer | Hospital (ICU) | Chart
| Grunfeld, E.^9^ | | | | | | | Other
| Cancer Care Ontario^10^ | | | | | | | Reliability / Validity not reported
| Cancer Care Ontario^11^ | | | | | | | Grunfeld, E.: Cancer registry, administrative claim data, hospital discharge abstract
24 | Ryndes, T.^3^ | (Measure) Safe dying in hospice. | All Caregiver's of Hospice patients who died while in hospice. | Number of deceased hospice patient's caregivers with documentation in the patient's medical record who were contacted and surveyed as to the quality of care provided by the hospice using the following question: If you cared for the patient at home, did hospice increase your confidence to safely care for your loved one as death approached?. | Mixed disease | Adult | Home | Chart
| National Hospice and Palliative Care Organization (NHPCO)^4^ | | | | | | | Construct validity reported
| Connor, S.^12^ | | | | | | | Discriminant validity reported
25 | ACOVE End of Life | (Indicator) Care consistency with documented care preferences. | All vulnerable elderly patients in any health care setting with specific treatment preferences documented in their medical record. | Number of vulnerable elders with specific treatment preferences documented in their medical record with those treatment preferences having been followed. | Mixed disease | Adult | Hospice | Chart
| Wenger, N.S.^2^ | If a vulnerable elder has specific treatment preferences (e.g., a do-not-resuscitate order, no tube feeding, or no hospital transfer) documented in a medical record, THEN these treatment preferences should be followed. | | | | | Ambulatory / outpatient care
| | | | | | | Hospital (non-ICU)
| | | | | | | Hospital (ICU)
Potential Indicators Assessment
1 | Dokken, D.L.^13^ | IF a child with life threatening illness is admitted to any health care setting, THEN the needs of each child are supported through periodic assessment and reassessment of the child's physical, social, emotional, developmental, spiritual, and educational strengths and needs in light of the child's developmental level and diagnosis and, based on the assessed needs, development and implementation of interventions involving experts in relevant areas (e.g., child life, chaplancy, physical and occupational therapy, psychology, etc.) should be conducted. | All Children With Life Threatening Illness Admitted to Any Health Care Setting. | Number of children with life threatening illness admitted to any health care setting with documentation in the medical record that the needs of each child were periodically assessed (including child's physical, social, emotional, developmental, spiritual, and educational strengths and needs in light of the child's developmental level and diagnosis) and, based on the assessed needs, there is evidence of the development and implementation of interventions involving experts in relevant areas (e.g., child life, chaplaincy, physical and occupational therapy, psychology, etc.). | Not Reported | Children | Hospital (non-ICU) | Chart
| | | | | | | Hospital (ICU) | Reliability / Validity not reported
Potential Indicators Application
2 | Lilly, C.M.^14^ | IF an ICU patient has a poor prognosis (e.g., a condition associated with a high probability of death, who had a predicted length of ICU stay longer than 5 days, a predicted mortality of greater than 25% as estimated by the attending physician, or a change in functional status that is potentially irreversible and sufficient to preclude eventual return to home) or a deteriorating condition (a progressive worsening of a patient's condition that predisposes the patient to death), THEN the attending physician should assess the patient's medical condition, review the case with the patient's primary care physician and agree on a recommended care plan, review any known advance directives, and conduct a family meeting with the patient's family (including health care proxy), where possible, the patient, the patient's nurse, and the hospital house officer in order to 1) review the medical facts and options for treatment, 2) to discuss the patient's perspectives on death and dying, chronic dependence, loss of function, and the acceptability of the risks and discomforts of critical care; 3) to agree on a care plan; and 4) to agree on criteria by which the success or failure of this care plan would be judged using defined “clinical events” as milestones indicating that the care plan had been effective or not and the time frame for their occurrence. | All ICU patients. | umber of ICU patients with a poor prognosis (e.g., a condition associated with a high probability of death, who had a predicted length of ICU stay longer than 5 days, a predicted mortality of greater than 25% as estimated by the attending physician, or a change in functional status that is potentially irreversible and sufficient to preclude eventual return to home) or a deteriorating condition (a progressive worsening of a patient's condition that predisposes the patient to death) with documentation in the medical record that the attending physician assessed the patient's medical condition, reviewed the case with the patient's primary care physician, reviewed any known advance directives, and conducted a family meeting with the patient's family (including health care proxy). | Mixed disease | Adult | Hospital (ICU) | Data Collection specified
| | | | | | White | | Reliability / Validity not reported
| | | | | | African American
| | | | | | Hispanic
| | | | | | 59% Male
| | | | | | Average age is 59.0
| | | | | | Age ranges
| | | | | | from 45 to 75
3 | National Comprehensive Cancer Network (NCCN)^15^ | All cancer patients with advanced, symptomatic, progressive disease and/or those with a life expectancy of <12 months, or with serious comorbid conditions, or the patient or family requests palliative care should receive a palliative care assessment, including symptoms, advance care planning discussion (living will, power of attorney, DNR orders, hospice preference), resource management/social support (caregivers, family, financial, community, cultural, spiritual, religious), and the benefits and risks of anticancer therapy to identify patient and family goals and expectations, referral for complex palliative care, discuss palliative care options (including hospice), elicit personal values and preferences of patient and family for end of life care, encourage communication of wishes between patient and family, and encourage the designation of a health care proxy. | All cancer patients with advanced, symptomatic, progressive disease and/or those with a life expectancy of <12 months, or with serious comorbid conditions, or the patient or family requests palliative care. | Number of cancer patients with advanced, symptomatic, progressive disease and/or those with a life expectancy of <12 months, or with serious comorbid conditions, or the patient or family requests palliative care with documentation in the chart that they received a palliative care assessment (including symptoms and advance care planning discussions of living will, power of attorney, DNR orders, hospice preference, resource management/social support concerning caregivers, family, financial, community, cultural, spiritual, religious needs, and the benefits and risks of anticancer therapy) to identify patient and family goals and expectations, wishes for referral for complex palliative care, discussion of palliative care options (including hospice), documentation of the personal values and preferences of the patient and family for end of life care, communication of wishes between patient and family, and encourage the designation of a health care proxy. | Mixed cancer | Adult | Hospice | Chart
| | | | | | | Ambulatory/outpatient care | Reliability / Validity not reported
| | | | | | | Hospital (non-ICU)
| | | | | | | Hospital (ICU)
4 | Clinical practice guidelines for quality palliative care^16^ | A plan of care for dying patients should be developed for the patient based on 1) a comprehensive interdisciplinary medical, psycho-social, spiritual/existential, cultural assessment of the patient and family; 2) the identified and expressed values, goals, and needs of the patient and family developed with professional guidance and support for decision making; the plan is regularly reviewed and is responsive to the patient's changing illness and the family's changing needs; 4) where identified, the patient/family should be referred to external specialist services; and 5) the services provided by the Palliative Care Team are consistent with the care plan and the patient's and family wishes. | All patients admitted to any health care setting and determined to need palliative care. | Number of dying patients admitted to any health care setting and needing palliative care with documentation in the patient's medical record of: 1) a comprehensive interdisciplinary medical, psycho-social, spiritual/existential, cultural assessment of the patient and family; 2) documentation that the expressed values, goals, and needs of the patient and family were developed with professional guidance and support for decision making; 3) the plan was regularly reviewed and was responsive to the patient's changing illness and the family's changing needs; 4) the patient/family were referred to external specialist services when appropriate; and 5) the services provided by the Palliative Care Team were consistent with the care plan and the patient's and family wishes. | Not Reported | Adult | Home care | Chart
| Standards and Quality Committee^17^ | | | | | | Hospice | Reliability / Validity not reported
| | | | | | | Ambulatory/outpatient care
| | | | | | | Hospital (non-ICU)
| | | | | | | Hospital (ICU)
5 | Standards and Quality Committee^17^ | All patients, in any health care setting, determined to be dying or whose death is expected, THEN the patient and family should have their psychological, emotional, social, cultural, and spiritual needs assessed on an ongoing basis by an interdisciplinary health care team, and where psychological, emotional, and/or spiritual needs are identified or expressed, should be referred to internal and external specialist services, including bereavement services and these assessments and referral/receipt of supportive services should be documented in the patient's medical record or why these needs were not assessed and/or addressed. | All patients, in any health care setting, who died with an expected death. | Number of deceased patients, in any health care setting, who died an expected death with documentation in the patient's medical record of ongoing assessment of the patient and family's psychological, emotional, social, cultural, and spiritual needs by an interdisciplinary health care team, and where psychological, emotional, and/or spiritual needs are identified or expressed, documentation of referral to internal and external specialist services, including bereavement services, and receipt of supportive services or why these needs were not assessed and/or addressed. | Mixed disease | Adult | Other | Data Collection specified
| | | | | | | | Reliability / Validity not reported
6 | Clarke, E.B.^18^ | IF a vulnerable elder's care, in any health care setting, will be transferred to another health care provider (individual, team, setting), THEN the current provider should maximize continuity of care across clinicians, consultants, and settings by orienting new clinicians regarding the patient and family health care preferences and plan of care and prepare patient and family for a change of clinician(s) and introduce new clinicians. | All vulnerable elders, in any health care setting, who were transferred to new clinician(s) or settings. | % of vulnerable elder's care, in any health care setting, who were transferred to another health care provider (individual, team, setting), with documentation in the patient's medical record that the current provider oriented new clinicians regarding the patient and family's treatment preferences and plan of care, prepared the patient and family for a change of clinician(s), and introduced new clinicians to the patient and family. | Mixed disease | Adult | Hospital (ICU) | Chart
| | | | | | | | Reliability / Validity not reported
7 | Masera, G.^19^ | IF a child with life threatening illness is admitted to any health care setting, THEN a discussion of an advance directive discussion should be conducted within 48 hours of admission to ensure that treatments that have become burdensome are not used. | All children with life threatening illness admitted to any health care setting. | % of children with life threatening illness admitted to any health care setting with documentation in the medical record of a discussion with the child's parents of advance directives with LST decisions documented within 48 hours of admission. | Mixed cancer | Adult/Children | Home care | Chart
| American Academy of Pediatrics. Committee on Bioethics and Committee on Hospital Care. Palliative care for children^20^ | | | | | | Hospital (ICU) | Reliability / Validity not reported
8 | Masera, G.^19^ | IF a child with cancer cannot be successfully treated by presently available therapies, and the child needs specific treatments identified to be palliative and not curative for mental or physical distress, THEN the focus of care should be on key issues, including communication, social, psychological, emotional support, symptom control, etc. and a advance directive discussion should be conducted with the child's parents within 48 hours of admission. | All children with life threatening illness admitted to any health care setting. | % of children with cancer that cannot be successfully treated by presently available therapies needing specific treatments identified to be palliative and not curative for mental or physical distress with documentation in their medical record that the focus of care is on key issues, including communication, social, psychological, emotional support, symptom control, etc. and a advance directive discussion should be conducted with the child's parents within 48 hours of admission. | Mixed cancer | Children | Home care | Chart
| American Academy of Pediatrics. Committee on Bioethics and Committee on Hospital Care. Palliative care for children^20^ | | | | | | Hospital (ICU) | Reliability / Validity not reported
9 | Mitchell, S.L.^21^ | IF a patient entering any health care facility is determined to have dementia and has a feeding tube inserted and there is no accompanying documentation of the patient's advance directive or treatment preferences, THEN the medical record should document that the health care team has conferred with the patient's family members and/or proxy regarding sustaining or withdrawing the feeding tube (including a discussion of the evidence regarding the lack of benefit, improved survival, or prevention of aspiration of feeding tubes) within 48 hours of admission. | Total number of patients entering any health care facility with dementia, a feeding tube, and no accompanying documentation of the patient's advance directive or treatment preferences with LOS > 24 hours. | Number of patients entering any health care facility with dementia, a feeding tube, and no accompanying documentation of the patient's advance directive or treatment preferences with documentation in the medical record that the health care team conferred with the patient's family members and/or proxy regarding sustaining or withdrawing the feeding tube (including a discussion of the evidence regarding the lack of benefit, improved survival, or prevention of aspiration of feeding tubes) within 48 hours of admission. | Mixed disease | Adult | Hospital (non-ICU) | Chart
| | | | | | Lower boundary for age is 65 | Hospital (ICU) | Reliability / Validity not reported
10 | Dokken, D.L.^13^ | IF a child with life threatening illness is admitted to any health care facility, THEN the child and his/her family should be regarded as the unit of care and 1) any concerns raised by the family about the child's condition should be acknowledged and addressed in a timely and respectful manner, 2) the family's cultural values, beliefs, views about quality of life and customary modes of interaction among family and community should be respected by health care providers, 3) the family is present with the child and involved in his/her care to the extent they desire and degree feasible based on the child's condition and health care setting, and 4) the impact of the child's illness on the parental relationship, siblings, and family coping strategies and finances should be routinely assessed, and a range of practical (including financial), emotional, and spiritual supports should be made available to meet family-identified needs by the health care institution and/or through the community. | All children with a life threatening illness admitted to any health care facility. | Number of children with life threatening illness is admitted to any health care facility with documentation in the patient's medical record that the child and his/her family were regarded as the unit of care and 1) any concerns raised by the family about the child's condition were acknowledged and addressed in a timely and respectful manner by the health care team, 2) the family's cultural values, beliefs, views about quality of life and customary modes of interaction among family and community were respected by health care providers, 3) the family was present with the child and involved in his/her care to the extent they desired and degree feasible based on the child's condition and health care setting, and 4) the impact of the child's illness on the parental relationship, siblings, and family coping strategies and finances was routinely assessed and a range of practical (including financial), emotional, and spiritual supports were made available to meet family-identified needs by the health care institution and/or through the community. | Not Reported | Children | Hospital (non-ICU) | Chart
| | | | | | | Hospital (ICU) | Reliability / Validity not reported
11 | Widger, K.A.^22^ | Key components of quality care for children include information transmission, preparation for death and care at death, bereavement care, interpersonal aspects and competence of health professionals, clarity and honesty of communication, parent role, support for the family, pain and symptom management, decision making, psychosocial and spiritual needs of the child, availability and accessibility of services, coordination and integration of services, respite care for families, and financial support. | All children with a life threatening illness admitted to any health care facility. | Number of children with a life-threatening illness admitted to any health care facility with documentation in the patient's medical record that the key components of quality terminal care for children with cancer and their families. | Mixed cancer | Children | Not Reported | Not Reported
12 | Dokken, D.L.^13^ | IF a child with life threatening illness is admitted to any health care setting, THEN each child should have a designated individual, a physician or other health care providers, identified as responsible for coordinating the child's overall care and who should 1)should be involved in care planning and decision-making with the child, family, and other health care providers, 2) is responsible for ongoing communication among the designated health care provider, the child and family, and the child's other health care providers, and the health care setting should develop and implement a process for the child and family to articulate concerns about the choice of designated health care provider and to explore the possibility of changing providers. | All children with a life threatening illness admitted to any health care facility. | Number of children with life threatening illness admitted to any health care setting with documentation in the medical record that a designated individual, a physician or other health care providers, was identified and was identified as being responsible for the coordinating the child's overall care and who was involved in care planning and decision-making with the child, family, and other health care providers, 2) was identified to the child and family as responsible for ongoing communication among the designated health care provider, the child and family, and the child's other health care providers, and there is documentation in the medical record that the child and family were informed about the health care setting's process for the child and family to articulate concerns about the choice of designated health care provider and to the method established for the child and family to change designated providers if they chose to do so. | Not Reported | Children | Hospital (non-ICU) | Chart
| | | | | | | Hospital (ICU) | Reliability / Validity not reported
13 | Dokken, D.L.^13^ | IF a child with life threatening illness is admitted to any health care setting, THEN each child should have a comprehensive and appropriate written plan of care documented in their medical record and should be developed with the child's (to the extent appropriate), the family, and their health care providers involvement and that is 1) periodically reviewed, 2) that outlines the roles of family caregivers and the relationships between them, and 3) that includes discharging and receiving health care providers, within and across care settings, and 4) that is communicated in a timely manner across all care settings. | Number of children with life threatening illness admitted to any health care setting with documentation in their medical record of a comprehensive and appropriate written plan of care developed with the child's (to the extent appropriate), the family, and their health care providers involvement that is 1) periodically reviewed, 2) that outlines the roles of family caregivers and the relationships between them, and that is communicated in a timely manner across all care settings, including discharging and receiving health care providers and within and across care settings. | All children with a life threatening illness admitted to any health care facility. | Not Reported | Children | Hospital (non-ICU) | Chart
| | | | | | | Hospital (ICU) | Reliability / Validity not reported
14 | National Comprehensive Cancer Network (NCCN)^15^ | All families and next of kin of cancer patients who have died SHOULD receive culturally sensitive and respectful after death care, including respectful treatment of the patient's body, family time with the body, address concerns about organ donation or autopsy, facilitate funeral arrangements, inform insurance companies, and the offer and referral of family/next of kin to grief and bereavement services. | Number of families and next of kin of cancer patients who died with documentation of receiving culturally sensitive and respectful after death care, including respectful treatment of the patient's body, family time with the body, address concerns about organ donation or autopsy, facilitate funeral arrangements, inform insurance companies, and the offer and referral of family/next of kin to grief and bereavement services. | All families and next of kin of patients who died in any health care setting. | Mixed cancer | Adult | Home care | Chart
| | | | | | | Hospice | Reliability / Validity not reported
| | | | | | | Ambulatory/outpatient care
| | | | | | | Hospital (non-ICU)
| | | | | | | Hospital (ICU)

## Reference List for Appendix F4

1 Wenger NS, Solomon DH, Roth CP, et al. The quality of medical care provided to vulnerable community-dwelling older patients. Ann Intern Med. 2003;139(9):740-7. [pmid: 14597458].
2 Wenger NS, Rosenfeld K. Quality indicators for end-of-life care in vulnerable elders. Ann Intern Med. 2001;135(8 Pt 2):677-85. [pmid: 11601950].
3 Ryndes T, Connor S, Cody C, Merriman M, Bruno S, Fine P, et al. Report on the alpha and beta pilots of end result outcome measures constructed by the outcomes forum.
4 National Hospice and Palliative Care Organization (NHPCO). Instructions for use of the six measures.
5 Maxwell T, Cuny J. The UHC palliative care benchmarking project. University Health System Consortium 2004;1–35.
6 VHA. Transformation of the Intensive Care Unit. Palliative Care Bundle: Care and Communication Measurement Guide. 2005.
7 Earle CC, Park ER, Lai B, et al. Identifying potential indicators of the quality of end-of-life cancer care from administrative data. J Clin Oncol. 2003;21(6):1133-38. [pmid: 12637481].
8 Earle CC, Neville BA, Landrum MB, et al. Evaluating claims-based indicators of the intensity of end-of-life cancer care.
9 Grunfeld E, et al. Nova Scotia and Ontario quality end of life indicators project. 2005.
10 National Cancer Policy Board (NCPB). Assessing the quality of cancer care: an approach to measurement in Georgia.: The National Academies Press. 2005.
11 Wu JS, Wong R, Johnston M, Bezjak A, Whelan T, Laetsch N , et al. Radiotherapy fractionation for the palliation of uncomplicated painful bone metastases.: Program in Evidence-Based Care. 2003.
12 Conor SR, Tecca M, Lund Person J, et al. Measuring hospice care: the national hospice and palliative care organization national hospice data set. J Pain Symptom Manage. 2004;28(4):316-28. [pmid: 15471649].
13 Dokken DL, Heller KS, Levetown M, et al. Quality domains, goals and indicators for family-centered care of children living with life-threatening conditions. Education Development Center, Inc. 2002.
14 Lilly CM, De Meo DL, Sonna LA, et al. An intensive communication intervention for the critically ill. Am J Med. 2000;109(6):469-75. [pmid: 11042236].
15 National Comprehensive Cancer Network (NCCN). Palliative care. Clinical Practice Guidelines in Oncology 2004;(1)
16 Clinical practice guidelines for quality palliative care.: National Consensus Project for Quality Palliative Care. 2004.
17 Standards and Quality Committee. Standards for palliative care provision. Australia. 1999.
18 Clarke EB, Curtis JR, Luce JM, et al. Quality indicators for end-of-life care in the intensive care unit. Crit Care Med. 2003;31(9):2255-62. [pmid: 14501954].
19 Masera G, Spinetta JJ, Jankovic M, et al. Guidelines for assistance to terminally ill children with cancer: a report of the SIOP Working Committee on psychosocial issues in pediatric oncology. Med Pediatr Oncol. 1999;32(1):44-8. [pmid: 9917752].
20 American Academy of Pediatrics. Committee on Bioethics and Committee on Hospital Care. Palliative care for children. Pediatrics. 2000;106(2 Pt 1):351-7. [pmid: 10920167].
21 Mitchell SL, Berkowitz RE, Lawson FME, et al. A cross-national survey of tube-feeding decisions in cognitively impaired older persons. Journal of the American Geriatrics Society. 2000;48(4):391-7. [pmid: 10798465].
22 Widger KA, Wilkins K. What are the key components of quality perinatal and pediatric end-of-life care? A literature review. J Palliat Care. 2004;20(2):105-12. [pmid: 15332475].