# Appendix F3. Quality Measures and Indicators for Supportive Cancer Care: Depression

No. | Measure or Indicator Set/ Reference / Year | Description of measure or indicator | Denominator | Numerator | Disease | Patient Characteristics | Setting | Data Source, Reliability, and Validity
Assessment
1 | UHC | (Measure) Regular assessment for psychosocial well-being. | Adults > or = 18 years of age, with admission for CHF (DRG 127), Cancer (DRG 82, 203, 172, 274, 346, 10) HIV (DRG 489) OR respiratory (DRG 475, 483) AND length of stay > 4 days, 2 prior admissions for any cause in preceding 12 months in the hospital. | Formal psychosocial assessment up to 1 year prior to admission during a previous hospitalization OR within 4 days of index admission. | CHF | Adult | Hospital (non-ICU) | Chart
| Maxwell, T.^1^ | | | | Mixed cancer | Average age is 58.4 | Hospital (ICU) | Reliability / Validity not reported
| | | | | HIV | Lower boundary for age is 18
| | | | | Mixed respiratory diseases
2 | ACOVE End of Life | (Indicator) Regular spiritual assessment in expected dying. | Vulnerable elder who was conscious during the last 3 days of life. | Vulnerable elder with documentation of spiritual assessment in the medical record. | Not Reported | Not Reported | All settings | Patient interview / survey
| Wenger, N.S.^2^ | IF a vulnerable elder who was conscious during the last 3 days of life died an expected death, THEN the medical record should contain documentation about spirituality or how the patient was dealing with death or religious feelings. | | | | | | Chart
| Saliba, D.^3^ | | | | | | | Reliability / Validity not reported
Treatment
3 | ACOVE | (Measure) Regular assessment or treatment of depression in newly diagnosed cancer. | Vulnerable elders presenting with onset or discovery malignancy (excluding skin cancer) and other conditions*. | Patients asked about or treated for depression, or referred to a mental health professional within two months of diagnosis of a condition. | Saliba, D.: | Adult | All settings | Patient interview / survey
| Wenger, N.S.^2^ | | | | Mixed nursing home population for 11 diagnoses, not cancer | | | Chart
| Saliba, D.^3^ | | | | | | | Reliability / Validity not reported
| Nakajima, G.A.^4^
4 | ACOVE | (Measure) Routine assessment or treatment of depression in symptomatic patients. | Vulnerable elders presenting with new onset of one the following symptoms: sad mood, feeling down; insomnia or difficulties with sleep; apathy or loss of interest in pleasurable activities; complaints of memory loss; unexplained weight loss of greater than 5% in the past month or 10% over one year; or unexplained fatigue or low energy. | Patients asked about or treated for depression, or referred to a mental health professional within two weeks of presentation. | Saliba, D.: | Adult | All settings | Patient interview / survey
| Wenger, N.S.^2^ | | | | Mixed nursing home population for 11 diagnoses, not cancer | | | Chart
| Saliba, D.^3^ | | | | | | | Reliability / Validity not reported
| Nakajima, G.A.^4^
Potential Indicators Assessment
5 | ACOVE End of Life | IF a vulnerable elder has thoughts of suicide THEN the medical record should document, on the same date, that the patient either has no immediate plan for suicide, or that the patient was referred for evaluation for psychiatric hospitalization. | Vulnerable elders with thoughts of suicide. | Patients where medical record documents, on the same date, that the patient either has no immediate plan for suicide, or that the patient was referred for evaluation for psychiatric hospitalization. | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported
6 | ACOVE End of Life | IF a vulnerable elder receives a diagnosis of a new depression episode THEN the medical record should document at least three of the nine Diagnostic and Statistical Manual (DSM) IV target symptoms for major depression within the first month of diagnosis. | Vulnerable elders with diagnosis of a new depression episode. | Patients where the medical record documents at least three of the nine DSM-IV target symptoms for major depression within the first month of diagnosis. | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported
7 | ACOVE End of Life | IF a vulnerable elder receives a diagnosis of a new depression episode THEN the medical record should document, on the day of diagnosis, the presence or absence of suicidal ideation. | Vulnerable elders with diagnosis of a new depression episode. | Patients where the medical record document on the day of diagnosis the presence or absence of suicidal ideation and psychosis (consisting of, at a minimum, auditory hallucinations or delusions). | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported
Potential Indicators Treatment
8 | ACOVE End of Life | IF a vulnerable elder is being treated for depression with antidepressants THEN the antidepressants should be prescribed at appropriate starting doses, and they should have an appropriate titration schedule to a therapeutic dose, therapeutic blood level, or remission of symptoms by 12 weeks. | Vulnerable elders being treated for depression with antidepressants. | Patients with antidepressants prescribed at appropriate starting doses, and with an appropriate titration schedule to a therapeutic dose, therapeutic blood level, or remission of symptoms by 12 weeks. | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported
9 | ACOVE End of Life | IF a vulnerable elder has no meaningful symptom response after 6 weeks of treatment THEN one of the following should be initiated by the eighth week of treatment: Optimization of medication (i.e., alter dose of initial medication; change to or add a different medication); psychiatric referral (if initial treatment was medication); or medication trial (if initial treatment was psychotherapy alone). | Vulnerable elders with depression and no meaningful symptom response after 6 weeks of treatment. | Patients with one of the following treatment options initiated by the 8th week of treatment: medication dose should be optimized or the patient should be referred to a psychiatrist (if initial treatment was medication); or medication should be initiated or referral to a psychiatrist should be offered (if initial treatment was psychotherapy alone). | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported
Potential Indicators Follow-up
10 | ACOVE End of Life | IF a vulnerable elder responds only partially after 12 weeks of treatment THEN at least one of the following treatment options should be instituted by the 16th week of treatment: switch to a different medication class or add a second medication to the first (if initial treatment includes medication); add psychotherapy (if the initial treatment was medication); a trial of medication (if initial treatment was psychotherapy without medication), consider electroconvulsive therapy, or referral to a psychiatrist. | Vulnerable elders responding only partially after 12 weeks of treatment. | Patients with one of the following treatment options instituted by the 16th week of treatment: switch to a different medication class or add a second medication to the first (if initial treatment includes medication); add psychotherapy (if the initial treatment was medication); try medication (if initial treatment was psychotherapy without medication); consider ECT; or refer to a psychiatrist. | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported
11 | ACOVE End of Life | IF a vulnerable elder has responded to antidepressant medication THEN he or she should be continued on the drug at the same dosage for at least 6 months, and at least one physician documentation about depression should occur during that time period | Vulnerable elders responding to antidepressant medication. | Patients continued on the drug at the same dose for at least six months, and making at least one clinician contact (office visit or phone) during that time period. | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported
12 | ACOVE End of Life | IF a vulnerable elder is diagnosed with depression THEN antidepressant treatment, psychotherapy, or electroconvulsive therapy should be offered within 2 weeks after diagnosis unless there is documentation within that period that the patient has improved, or unless the patient has substance abuse or dependence, in which case treatment could wait until 8 weeks after the patient is in a drug- or alcohol-free state. | Vulnerable elders with diagnosis of a new depression episode. | Patients with antidepressant treatment, psychotherapy, or electroconvulsive therapy (ECT) be offered within two weeks after diagnosis unless there is documentation within that period that the patient has improved, or unless the patient has substance abuse or dependence, in which case treatment may wait until eight weeks after the patient is in a drug or alcohol free state. | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported
13 | ACOVE End of Life | IF a vulnerable elder is started on an antidepressant medication THEN the following medications should not be used as first- or second-line therapy: tertiary amine tricyclics (amitriptyline, imipramine, doxepin, clomipramine, trimipramine); monoamine oxiase inhibitors (MAOIs) (unless atypical depression is present); benzodiazepines; or stimulants (except methylphenidate). | Vulnerable elders being treated for depression with antidepressants. | Patients where the following medications are not used as first- or second-line therapy: tertiary amine tricyclics, monoamine oxidase inhibitors (unless atypical depression is present), benzodiazepines, or stimulants (except methylphenidate). | Not Reported | Adult | All settings | Chart
| Nakajima, G.A.^4^ | | | | | | | Reliability / Validity not reported

* Other conditions include stroke, myocardial infarction, dementia, chronic pain, alcohol or substance abuse or dependence, anxiety disorder, or personality disorder.

## Reference List for Appendix F3

1 Maxwell T, Cuny J. The UHC palliative care benchmarking project. University Health System Consortium 2004;1–35.
2 Wenger NS, Solomon DH, Roth CP, et al. The quality of medical care provided to vulnerable community-dwelling older patients. Ann Intern Med. 2003;139(9):740-7. [pmid: 14597458].
3 Saliba D, Solomon D, Rubenstein L, et al. Feasibility of quality indicators for the management of geriatric syndromes in nursing home residents. J Am Med Dir Assoc. 2004;5(5):310-9. [pmid: 15357888].
4 Nakajima GA, Wenger NS. Quality indicators for the care of depression in vulnerable elders.: RAND.