# Appendix F2. Quality Measures and Indicators for Supportive Cancer Care: Dyspnea

No. | Measure or Indicator Set/ Reference / Year | Description of measure or indicator | Denominator | Numerator | Disease | Patient Characteristics | Setting | Data Source, Reliability, and Validity
Assessment
1 | UHC | (Measure) Regular assessment of dyspnea. | Adults > or = 18 years of age, with admission for CHF (DRG 127), Cancer (DRG 82, 203, 172, 274, 346, 10) HIV (DRG 489) OR respiratory (DRG 475, 483) AND length of stay > 4 days AND 2 prior admissions for any cause in preceding 12 months in the hospital. | Dyspnea assessment within 48 hours of admission. | CHF | Adult | Hospital (non-ICU) | Chart
| Maxwell, T.^1^ | | | | Mixed cancer | Average age is 58.4 | Hospital (ICU) | Reliability / Validity not reported
| | | | | HIV | Lower boundary for age is 18
| | | | | Mixed respiratory diseases
Treatment
2 | ACOVE End of Life | (Indicator) Effective dyspnea treatment in expected dying. | Noncomatose vulnerable elders who are not expected to survive and a mechanical ventilator is withdrawn or intubation is withheld. | Patient received or had ordered an opiate or benzodiazepine or barbiturate infusion to reduce dyspnea and the chart documented whether the patient has dyspnea. | Not Reported | Adult | All settings | Chart
| Wenger, N.S.^2^ | IF a noncomatose vulnerable elder is not expected to survive and a mechanical ventilator is withdrawn or intubation is withheld, THEN the patient should receive (or have orders available for) an opiate of benzodiazepine or barbiturate infusion to reduce dyspnea, and the chart should document whether the patient has dyspnea. | | | | | | Reliability / Validity not reported
3 | ACOVE End of Life | (Indicator) Regular treatment and follow-up of dyspnea in expected dying. | Vulnerable elders who had dyspnea in the last 7 days of life and died expected deaths. | Chart documents how dyspnea was treated and follow-up about the dyspnea. | Not Reported | Adult | All settings | Chart
| Wenger, N.S.^2^ | IF a vulnerable elder who had dyspnea in the last 7 days of life died an expected death, THEN the chart should document how the dyspnea was treated and follow-up should be documented about the dyspnea. | | | | | | Reliability / Validity not reported
4 | QA Tools | (Indicator) Treatment of dyspnea caused by hypoxia. | Patients with dyspnea and baseline room air oxygen saturation < 88% at rest. | Therapy with home oxygen was used. | COPD | Adult | Not Reported | Chart
| Golomb, B.^3^ | | | | | | | Reliability / Validity not reported
| McGlynn, E.A.^4^
| Asch, S.M.^5^
Follow-up
5 | UHC | (Measure) Timely treatment of inpatient dyspnea. | Adults > or = 18 years of age, with admission for CHF (DRG 127), Cancer (DRG 82, 203, 172, 274, 346, 10) HIV (DRG 489) OR respiratory (DRG 475, 483) AND length of stay > 4 days, 2 prior admissions for any cause in preceding 12 months in the hospital , AND reported dyspnea within the 1st 48 hours of admission. | Dyspnea relief or reduction within 48 hours of admission. | CHF | Adult | Hospital (non-ICU) | Chart
| Maxwell, T.^1^ | | | | Mixed cancer | Average age is 58.4 | Hospital (ICU) | Reliability / Validity not reported
| | | | | HIV | Lower boundary for age is 18
| | | | | Mixed respiratory diseases
Potential Indicators Assessment
6 | Dudgeon, D.J.^6^ | The optimal treatment for breathlessness is correction of the cause. | Patients with dyspnea. | Evaluation was performed to search for correctable conditions as causative for dyspnea. | Mixed cancer | Adult | Not Reported | Data source not reported
| Kvale, P.A.^7^ | In all patients with lung cancer, potentially correctable causes of dyspnea, such as localized obstruction of a major airway, a large pleural effusion, or an exacerbation of coexisting COPD, should be sought initially. | | | Lung cancer | | | Reliability / Validity not reported
| Dyspnea. Mechanisms, assessment, and management: a consensus statement. American Thoracic Society^8^ | Diagnostic testing ... to identify the specific nature of the disorder ... is the cornerstone of the assessment of dyspnea and leads to a correct diagnosis in many, but not all, cases. Correction or amelioration of the disorder follows and generally reduces the intensity of dyspnea, increases the comfort with which patients perform activities, and increases their capacity to exercise. | | | COPD
| Ferguson, G.T.^9^ | Spirometry ... is recommended for patients with respiratory symptoms such as chronic cough, episodic wheezing, and exertional dyspnea in order to detect airways obstruction.
Potential Indicators Treatment
7 | Kvale, P.A.^7^ | Patients with malignant pleural effusions that cause dyspnea initially should be drained by thoracentesis. | Patients with cancer and dyspnea caused by malignant pleural effusion. | Therapy with thorocentesis and appropriate subsequent therapy (pleurodesis, chemotherapy, or other) | Lung cancer | Adult | Not Reported | Data source not reported
| | Patients with NSCLC and better performance status and recurrent malignant pleural effusions, and whose lungs re-expand with initial thoracentesis or thoracoscopy, should be followed up by pleurodesis. | | | Mixed cancer | | | Reliability / Validity not reported
| | In patients with SCLC, the treatment of choice for malignant effusions is systemic chemotherapy.
8 | Kvale, P.A.^7^ | For patients with central airway obstruction, bronchoscopy should be done to determine the type of airway obstruction (extraluminal tumor compression of the major airways, intraluminal tumor growth, or both). | Patients with cancer and dyspnea caused by central airway obstruction. | Diagnostic bronchoscopy and bronchoscopic therapy (laser, electrocautery, stent, argon plasma coagulation, cryotherapy, brachytherapy, and/or photodynamic therapy) was offered or received. | Mixed cancer | Adult | Not Reported | Data source not reported
| | In patients with central airway obstruction, rapid relief of dyspnea can be accomplished via bronchoscopy with removal of intraluminal tumor (laser, electrocautery, APC) and/or by inserting a stent. | | | | | | Reliability / Validity not reported
9 | Kvale, P.A.^7^ | For all lung cancer patients with dyspnea, nonpharmacologic, noninterventional treatments including patient education and intervention by allied health personnel should be used to help control dyspnea, including breathing control, activity pacing, relaxation techniques, fans, and psychosocial support. | Patients with cancer and dyspnea. | Therapy with nonpharmacologic and noninterventional approaches (including breathing control, activity pacing, relaxation techniques, fans, and psychosocial support), including patient education, was received. | Mixed cancer | Adult | Not Reported | Data source not reported
| | | | | | | | Reliability / Validity not reported
10 | Socinski, M.A.^10^ | Data from case series and randomized trials show that chemotherapy can have a palliative effect on disease-related symptoms [especially dyspnea, cough, and chest pain] and can improve QOL compared to BSC in stage IV NSCLC patients who are deemed suitable for treatment. | Patients with appropriate malignancies and dyspnea. | Palliative chemotherapy or radiotherapy (external beam, brachytherapy, and photodynamic therapy) was offered or received for patients who are deemed suitable for treatment. | Mixed cancer | Not Reported | Not Reported | Data source not reported
| Pfister, D.G.^11^ | Brachytherapy, photodynamic therapy, and the laser ... have been found to produce effective palliation of symptomatic endobronchial disease, with palliation of cough, hemoptysis, and dyspnea. | | | | | | Reliability / Validity not reported
11 | Kvale, P.A.^7^ | For all lung cancer patients with dyspnea, pharmacologic approaches for the management of dyspnea may include oxygen, bronchodilators, corticosteroids, antibiotics, and opioids. | Patients with cancer and dyspnea. | Therapy with pharmacologic approaches (including oxygen, bronchodilators, corticosteroids, antibiotics, anxiolytics, and opiates) were offered or received in appropriate conditions as part of the palliative management. | Lung cancer | Adult | Not Reported | Data source not reported
| Dyspnea. Mechanisms, assessment, and management: a consensus statement. American Thoracic Society^8^ | It is reasonable to recommend a trial of anxiolytic therapy on an individual basis, particularly in those with morbid anxiety or respiratory panic attacks. | | | Mixed cancer | | | Reliability / Validity not reported
| Jennings, A.L.^12^ | Bronchodilators have been shown ... to improve dyspnea [in those with obstructive lung disease]. | | | CHF
| Booth, S.^13^ | This review shows statistically strong evidence for a small and probably clinically significant effect of oral or parenteral opioids in the treatment of breathlessness. | | | COPD
| | Opiates acutely relieve dyspnea and improve exercise performance ...; despite safety concerns, these drugs do have a place in the management of patients in the terminal phase of their illness. | | | Infection
| | Oxygen therapy may be one part of the palliative or supportive care of patients with cancer.

## Reference List for Appendix F2

1 Maxwell T, Cuny J. The UHC palliative care benchmarking project. University Health System Consortium 2004;1–35.
2 Wenger NS, Rosenfeld K. Quality indicators for end-of-life care in vulnerable elders. Ann Intern Med. 2001;135(8 Pt 2):677-85. [pmid: 11601950].
3 Golomb B. Chronic obstructive pulmonary disease. In: Kerr EA, Asch SM, Hamilton EG, McGlynn EA. Quality of care for cardiopulmonary conditions: a review of the literature and quality indicators. RAND; 2000. p. 91–109.
4 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-45. [pmid: 12826639].
5 Asch SM, McGlynn EA, Hogan MM, et al. Comparison of quality of care for patients in the Veterans Health Administration and patients in a national sample. Ann Intern Med. 2004;141(12):938-45. [pmid: 15611491].
6 Dudgeon DJ, Lertzman M. Dyspnea in the advanced cancer patient. J Pain Symptom Manage 1998;16(4):212–9. Comment in: J Pain Symptom Manage. Nov. 1999;18(5):313-5. PMID: 10584452.
7 Kvale PA, Simoff M, Prakash UB. Lung cancer. Palliative care. Chest. 2003;123(1 Suppl):284S-311S. [pmid: 12527586].
8 Dyspnea. Mechanisms, assessment, and management: a consensus statement. American Thoracic Society. Am J Respir Crit Care Med. 1999;159(1):321-40. [pmid: 9872857].
9 Ferguson GT, Enright PL, Buist AS, et al. Office spirometry for lung health assessment in adults: a consensus statement from the National Lung Health Education Program. Chest. 2000;117(4):1146-61. [pmid: 10767253].
10 Socinski MA, Morris DE, Masters GA, et al. Chemotherapeutic management of stage IV non-small cell lung cancer. Chest. 2003;123(1 Suppl):226S-243S. [pmid: 12527582].
11 Pfister DG, Johnson DH, Azzoli CG, et al. American Society of Clinical Oncology treatment of unresectable non-small-cell lung cancer guideline: update 2003. J Clin Oncol. 2004;22(2):330-53. [pmid: 14691125].
12 Jennings AL, Davies AN, Higgins JP, et al. Opioids for the palliation of breathlessness in terminal illness. Cochrane Database Syst Rev 2001;(4):CD002066 .
13 Booth S, Wade R, Johnson M, et al. The use of oxygen in the palliation of breathlessness. A report of the expert working group of the Scientific Committee of the Association of Palliative Medicine. Respir Med. 2004;98(1):66-77. [pmid: 14959816].