# Appendix F1. Quality Measures and Indicators for Supportive Cancer Care: Pain

No. | Measure or Indicator Set/ Reference / Year | Description of measure or indicator | Denominator | Numerator | Disease | Patient Characteristics | Setting | Data Source, Reliability, and Validity
Assessment
1 | QA Tools | (Measure) Regular assessment of Pain. | All patients with metastatic cancer to bone. | Patients with the presence or absence of pain noted at least every 6 months. | Mixed cancer | McGlynn, E. A.: | McGlynn, E. A.: | McGlynn, E. A.:
| RAND^1^ | | | | | Adult | Community | Chart
| McGlynn, E.A.^2^ | | | | | White | Asch, S. M.: | Reliability reported
| Asch, S.M.^3^ | | | | | Other (Non-White) | Community | Asch, S. M.:
| | | | | | 60% Male | (including veteran sample) | Chart
| | | | | | Average age is 45.5
| | | | | | Age ranges from 18 to 97
| | | | | | Asch, S. M.:
| | | | | | 100% Male
| | | | | | Average age is 63.0
2 | UHC | (Measure) Routine inpatient pain assessment. | Adults > or = 18 years of age, with admission for CHF (DRG 127), Cancer (DRG 82, 203, 172, 274, 346, 10) HIV (DRG 489) OR respiratory (DRG 475, 483) AND length of stay > 4 days, 2 prior admissions for any cause in preceding 12 months in the hospital. | Pain assessment within 48 hours of admission on chart review. | CHF | Adult | Hospital (non-ICU) | Chart
| Maxwell, T.^4^ | | | | Mixed cancer | Average age is 58.4 | Hospital (ICU) | Reliability / Validity not reported
| | | | | HIV | Lower boundary for age is 18
| | | | | Mixed respiratory diseases
3 | UHC | (Measure) Routine inpatient pain assessment with a numeric scale. | Adults > or = 18 years of age, with admission for CHF (DRG 127), Cancer (DRG 82, 203, 172, 274, 346, 10) HIV (DRG 489) OR respiratory (DRG 475, 483) AND length of stay > 4 days, 2 prior admissions for any cause in preceding 12 months in the hospital , AND reported pain within the 1st 48 hours of admission. | Persons assessed with a numeric pain scale. | CHF | Adult | Hospital (non-ICU) | Chart
| Maxwell, T.^4^ | | | | Mixed cancer | Average age is 58.4 | Hospital (ICU) | Reliability / Validity not reported
| | | | | HIV | Lower boundary for age is 18
| | | | | Mixed respiratory diseases
4 | VHA | (Measure) Regular ICU pain assessment. | 4 hour periods during which the patients physically present in the ICU, including the initial period if at least present for 2 hours. | Total number of 4-hour intervals (within the first 24 hours following ICU admission) for which pain was assessed and documented, using an appropriate rating scale. | Mixed ICU Population | Not Reported | Hospital (ICU) | Data source not reported
| VHA Updated March 2005^5^ | | | | | | | Reliability / Validity not reported
| Pronovost, P.J.^6^
| Erdek, M.A.^7^
5 | QOPI | (Measure) Assessing pain in patients close to death. | Recently deceased patients from oncology practices. | Medical records where there is an explicit practioner's notation quantifying their physical pain or lack thereof on their last visit to the office prior to death. | Mixed cancer | Not Reported | Ambulatory / outpatient care | Chart
| Neuss, M.N.^8^ | | | | | | | Reliability / Validity not reported
6 | ACOVE End of Life | (Indicator) Routine pain assessment in expected dying. | Vulnerable elders who are conscious during the last 3 days of life. | Number of vulnerable elders with documentation of pain or lack of pain during the last 3 days of life. | Not Reported | Wenger, N. S.: | Wenger, N. S.: | Patient interview / survey
| Wenger, N.S.^9^ | IF a VE who was conscious during the last 3 days and died an expected death THEN the medical record should contain documentation about pain or lack of pain during the last 3 days of life. | | | | Adult | Not Reported | Chart
| Saliba, D.^10^ | | | | | 36% Male | Saliba, D.: | Reliability / Validity not reported
| | | | | | Average age is 81.0 | Nursing home
7 | Cancer Care Georgia | (Indicator) Routine assessment of pain. | Number of cancer patient encounters. | Number of cancer patient encounters where patient where patient was assessed for pain. | Mixed cancer | Not Reported | Not Reported | Data source not reported
| National Cancer Policy Board (NCPB)^11^ | | | | | | | Reliability / Validity not reported
Treatment
8 | QA Tools | (Measure) Responsive pain treatment. | All cancer patients whose pain is uncontrolled. | Patients offered a change in pain management within 24hours of the pain complaint. | Mixed cancer | McGlynn, E. A.: | McGlynn, E. A.: | McGlynn, E. A.:
| RAND^1^ | | | | | Adult | Community | Chart
| McGlynn, E.A.^2^ | | | | | White | Asch, S. M.: | Reliability reported
| Asch, S.M.^3^ | | | | | Other (Non-White) | Community | Asch, S. M.:
| | | | | | 60% Male | (including veteran sample) | Chart
| | | | | | Average age is 45.5
| | | | | | Age ranges from 18 to 97
| | | | | | Asch, S. M.:
| | | | | | 100% Male
| | | | | | Average age is 63.0
9 | UHC | (Measure) Regular prophylaxis of opiate-induced constipation. | Adults > or = 18 years of age, with admission for CHF (DRG 127), Cancer (DRG 82, 203, 172, 274, 346, 10) HIV (DRG 489) OR respiratory (DRG 475, 483) AND length of stay > 4 days, 2 prior admissions for any cause in preceding 12 months in the hospital , AND treated with narcotics. | Proportion with a bowel regimen ordered within 24 hours of the opioid ordered and not contraindicated. | CHF | Average age is 58.4 | Hospital (non-ICU) | Chart
| Maxwell, T.^4^ | | | | Mixed cancer | Lower boundary for age is 18 | Hospital (ICU) | Reliability / Validity not reported
| | | | | HIV
| | | | | Mixed respiratory diseases
10 | Wu, J.S.^12^ | (Indicator) Minimizing radiotherapy burden. | All adult patients with single of multiple radiographically confirmed bone metastases of any histology corresponding to painful areas in previously nonirradiated areas without pathologic fractures or spinal cord/cauda equina compression. It does not apply to the management of malignant primary bone tumor. For patients receiving radiotherapy where the objective / intent is pain relief. | % of those patients receiving single dose therapy as a single 8Gy treatment, prescribed to the appropriate target volume. | Mixed cancer | Adult | Not Reported | Data source not reported
| | | | | | | | Reliability / Validity not reported
11 | Cancer Care Nova Scotia | (Indicator) Effective treatment for painful bony metastasis. | Patients with uncontrolled bone pain. | Patients who are offered within one week of the notation of pain: - radiation therapy to the sites of pain. | Mixed cancer | All patients in the population with cancer | Not Reported | Cancer registry, administrative claim data, hospital discharge abstract
| Grunfeld, E.^13^ | | | | | | | Reliability / Validity not reported
Follow-up
12 | NHPCO | (Measure) Timely treatment of pain in hospice. | Patients admitted to hospice who answer 'yes' when asked “Are you uncomfortable because of pain?”. | The proportion of patients between 48 and 120 hours after admission who report 'yes' when asked “Was your pain brought to an acceptable level within 48 hours of your admission to the hospice program?”. | Mixed hospice population | NHPCO: | Hospice | Patient interview / survey
| National Hospice and Palliative Care Organization (NHPCO)^14^ | | | | | Adult | | Reliability / Validity not reported
| Connor, S.R.^15^ | | | | | Connor, S. R.:
| Ryndes, T.^16^ | | | | | Adult
| | | | | | White
| | | | | | African American
| | | | | | Hispanic
| | | | | | Asian
| | | | | | Native American / Eskimo
| | | | | | 44% Male
13 | VHA | (Measure) Effective treatment of pain in the ICU. | Total number of 4-hour intervals (within the first 24 hours following ICU admission) with numerical pain values of 1 to 10, for patients with an ICU length of stay >=24 hours. | Total number of 4-hour intervals (within the first 24 hours following ICU admission) for which the documented pain score was <3. | Mixed ICU Population | Not Reported | Hospital (ICU) | Data source not reported
| Updated March 2005^5^ | | | | | | | Reliability / Validity not reported
| Pronovost, P.J.^6^
| Erdek, M.A.^7^
14 | Cancer Care Ontario^17^ | (Measure) Satisfaction with pain treatment. | Outpatient cancer patients reporting mild to severe pain. | Patients where the response to the question “Do you think staff did everything they could to control your pain or discomfort?” was (1) yes, completely; (2) yes, somewhat; or (3) no. | Mixed cancer | Not Reported | Ambulatory / outpatient care | Patient interview / survey
| | | | | | | | Reliability / Validity not reported
15 | UHC | (Measure) Timely treatment of inpatient pain. | Adults > or = 18 years of age, with admission for CHF (DRG 127), Cancer (DRG 82, 203, 172, 274, 346, 10) HIV (DRG 489) OR respiratory (DRG 475, 483) AND length of stay > 4 days, 2 prior admissions for any cause in preceding 12 months in the hospital , AND reported pain within the 1st 48 hours of admission. | Persons with pain relief or reduction within 48 hours of admission < or = 3 on 0–10 scale. | CHF | Adult | Hospital (non-ICU) | Chart
| Maxwell, T.^4^ | | | | Mixed cancer | Average age is 58.4 | Hospital (ICU) | Reliability / Validity not reported
| | | | | HIV | Lower boundary for age is 18
| | | | | Mixed respiratory diseases
16 | Cancer Care Georgia | (Indicator) Effective treatment of pain. | Number of cancer patients who are not comatose. | Number of cancer patients who report being in more than minor pain. | Mixed cancer | Not Reported | Not Reported | Data source not reported
| National Cancer Policy Board (NCPB)^11^ | | | | | | | Reliability / Validity not reported
Potential Indicators Assessment
17 | Erdek, M.A.^7^ | Physician documentation of pain assessment. | All patients with cancer. | Patients where a pain assessment is documented in the physician note.
18 | Green, C.R.^18^ | Disparities in pain assessment. | All patients with cancer who are assessed for pain. | Non-white patients with cancer who are assessed for pain.
19 | Ferrell, B.R.^19^ | Assessment in patients who cannot verbalize their pain. | Cancer patients who have difficulty verbalizing their pain. | Patients who are assessed for pain.
20 | Carr, D.B.^20^ | Assessment for depression in patients with pain. | All cancer patients with pain. | Patients assessed for depression.
Potential Indicators Treatment
21 | Allard, P.^21^ | Education about pain management. | Cancer patients with pain. | Patients who are educated about pain management.
| Gordon, D.B.^22^
22 | Marinangeli, F.^23^ | Use of opioids for sever, persistent pain. | Cancer patients with severe, persistent pain. | Patients who are treated with opioids.
| Gordon, D.B.^22^
23 | NIH State-of-the-Science Statement^24^ | Use of long-acting pain medications. | All adults with cancer who have persistent pain and are prescribed opioids. | Adults who are prescribed long acting opioids.
24 | World Health Organization (WHO)^25^ | Procedure-related pain in children. | All children with cancer receiving painful procedures. | Children who receive appropriate preparation and/or anesthesia.

## Reference List for Appendix F1

1 In: Asch SM, Kerr EA, Hamilton EG, Reifel JL, McGlynn EA. Quality of care for oncologic condition and HIV: a review of the literature and quality indicators. RAND; 2000.
2 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-45. [pmid: 12826639].
3 Asch SM, McGlynn EA, Hogan MM, et al. Comparison of quality of care for patients in the Veterans Health Administration and patients in a national sample. Ann Intern Med. 2004;141(12):938-45. [pmid: 15611491].
4 Maxwell T, Cuny J. The UHC palliative care benchmarking project. University Health System Consortium 2004;1–35.
5 VHA. Transformation of the Intensive Care Unit. Palliative Care Bundle: Care and Communication Measurement Guide. 2005.
6 Pronovost PJ, Berenholtz SM. A practical guide to measuring performance in the intensive care unit.: VHA. 2002.
7 Erdek MA, Pronovost PJ. Improving assessment and treatment of pain in the critically ill. Int J Qual Health Care. 2004;16(1):59-64. [pmid: 15020561].
8 Neuss MN, Desch CE, McNiff KK, et al. A process for measuring the quality of cancer care: the Quality Oncology Practice Initiative. J Clin Oncol. 2005;23(25):6233-9. [pmid: 16087948].
9 Wenger NS, Rosenfeld K. Quality indicators for end-of-life care in vulnerable elders. Ann Intern Med. 2001;135(8 Pt 2):677-85. [pmid: 11601950].
10 Saliba D, Solomon D, Rubenstein L, et al. Feasibility of quality indicators for the management of geriatric syndromes in nursing home residents. J Am Med Dir Assoc. 2004;5(5):310-9. [pmid: 15357888].
11 National Cancer Policy Board (NCPB). Assessing the quality of cancer care: an approach to measurement in Georgia.: The National Academies Press. 2005.
12 Wu JS, Wong R, Johnston M, Bezjak A, Whelan T, Laetsch N , et al. Radiotherapy fractionation for the palliation of uncomplicated painful bone metastases.: Program in Evidence-Based Care. 2003.
13 Grunfeld E, et al. Nova Scotia and Ontario quality end of life indicators project. 2005.
14 National Hospice and Palliative Care Organization (NHPCO). Instructions for use of the six measures.
15 Conor SR, Tecca M, Lund Person J, et al. Measuring hospice care: the national hospice and palliative care organization national hospice data set. J Pain Symptom Manage. 2004;28(4):316-28. [pmid: 15471649].
16 Ryndes T, Connor S, Cody C, Merriman M, Bruno S, Fine P, et al. Report on the alpha and beta pilots of end result outcome measures constructed by the outcomes forum.
17 Cancer Care Ontario. Cancer system quality index: satisfaction with pain management. Ontario, Canada: Cancer Care Ontario. 2005.
18 Green CR, Anderson KO, Baker TA, et al. The unequal burden of pain: confronting racial and ethnic disparities in pain. Pain Med. 2003;4(3):277-94. [pmid: 12974827].
19 Ferrell BA, Ferrell BR, Rivera L. Pain in cognitively impaired nursing home patients. J Pain Symptom Manage. 1995;10(8):591-8. [pmid: 8594119].
20 Carr DB, Goudas LC, Balk EM, et al. Evidence report on the treatment of pain in cancer patients. J Natl Cancer Inst Monogr 2004;(32):23–31.
21 Allard P, Maunsell E, Labbe J, et al. Educational interventions to improve cancer pain control: a systematic review. J Palliat Med. 2001;4(2):191-203. [pmid: 11441627].
22 Gordon DB, Dahl JL, Miaskowski C, et al. American pain society recommendations for improving the quality of acute and cancer pain management: American Pain Society Quality of Care Task Force. Arch Intern Med. 2005;165(14):1574-80. [pmid: 16043674].
23 Marinangeli F, Ciccozzi A, Leonardis M, et al. Use of strong opioids in advanced cancer pain: a randomized trial. J Pain Symptom Manage. 2004;27(5):409-16. [pmid: 15120769].
NIH State-of-the-Science Statement on symptom management in cancer: pain, depression, and fatigue. NIH Consensus State Sci Statements 2002;19(4):1–29.
25 World Health Organization (WHO). Cancer pain relief and palliative care in children. 1998.