# Appendix D. RAND SCEPC Cancer Quality Measures Project - Measure Developer Contact Form

Measure Developer Contact Form