# Appendix C. Literature Search Strategies

SEARCH METHODOLOGIES - END OF LIFE CANCER MEASUREMENT CINAHL

DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL - 1995-2005

OTHER LIMITERS:

ENGLISH

HUMAN

SEARCH STRATEGY #1 (PAIN NOT PALLIATIVE)

(neoplasm$ or cancer$ or tumour$ or tumor$ or carcinoma$ or adenocarcinoma$ or malignan$).mp. [mp=title, cinahl subject headings, abstract, instrumentation]

AND

(guideline$ or audit$ or outcome$ or peer review$ or professional review$ or evaluat$ or benchmark$ or utilization review$ or consensus or perform$ or quality).mp.

AND

((quality or perform$) and (measur$ or indicator$ or assess$)).mp.

AND

pain.mp.

NUMBER OF ITEMS RETRIEVED : 414

SEARCH STRATEGY #2 (DEPRESSION):

(neoplasm$ or cancer$ or tumour$ or tumor$ or carcinoma$ or adenocarcinoma$ or malignan$).mp.

AND

(guideline$ or audit$ or outcome$ or peer review$ or professional review$ or evaluat$ or benchmark$ or utilization review$ or consensus or perform$ or quality).mp.

AND

((quality or perform$) and (measur$ or indicator$ or assess$)).mp.

AND

(depression or depressive or sadness).mp.

NUMBER OF ITEMS RETRIEVED: 215

DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL - 1995-2005

OTHER LIMITERS:

ENGLISH

HUMAN

SEARCH STRATEGY #3 (DYSPNEA)

(dyspnea or shortness of breath or difficulty breathing or breathless$).mp.

AND

(guideline$ or audit$ or outcome$ or peer review$ or professional review$ or evaluat$ or benchmark$ or utilization review$ or consensus).mp.

AND

((quality or perform$) and (measur$ or indicator$ or assess$)).mp.

NUMBER OF ITEMS RETRIEVED : 278 (78 were duplicates)

DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL - 1995-2005

OTHER LIMITERS:

ENGLISH

HUMAN

SEARCH STRATEGY #4 (ADVANCE DIRECTIVES)

(advance directive$ or withdraw$ care or living will or resuscitat$).mp.

AND

(guideline$ or audit$ or outcome$ or peer review$ or professional review$ or evaluat$ or benchmark$ or utilization review$ or consensus).mp.

AND

((quality or perform$) and (measur$ or indicator$ or assess$)).mp.

NUMBER OF ITEMS RETRIEVED : 182

SEARCH METHODOLOGIES - END OF LIFE CANCER MEASUREMENT REVISIONS - DYSPNEA & ADVANCE DIRECTIVES “NOT” CANCER

DATABASE SEARCHED & TIME PERIOD COVERED:

PUBMED - 1995-2005

OTHER LIMITERS:

ENGLISH

HUMAN

SEARCH STRATEGY #1 (DYSPNEA)

guideline*[tiab] OR quality of health care OR guideline adherence OR medical audit OR nursing audit OR outcome and process assessment, health care OR commission on professional and hospital activities OR peer review, health care OR professional review organizations OR program evaluation OR benchmarking OR quality assurance, health care OR guidelines[mh] OR practice guidelines OR total quality management OR quality indicators, health care OR utilization review OR practice guideline[pt] OR consensus development conference[pt] OR (communication AND physician* AND (patient* OR consumer*))

AND

(quality OR perform*) AND (measur* OR indicator* OR assess*)

AND

dyspnea OR shortness of breath OR difficulty breathing OR breathless*

NOT

case report*

NUMBER OF ITEMS RETRIEVED : 887

DATABASE SEARCHED & TIME PERIOD COVERED:

PUBMED - 1995-2005

OTHER LIMITERS:

ENGLISH

HUMAN

SEARCH STRATEGY #2 (ADVANCE DIRECTIVES)

guideline*{tiab} OR quality of health care OR guideline adherence OR medical audit OR nursing audit OR outcome and process assessment, health care OR commission on professional and hospital activities OR peer review, health care OR professional review organizations OR program evaluation OR benchmarking OR quality assurance, health care OR guidelines[mh] OR practice guidelines OR total quality management OR quality indicators, health care OR utilization review OR practice guideline[pt] OR consensus development conference[pt] OR (communication AND physician* AND (patient* OR consumer*))

AND

(quality OR perform*) AND (measur* OR indicator* OR assess*)

AND

advance care OR advance directive* OR withdrawal of care OR living will OR “do not resuscitate”

NOT

case report*

NUMBER OF ITEMS RETRIEVED : 486

SEARCH METHODOLOGIES - END OF LIFE CANCER MEASUREMENT PAIN NOT PALLIATIVE/DEPRESSION - PUBMED

SEARCH STRATEGY #1 (PAIN NOT PALLIATIVE):

DATABASE SEARCHED & TIME PERIOD COVERED:

PUBMED 1995-2005

OTHER LIMITERS:

ENGLISH

HUMAN

NOT CASE REPORTS

SEARCH STRATEGY:

neoplasms[mh] OR neoplasm*[tiab] OR cancer* OR tumour* OR tumor* OR carcinoma* OR adenocarcinoma* OR malignan*

AND

pain[mh] OR pain[ti]

AND

quality of health care OR guideline adherence OR medical audit OR nursing audit OR outcome and process assessment, health care OR commission on professional and hospital activities OR peer review, health care OR professional review organizations OR program evaluation OR benchmarking OR quality assurance, health care OR guidelines[mh] OR practice guidelines OR total quality management OR quality indicators, health care OR utilization review OR practice guideline[pt] OR consensus development conference[pt] OR (communication AND physician* AND (patient* OR consumer*))

AND

(quality OR perform*) AND (measur* OR indicator* OR assess*)

NOT

case report*

NUMBER OF ITEMS RETRIEVED: 691

SEARCH STRATEGY #2 (DEPRESSION):

DATABASE SEARCHED & TIME PERIOD COVERED:

PUBMED 1995-2005

OTHER LIMITERS:

ENGLISH

HUMAN

NOT CASE REPORTS

SEARCH STRATEGY:

neoplasms[mh] OR neoplasm*[tiab] OR cancer* OR tumour* OR tumor* OR carcinoma* OR adenocarcinoma* OR malignan*

AND

depressive disorders OR depression OR sadness

AND

quality of health care OR guideline adherence OR medical audit OR nursing audit OR outcome and process assessment, health care OR commission on professional and hospital activities OR peer review, health care OR professional review organizations OR program evaluation OR benchmarking OR quality assurance, health care OR guidelines[mh] OR practice guidelines OR total quality management OR quality indicators, health care OR utilization review OR practice guideline[pt] OR consensus development conference[pt] OR (communication AND physician* AND (patient* OR consumer*))

AND

(quality OR perform*) AND (measur* OR indicator* OR assess*)

NOT

case report*

NUMBER OF ITEMS RETRIEVED: :468

SEARCH METHODOLOGY - END OF LIFE CANCER MEASUREMENT - DEPRESSION PSYCINFO

DATABASE SEARCHED & TIME PERIOD COVERED:

PSYCINFO - 1995-2005

OTHER LIMITERS:

ENGLISH

HUMAN

SEARCH STRATEGY

(kw: neoplasm* OR kw: cancer* OR kw: tumour* OR kw: tumor* OR kw: carcinoma* OR kw: adenocarcinoma* OR kw: malignan*)

AND

(kw: guideline* OR kw: audit OR kw: outcome* OR (kw: peer and kw: review) OR (kw:professional and kw: review) OR kw: evaluat* OR kw: benchmark* OR (kw: utilization and kw: review) OR kw: consensus)

AND

((kw: quality OR kw: perform*) AND (kw: measur* OR kw: indicator* OR kw: assess*))

AND

((kw: depressive and kw: disorders) OR kw: depression OR kw: sadness)

NUMBER OF ITEMS RETRIEVED: 86

SEARCH METHODOLOGIES - END OF LIFE CANCER MEASUREMENT PSYCINFO

DATABASE SEARCHED & TIME PERIOD COVERED:

PSYCINFO - 1995-2005

OTHER LIMITERS:

ENGLISH

SEARCH STRATEGY #1 (PAIN NOT PALLIATIVE):

(kw: neoplasm* OR kw: cancer* OR kw: tumour* OR kw: tumor* OR kw: carcinoma* OR kw: adenocarcinoma* OR kw: malignan*)

AND

(kw: guideline* OR kw: audit OR kw: outcome* OR (kw: peer and kw: review) OR (kw:professional and kw: review) OR kw: evaluat* OR kw: benchmark* OR (kw: utilization and kw: review) OR kw: consensus)

AND

((kw: quality OR kw: perform*) AND (kw: measur* OR kw: indicator* OR kw: assess*))

AND

Kw: pain

NUMBER OF ITEMS RETRIEVED: 92

SEARCH STRATEGY #2 (DEPRESSION):

DATABASE SEARCHED & TIME PERIOD COVERED:

PSYCINFO - 1995-2005

OTHER LIMITERS:

ENGLISH

(kw: neoplasm* OR kw: cancer* OR kw: tumour* OR kw: tumor* OR kw: carcinoma* OR kw: adenocarcinoma* OR kw: malignan*)

AND

(kw: guideline* OR kw: audit OR kw: outcome* OR (kw: peer and kw: review) OR (kw: professional and kw: review) OR kw: evaluat* OR kw: benchmark* OR (kw: utilization and kw: review) OR kw: consensus)

AND

((kw: quality OR kw: perform*) AND (kw: measur* OR kw: indicator* OR kw: assess*))

AND

((kw: depressive and kw: disorders) OR kw: depression OR kw: sadness)

NUMBER OF ITEMS RETRIEVED: 86

SEARCH STRATEGY #3 (DYSPNEA):

DATABASE SEARCHED & TIME PERIOD COVERED:

PSYCINFO- 1995-2005

OTHER LIMITERS:

ENGLISH

SEARCH STRATEGY:

(kw: dyspnea OR (kw: shortness and kw: breath) OR (kw: difficulty and kw: breathing) OR kw: breathless*)

AND

(kw: guideline* OR kw: audit OR kw: outcome* OR (kw: peer and kw: review) OR (kw:professional and kw: review) OR kw: evaluat* OR kw: benchmark* OR (kw: utilization and kw: review) OR kw: consensus)

AND

((kw: quality OR kw: perform*) AND (kw: measur* OR kw: indicator* OR kw: assess*))

NUMBER OF ITEMS RETRIEVED: 25

SEARCH STRATEGY #4 (ADVANCE DIRECTIVES):

DATABASE SEARCHED & TIME PERIOD COVERED:

PSYCINFO- 1995-2005

OTHER LIMITERS:

ENGLISH

SEARCH STRATEGY:

((kw: advance and kw: care) OR (kw: advance and kw: directive*) OR (kw: withdrawal and kw: care) OR (kw: living and kw: will) OR kw: do w1 resuscitate)

AND

(kw: guideline* OR kw: audit OR kw: outcome* OR (kw: peer and kw: review) OR (kw: professional and kw: review) OR kw: evaluat* OR kw: benchmark* OR (kw: utilization and kw: review) OR kw: consensus)

AND

((kw: quality OR kw: perform*) AND (kw: measur* OR kw: indicator* OR kw: assess*))

NUMBER OF ITEMS RETRIEVED: 66