# Appendix B. TEP Worksheet

Indicator Worksheet—Cancer Care Quality Measures: Symptoms and End of Life Care

Established Indicator Worksheet

TEP Member | Indicator statement | Numerator | Denominator | Source | Guideline at SCEPC?