# Appendix H. Excluded Studies

## Rejected: Duplicate Data

1 Appendix A: panel rating sheets by condition. Kerr, E. A.; Asch, S. M.; Hamilton, E. G., and McGlynn, E. A. Quality of care for cardiopulmonary conditions: a review of the literature and quality indicators. RAND; 2000; pp. 251–84. Rec #: 739
2 Appendix B: crosswalk table to original and final indicators. Kerr, E. A.; Asch, S. M.; Hamilton, E. G., and McGlynn, E. A. Quality of care for cardiopulmonary conditions: a review of the literature and quality indicators. RAND; 2000; pp. 285–327. Rec #: 740

## Rejected: Non-Western Location

1 Auchus, A. P. and Chen, C. P. Asia-Pacific Consensus Statement on dementia. Alzheimer Dis Assoc Disord.2001 Apr–2001 Jun 30; 15(2):63–5.Rec #: 635
2 Howland SC. Managing the Alzheimer's patient. Emerg Med Serv. Sep. 2000;29(9):89-92. Rec #: 32435. [pmid: 11143041].
3 Ministry of Health, Singapore. Cancer pain. 2003 Mar(Clnical Practice Guildelines). Rec #: 207
4 National Comprehensive Cancer Network (NCCN). Colon cancer. Clinical Practice Guidelines in Oncology. 2005; (2). Rec #: 128
5 Palliative Care and Critical Care Committees. Removal of mechanical ventilation in the dying patient. Guidelines for Physician Staff Froedtert Hospital, Milwaukee, Wisconsin :1–4. Rec #: 136
6 Tomita T and Kitamura T. Clinical and research measures of grief: a reconsideration. Compr Psychiatry. 2002Mar–2002 Apr 30; 43(2):95–102.Rec #: 15879

## Rejected: No Domain of Interest

1 American Academy of Hospice and Palliative Medicine (AAHPM). Position statements: comprehensive end-of-life care and physician-assisted suicide [Web Page]. 1997 Jun 25; Accessed 2005 Jan 24. Rec #: 483
2 American Academy of Hospice and Palliative Medicine (AAHPM). Position statements: statement on the ethics of palliative care research [Web Page]. 2002 Jan 30; Accessed 2005 Jan 24. Rec #: 482
3 American Academy of Hospice and Palliative Medicine (AAHPM). Position statements: statement on the use of nutrition and hydration [Web Page]. 2001 Nov 16; Accessed 2005 Jan 24. Rec #: 481
4 American Academy of Hospice and Palliative Medicine (AAHPM). Positions statements: statement on sedation at the end-of-life [Web Page]. 2002 Sep 13; Accessed 2005 Jan 24. Rec #: 480
5 American Board of Family Practice. Carcinoma of the breast. Reference Guide. 2001. Rec #: 465
6 Bast R. C Jr, Ravdin P, Hayes D. F, Bates S, Fritsche H Jr, Jessup J. M, Kemeny N, Locker G. Y, Mennel R. G, Somerfield M. R. 2000 update of recommendations for the use of tumor markers in breast and colorectal cancer: clinical practice guidelines of the American Society of Clinical Oncology. J Clin Oncol. Mar 15. 2001;19(6):1865-78. Rec #: 174. [pmid: 11251019].
7 Benson AB 3rd, Schrag D, Somerfield M. R, Cohen A. M, Figueredo A. T, Flynn P. J, Krzyzanowska M. K, Maroun J, McAllister P, Van Cutsem E, Brouwers M, Charette M, Haller D. G. American Society of Clinical Oncology recommendations on adjuvant chemotherapy for stage II colon cancer. J Clin Oncol. Aug 15. 2004;22(16):3408-19. Rec #: 170. [pmid: 15199089].
8 Bramwell, V. H. C.; Anderson, D.; Charette, M. L., and Sarcoma Disease Site Group. Doxorubicin-based chemotherapy for the palliative treatment of adult patients with locally advanced or metastatic soft tissue sarcoma. Practice Guideline Report #11–1. 1999(Program in Evidence-Based Care). Rec #: 152
9 Browning, D. M. and Solomon, M. Z. The initiative for pediatric palliative care: an interdisciplinary educational approach for health care professionals. Rec #: 755
10 Burt R. A. The limitations of protocols for end-of-life care. Respir Care. Dec. 2000;45(12):1523-9. discussion 1529–33. Rec #: 223. [pmid: 11107218].
11 Byock I, Norris K, Curtis J. R, Patrick D. L. Improving end-of-life experience and care in the community: a conceptual framework. J Pain Symptom Manage. Sep. 2001;22(3):759-72. Rec #: 642. [pmid: 11532589].
12 Cherny, N. I.; Catane, R.; Kosmidis, P. A., and Members of the ESMO Palliative Care Working Group. ESMO policy on supportive and palliative care. European Society for Medical Oncology (ESMO). 2003:1–5. Rec #: 139
13 Chow T. W, MacLean C. H. Quality indicators for dementia in vulnerable community-dwelling and hospitalized elders. Ann Intern Med. Oct 16. 2001;135(8 Pt 2):668-76. Rec #: 645. [pmid: 11601949].
14 Cluzeau F. A, Littlejohns P, Grimshaw J. M, Feder G, Moran S. E. Development and application of a generic methodology to assess the quality of clinical guidelines. Int J Qual Health Care. Feb. 1999;11(1):21-8. Rec #: 432. [pmid: 10411286].
15 Cummings J. L, Frank J. C, Cherry D, Kohatsu N. D, Kemp B, Hewett L, Mittman B. Guidelines for managing Alzheimer's disease: part I. Assessment. Am Fam Physician. Jun 1. 2002;65(11):2263-72. Rec #: 633. [pmid: 12074525].
16 Daly B. J. Organizational change and delivery of multidisciplinary palliative care. Respir Care. Dec. 2000;45(12):1501-10. discussion 1510–2. Rec #: 221. [pmid: 11107216].
17 Davidson, K. Family bereavement support before and after the death of a nursing home resident. University of Iowa Gerontological Nursing Interventions Research Center (RDC); 2002. Rec #: 713
18 Dudley R. A, Bowers L. V, Luft H. S. Reconciling quality measurement with financial risk adjustment in health plans. Jt Comm J Qual Improv. Mar. 2000;26(3):137-46. Rec #: 427. [pmid: 10709147].
19 European Society for Medical Oncology (ESMO). Minimum clinical recommendations for diagnosis, adjuvant treatment and follow-up of primary breast cancer. ESMO Guidelines Task Force; 2003. Rec #: 117
20 European Society for Medical Oncology (ESMO). Minimum clinical recommendations for diagnosis, treatment and follow-up of advanced colorectal cancer. ESMO Guidelines Task Force; 2002. Rec #: 115
21 European Society for Medical Oncology (ESMO). Minimum clinical recommendations for diagnosis, treatment and follow-up of Ewing's sarcoma of bone. ESMO Guidelines Task Force; 2002. Rec #: 118
22 European Society for Medical Oncology (ESMO). Minimum clinical recommendations for diagnosis, treatment and follow-up of locally recurrent or metastatic breast cancer (MBC): ESMO Guidelines Task Force; 2003. Rec #: 114
23 European Society for Medical Oncology (ESMO). Minimum clinical recommendations for diagnosis, treatment and follow-up of non-small-cell lung cancer (NSCLC). ESMO Guidelines Task Force; 2003. Rec #: 116
24 European Society for Medical Oncology (ESMO). Minimum clinical recommendations for diagnosis, treatment and follow-up of osteosarcoma : ESMO Guidelines Task Force; 2002. Rec #: 111
25 European Society for Medical Oncology (ESMO). Minimum clinical recommendations for diagnosis, treatment and follow-up of small-cell lung cancer (SCLC): ESMO Guidelines Task Force; 2003. Rec #: 112
26 European Society for Medical Oncology (ESMO). Minimum clinical recommendations for the diagnosis, treatment and follow-up of prostate cancer: ESMO Guidelines Task Force; 2003. Rec #: 113
27 Fahey T, Montgomery A. A, Barnes J, Protheroe J. Quality of care for elderly residents in nursing homes and elderly people living at home: controlled observational study. BMJ. Mar 15. 2003;326(7389):580. Rec #: 631. [pmid: 12637404].
28 Fowler F. J Jr, Coppola K. M, Teno J. M. (Center for Survey Research, University of Massachusetts at Boston, 100 Morrissey Boulevard, Boston, MA 02125–3393.). Methodological challenges for measuring quality of care at the end of life. Journal of Pain and Symptom Management. Feb. 1999;17(2):114-9. Rec #: 343. [pmid: 10069151].
29 Gagliardi, A. R.; Fung, M. F. K.; Langer, B.; Stern, H., and Brown, A. D. Development of ovarian cancer surgery quality indicators using a modified delphi approach. Ottawa, Ontario, Canada. Rec #: 726
30 Giordano M. The respiratory therapist and palliative care. Respir Care. Dec. 2000;45(12):1468-74. discussion 1475–7. Rec #: 218. [pmid: 11107213].
31 Gralla R. J, Osoba D, Kris M. G, Kirkbride P, Hesketh P. J, Chinnery L. W, Clark-Snow R, Gill D. P, Groshen S, Grunberg S, Koeller J. M, Morrow G. R, Perez E. A, Silber J. H, Pfister D. G. Recommendations for the use of antiemetics: evidence-based, clinical practice guidelines. American Society of Clinical Oncology. J Clin Oncol. Sep. 1999;17(9):2971-94. Rec #: 162. [pmid: 10561376].
32 Hillner B. E, Ingle J. N, Chlebowski R. T, Gralow J, Yee G. C, Janjan N. A, Cauley J. A, Blumenstein B. A, Albain K. S, Lipton A, Brown S. American Society of Clinical Oncology 2003 update on the role of bisphosphonates and bone health issues in women with breast cancer. J Clin Oncol. Nov 1. 2003;21(21):4042-57. Rec #: 462. [pmid: 12963702].
33 Holtzman J, Degelau J, Meyers R, Holtzman J, Christianson C, Lurie N. (Institute of Health Services Research, School of Public Health, Box 197 Mayo, 420 Delaware Street S.E., Minneapolis, MN 55455.). Development and testing of a process measure of nursing home quality of care. Journal of the American Geriatrics Society. Oct. 1997;45(10):1203-7. Rec #: 397. [pmid: 9329481].
34 Hunt et al. ACC/AHA guidelines for the evaluation and management of chronic heart failure in the adult: a report of the American College of Cardiology/American Heart Association task force on practice guidlines (Committee to reise the 1995 guidelines for the evaluation and management of heart failure). ACC/AHA Practice Guidelines. 2001:1–55. Rec #: 120
35 Jacobsen, P. B.; Donovan, K. A.; Trask, P. C.; Fleishman, S. B.; Zabora, J.; Baker, F., and Holland, J. C. Screening for psychological distress in ambulatory cancer patients: a multi-center evaluation of the distress thermomenter. Rec #: 487
36 Jennings B. M, Loan L. A, DePaul D, Brosch L. R, Hildreth P. Lessons learned while collecting ANA indicator data. J Nurs Adm. Mar. 2001;31(3):121-9. Rec #: 554. [pmid: 11263060].
37 Jett J. R, Scott W. J, Rivera M. P, Sause W. T. Guidelines on treatment of stage IIIB non-small cell lung cancer. Chest. Jan. 2003;123(1 Suppl):221S-225S. Rec #: 164. [pmid: 12527581].
38 Kahn, K. L.; Malin, J. L.; Adams, J., and Ganz, P. A. Developing a reliable, valid, and feasible plan for quality-of-care measurement for cancer: how should we measure? Med Care. 2002 Jun; 40(6 Suppl):III73–85. Rec #: 643
39 Levetown, M. ; Dokken, D.; Heller, K. S., and et al. for IPPC. A Pediatric Palliative Care Institutional Sel-Assessment Tool (ISAT). Education Development Center, Inc. 2002. Rec #: 749
40 Loblaw D. A, Mendelson D. S, Talcott J. A, Virgo K. S, Somerfield M. R, Ben-Josef E, Middleton R, Porterfield H, Sharp S. A, Smith T. J, Taplin M. E, Vogelzang N. J, Wade J. L Jr, Bennett C. L, Scher H. I. American Society of Clinical Oncology recommendations for the initial hormonal management of androgen-sensitive metastatic, recurrent, or progressive prostate cancer. J Clin Oncol. Jul 15. 2004;22(14):2927-41. Rec #: 475. [pmid: 15184404].
41 Lynn J, Nolan K, Kabcenell A, Weissman D, Milne C, Berwick D. M. Reforming care for persons near the end of life: the promise of quality improvement. Ann Intern Med. Jul 16. 2002;137(2):117-22. Rec #: 637. [pmid: 12118967].
42 MacIntyre N. R, Cook D. J, Ely E. W Jr, Epstein S. K, Fink J. B, Heffner J. E, Hess D, Hubmayer R. D, Scheinhorn D. J. Evidence-based guidelines for weaning and discontinuing ventilatory support: a collective task force facilitated by the American College of Chest Physicians; the American Association for Respiratory Care; and the American College of Critical Care Medicine. Chest. Dec. 2001;120(6 Suppl):375S-95S. Rec #: 470. [pmid: 11742959].
43 Malin J. L, Asch S. M, Kerr E. A, McGlynn E. A. Evaluating the quality of cancer care: development of cancer quality indicators for a global quality assessment tool. Cancer. Feb 1. 2000;88(3):701-7. Rec #: 641. [pmid: 10649266].
44 Multinational Association of Supportive Care in Cancer (MASCC). Consensus Conference on Antiemetic Therapy. Perugia International Cancer Conference VII; Perugia. 2004 Jun. Rec #: 169
45 National Comprehensive Cancer Network (NCCN). Acute Myeloid Leukemia. National Comprehensive Cancer Network; 2005 Mar 4(Practice Guidelines in Oncology; version 2.2005). Rec #: 658
46 National Comprehensive Cancer Network (NCCN). Antiemesis. National Comprehensive Cancer Network (NCCN); 2005 Jan 6(Practice Guidelines in Oncology; version 1.2005). Rec #: 699
47 National Comprehensive Cancer Network (NCCN). Basal cell and squamous cell skin cancers. National Comprehensive Cancer Network (NCCN); 2004 Jan 5(Practice Guidleines in Oncology; version 1.2004). Rec #: 685
48 National Comprehensive Cancer Network (NCCN). Bladder cancer. National Comprehensive Cancer Network; 2005 Mar 4(Practice Guidelines in Oncology; version 1.2005). Rec #: 659
49 National Comprehensive Cancer Network (NCCN). Bone cancer. Clinical Practice Guidelines in Oncology. 2005; (1). Rec #: 122
50 National Comprehensive Cancer Network (NCCN). Breast cancer. Clinical Practice Guidelines in Oncology. 2005; (1). Rec #: 126
51 National Comprehensive Cancer Network (NCCN). Breast cancer risk reduction. National Comprehensive Cancer Network (NCCN); 2004 May 3(Practice Guidleines in Oncology; version 1.2004). Rec #: 692
52 National Comprehensive Cancer Network (NCCN). Breat cancer screening and diagnosis. National Comprehensive Cancer Network (NCCN); 2004 Jul 13(Practice Guidleines in Oncology; version 1.2004). Rec #: 693
53 National Comprehensive Cancer Network (NCCN). Cancer and treatment-related anemia. National Comprehensive Cancer Network (NCCN); 2004 Dec 21(Practice Guidleines in Oncology; version 2.2004). Rec #: 698
54 National Comprehensive Cancer Network (NCCN). Cancer-related fatigue. National Comprehensive Cancer Network (NCCN); 2004 Apr 19(Practice Guidleines in Oncology; version 1.2004). Rec #: 700
55 National Comprehensive Cancer Network (NCCN). Cervical cancer. National Comprehensive Cancer Network; 2004 Oct 28(Practice Guidelines in Oncology; version 1.2004). Rec #: 663
56 National Comprehensive Cancer Network (NCCN). Cervical screening. National Comprehensive Cancer Network (NCCN); 2004 Oct 1(Practice Guidelines in Oncology; version 1.2005). Rec #: 694
57 National Comprehensive Cancer Network (NCCN). Colorectal screening. National Comprehensive Cancer Network (NCCN); 2004 Aug 27(Practice Guidleines in Oncology; version 1.2004). Rec #: 695
58 National Comprehensive Cancer Network (NCCN). Dermatofibrosarcoma protuberans. National Comprehensive Cancer Network (NCCN); 2004 Jan 5(Practice Guidleines in Oncology; version 1.2004). Rec #: 686
59 National Comprehensive Cancer Network (NCCN). Distress management. 2005(Clinical Practice Guidelines in Oncology). Rec #: 707
60 National Comprehensive Cancer Network (NCCN). Distress management: clinical practice guidelines. JNCCN. 2003; 1:344–74.Rec #: 486
61 National comprehensive Cancer Network (NCCN). Esophageal cancer. National Comprehensive Cancer Network; 2005 Jan 1(Practice Guidleines in Oncology; version 1.2005). Rec #: 665
62 National Comprehensive Cancer Network (NCCN). Fever and Neutropenia. National Comprehensive Cancer Network (NCCN); 2004 Nov 1(Practice Guidelines in Oncology; version 1.2004). Rec #: 703
63 National Comprehensive Cancer Network (NCCN). Genetic/familial high-risk assessment. National Comprehensive Cancer Network (NCCN); 2005 Feb 9(Practice Guidleines in Oncology; version 1.2005). Rec #: 696
64 National Comprehensive Cancer Network (NCCN). Head and neck cancers. National Comprehensive Cancer Network; 2005 Feb 7(Practice Guidelines in Oncology; version 1.2005). Rec #: 668
65 National Comprehensive Cancer Network (NCCN). Hepatobiliary cancers. National Comprehensive Cancer Network; 2005 Feb 1(Practice Guidelines in Oncology; version 1.2005). Rec #: 669
66 National Comprehensive Cancer Network (NCCN). Hodgkin's disease. National Comprehensive Cancer Network; 2004 Aug 10(Practice Guidelines in Oncology; version 1.2004). Rec #: 670
67 National Comprehensive Cancer Network (NCCN). Melanoma. National Comprehensive Cancer Network; 2004 Nov 1(Practice Guidelines in Oncology; version 1.2004). Rec #: 672
68 National Comprehensive Cancer Network (NCCN). Merkel cell carcinoma. National Comprehensive Cancer Network (NCCN); 2004 Jun(Practice Guidleines in OncologyPractice Guidleines in Oncology; version 1.2004). Rec #: 687
69 National Comprehensive Cancer Network (NCCN). Myelodysplastic syndoromes. National Comprehensive Cancer Network; 2004 Sep 9(Practice Guidelines in Oncology; version 1.2005). Rec #: 673
70 National Comprehensive Cancer Network (NCCN). Neuroendocrine tumors. National Comprehensive Cancer Network (NCCN); 2004 Oct 6(Practice Guidelines in Oncology; version 1.2004). Rec #: 677
71 National Comprehensive Cancer Network (NCCN). Non-Hodgkin's Lymphoma. National Comprehensive Cancer Network (NCCN); 2005 Feb 8(Practice Guidelines in Oncology; version 1.2005). Rec #: 678
72 National Comprehensive Cancer Network (NCCN). Non-small cell lung cancer. Clinical Practice Guidelines in Oncology. 2005; (2). Rec #: 124
73 National Comprehensive Cancer Network (NCCN). Occult Primary. National Comprehensive Cancer Network (NCCN); 2004 Nov 8(Practice Guidleines in Oncology; version 1.2005). Rec #: 680
74 National Comprehensive Cancer Network (NCCN). Ovarian cancer. National Comprehensive Cancer Network (NCCN); 2004 Nov 1(Practice Guidleines in Oncology; version 1.2005). Rec #: 681
75 National Comprehensive Cancer Network (NCCN). Pancreatic Adenocarcinoma. National Comprehensive Cancer Network (NCCN); 2004 Nov 1(Practice Guidleines in Oncology; version 1.2004 ). Rec #: 682
76 National Comprehensive Cancer Network (NCCN). Prostate cancer. Clinical Practice Guidelines in Oncology. 2004; (1). Rec #: 125
77 National Comprehensive Cancer Network (NCCN). Prostate cancer early detection. National Comprehensive Cancer Network (NCCN); 2004 Mar 3(Practice Guidleines in Oncology; version 1.2004). Rec #: 697
78 National Comprehensive Cancer Network (NCCN). Rectal cancer. Clinical Practice Guidelines in Oncology. 2005; (1). Rec #: 127
79 National Comprehensive Cancer Network (NCCN). Small cell lung cancer. Clinical Practice Guidelines in Oncology. 2005; (1). Rec #: 123
80 National Comprehensive Cancer Network (NCCN). Soft tissue sarcoma. National Comprehensive Cancer Network (NCCN); 2005 Feb 16(Practice Guidleines in Oncology; version1.2005). Rec #: 684
81 National Comprehensive Cancer Network (NCCN). Testicular Cancer. National Comprehensive Cancer Network (NCCN); 2004 Oct 18(Practice Guidleines in Oncology; version 1.2005). Rec #: 689
82 National Comprehensive Cancer Network (NCCN). Thyroid carcinoma. National Comprehensive Cancer Network (NCCN); 2005 Jan 31(Practice Guidelines in Oncology; version 1.2005). Rec #: 690
83 National Comprehensive Cancer Network (NCCN). Uterine cancer. National Comprehensive Cancer Network (NCCN); 2004 Oct 20(Practice Guidleines in Oncology; version 1.2004). Rec #: 691
84 National Hospice and Palliative Care Organization (NHPCO). Patient core measure sheet. http://www.nhpco.org/files/public/patientcoremeasuresheet.pdf. Rec #: 748
85 National Institute for Clinical Excellence. Improving supportive and palliative care for adults with cancer. National Institute for Clinical Excellence; 2004 Mar(Guidance on Cancer Services). Rec #: 466
86 Nelson J. F, Meier D. E. Palliative care in the intensive care unit: part I. J Intensive Care Med. 1999;14:130-9. Rec #: 484.
87 Oncology Nursing Society and Geriatric Oncology Consortium. Oncology nursing society and geriatriconcology consortium joint position on cancer care in the older adult. Oncology Nursing Forum.2004; 31(3):1–2.Rec #: 119
88 Oncology Nusing Society. Oncology nursing society and association of oncology social work joint position on end-of-life care; 2003(Oncology Nursing Society Position). Rec #: 141
89 Ozer H, Armitage J. O, Bennett C. L, Crawford J, Demetri G. D, Pizzo P. A, Schiffer C. A, Smith T. J, Somlo G, Wade J. L 3rd, Winn R. J, Wozniak A. J, Somerfield M. R. 2000 update of recommendations for the use of hematopoietic colony-stimulating factors: evidence-based, clinical practice guidelines. American Society of Clinical Oncology Growth Factors Expert Panel. J Clin Oncol. Oct 15. 2000;18(20):3558-85. Rec #: 159. [pmid: 11032599].
90 Palliative Care and Ethics Committees and Department/Divisions of Neurology, Geriatrics Radiology Gastroenterology. Non-oral hydration and feeding in advanced dementia or at the end of life. Guidlines for Physician Staff Froedtert Hospital, Milwaukee, Wisconsin:1–5. Rec #: 132
91 Palliative Care Working Group (Canadian Strategy for Cancer Control). Canadian strategy for cancer control: palliative care working group final report. 2002 Jan. Rec #: 140
92 Recht A, Edge S. B, Solin L. J, Robinson D. S, Estabrook A, Fine R. E, Fleming G. F, Formenti S, Hudis C, Kirshner J. J, Krause D. A., Kuske R. R, Langer A. S, Sledge G. W Jr, Whelan T. J, Pfister D. G. Postmastectomy radiotherapy: clinical practice guidelines of the American Society of Clinical Oncology. J Clin Oncol. Mar 1. 2001;19(5):1539-69. Rec #: 463. [pmid: 11230499].
93 Reifel, J. L. Colorectal cancer treatment. Asch, S. M.; Kerr, E. A.; Hamilton, E. G.; Reifel, J. L., and McGlynn, E. A. Quality of care for oncologic condition and HIV: a review of the literature and quality indicators. RAND; 2000; pp. 77–111. Rec #: 705
94 Reifel, J. L. Colorectal cancer treatment. Prostate cancer treatment. Asch, S. M.; Kerr, E. A.; Hamilton, E. G.; Reifel, J. L., and McGlynn, E. A. Quality of care for oncologic condition and HIV: a review of the literature and quality indicators. RAND; 2000; pp. 189–215. Rec #: 706
95 Rizzo J. D, Lichtin A. E, Woolf S. H, Seidenfeld J, Bennett C. L, Cella D, Djulbegovic B, Goode M. J, Jakubowski A. A, Lee S. J, Miller C. B, Rarick M. U, Regan D. H, Gordon M. S. Use of epoetin in patients with cancer: evidence-based clinical practice guidelines of the American Society of Clinical Oncology and the American Society of Hematology. J Clin Oncol. Oct 1. 2002;20(19):4083-107. Rec #: 161. [pmid: 12351606].
96 Robinson L. A, Wagner H Jr, Ruckdeschel J. C. Treatment of stage IIIA non-small cell lung cancer. Chest. Jan. 2003;123(1 Suppl):202S-220S. Rec #: 165. [pmid: 12527580].
97 Rubenfeld G. D. Withdrawing life-sustaining treatment in the intensive care unit. Respir Care. Nov. 2000;45(11):1399-407. discussion 1408–10. Rec #: 216. [pmid: 11063527].
98 Rubenstein E. B, Peterson D. E, Schubert M, Keefe D, McGuire D, Epstein J, Elting L. S, Fox P. C, Cooksley C, Sonis S. T. Clinical practice guidelines for the prevention and treatment of cancer therapy--induced oral and gastronintestinal mucositis. Cancer. 2004;100(9 Suppl):2026-46. Rec #: 168. [pmid: 15108223].
99 Schuchter L. M, Hensley M. L, Meropol N. J, Winer E. P. 2002 update of recommendations for the use of chemotherapy and radiotherapy protectants: clinical practice guidelines of the American Society of Clinical Oncology. J Clin Oncol. Jun 15. 2002;20(12):2895-903. Rec #: 160. [pmid: 12065567].
100 Scottish Intercollegiate Guidelines Network (SIGN). Breast cancer in women. National Clincal Guidelines. 1998 Oct; 29. Rec #: 464
101 Sessa C, Pampallona S, Carobbio M, Neuenschwander H, Cavalli F. Palliative care of cancer patients: audit of current hospital procedures. Support Care Cancer. May. 1998;6(3):266-72. Rec #: 445. [pmid: 9629881].
102 Shaw, P. and Agarwal, R. Pleurodesis for malignant pleural effusions. Cochrane Database Syst Rev. 2004; (1):CD002916. Rec #: 403
103 Simon G. R, Wagner H. Small cell lung cancer. Chest. Jan. 2003;123(1 Suppl):259S-271S. Rec #: 166. [pmid: 12527584].
104 Solomon D. H, Wenger N. S, Saliba D, Young R. T, Adelman A. M, Besdine R. K, Blazer D. G, Cassell C. K, Cummings J. L, Katz P. R, Kitzman D. W, Lavizzo-Mourey R. J, Mondoux L. C, Popovich R, Pories W. J, Wenger N. Popovich, R.; Pories, W. J., and Wenger, N. Appropriateness of quality indicators for older patients with advanced dementia and poor prognosis. J Am Geriatr Soc. Jul. 2003;51(7):902-7. Rec #: 632. [pmid: 12834508].
105 Stuart B, D'Onofrio CN, Boatman S, Feigelman G. CHOICES: promoting early access to end-of-life care through home-based transition management. J Palliat Med. Aug. 2003;6(4):671-83. Rec #: 7422. [pmid: 14516514].
106 Takada K, Aksentijevich I, Mahadevan V, Dean J. A, Kelley R. I, Kastner D. L. (National Institute of Arthritis and Musculoskeletal and Skin Diseases, NIH, Bethesda, MD.). Favorable preliminary experience with etanercept in two patients with the hyperimmunoglobulinemia D and periodic fever syndrome. Arthritis & Rheumatism. Sep. 2003;48(9):2645-51. Rec #: 324. [pmid: 13130485].
107 Taylor, A. and Box, M. Multicultural palliative care guidelines. Australia: Palliative Care Australia; 1999(Palliative Care Australia). Rec #: 476
108 The National Quality Forum (NQF). A comprehensive framework for hospital care performance evaluation: a consensus report. National Quality Forum; 2003. Rec #: 489
109 Thompson B. T, Cox P. N, Antonelli M, Carlet J. M, Cassell J, Hill N. S, Hinds C. J, Pimentel J. M, Reinhart K, Thijs L. G. Challenges in end-of-life care in the ICU: statement of the 5th International Consensus Conference in Critical Care: Brussels, Belgium, April 2003: executive summary. Crit Care Med. Aug. 2004;32(8):1781-4. Rec #: 638. [pmid: 15286559].
110 Tolson D, Smith M, Knight P. An investigation of the components of best nursing practice in the care of acutely ill hospitalized older patients with coincidental dementia: a multi-method design. J Adv Nurs. Nov. 1999;30(5):1127-36. Rec #: 578. [pmid: 10564412].
111 Viles L. Death and the practitioner. Respir Care. Dec. 2000;45(12):1513-9. discussion 1520–2. Rec #: 222. [pmid: 11107217].
112 Wallace SK, Ewer MS, Price KJ, Feeley TW. Outcome and cost implications of cardiopulmonary resuscitation in the medical intensive care unit of a comprehensive cancer center. Support Care Cancer. Jul. 2002;10(5):425-9. Rec #: 622. [pmid: 12136227].
113 Wu A. W, Gifford A, Asch S, Cohn S. E, Bozzette S. A, Yurk R. Quality-of-care indicators for HIV/AIDS. Dis Manage Health Outcomes. Jun. 2000;7(6):315-30. Rec #: 731.

## Rejected: Disease Not Cancer

1 Beal A. C, Co J. P, Dougherty D, Jorsling T, Kam J, Perrin J, Palmer R. H. Quality measures for children's health care. Pediatrics. Jan. 2004;113(1 Pt 2):199-209. Rec #: 757. [pmid: 14702502].
2 Buchanan RJ, Choi M, Wang S, Huang C. Analyses of nursing home residents in hospice care using the minimum data set. Palliat Med. Nov. 2002;16(6):465-80. Rec #: 354. [pmid: 12465693].
3 Chodosh J, Ferrell B. A, Shekelle P. G, Wenger N. S. Quality indicators for pain management in vulnerable elders. Ann Intern Med. Oct 16. 2001;135(8 Pt 2):731-5. Rec #: 647. [pmid: 11601956].
4 Chodosh J, Solomon D. H, Roth C. P, Chang J. T, MacLean C. H, Ferrell B. A, Shekelle P. G, Wenger N. S. The quality of medical care provided to vulnerable older patients with chronic pain. J Am Geriatr Soc. May. 2004;52(5):756-61. Rec #: 627. [pmid: 15086657].
5 Chou R, Clark E, Helfand M. Comparative efficacy and safety of long-acting oral opioids for chronic non-cancer pain: a systematic review. J Pain Symptom Manage. Nov. 2003;26(5):1026-48. Rec #: 238. [pmid: 14585554].
6 Foster R. L, Varni J. W. (School of Nursing, C288–10, University of Colorado, Health Sciences Center, 4200 East Ninth Avenue, Denver, CO 80262.). Measuring the quality of children's postoperative pain management: initial validation of the Child/Parent Total Quality Pain Management (TQPM) instruments. Journal of Pain and Symptom Management. Mar. 2002;23(3):201-10. Rec #: 310. [pmid: 11888718].
7 Kalso E, Allan L, Dellemijn P. L, Faura C. C, Ilias W. K, Jensen T. S, Perrot S, Plaghki L. H, Zenz M. Recommendations for using opioids in chronic non-cancer pain. Eur J Pain. 2003;7(5):381-6. Rec #: 243. [pmid: 12935789].
8 Standards and Quality Committee and Council of Palliative Care Australia. Resource manual for palliative care performance indicators in Australia. Australia; 1998 Jun(Palliaitve Care Australia). Rec #: 478

## Rejected: No Indicators

1 Cancer care during the last phase of life. J Clin Oncol. 1998 May; 16(5):1986–96.Rec #: 106
2 Definitions related to the use of opioids for the treatment of pain. WMJ. 2001; 100(5):28–9.Rec #: 202
3 Organizational assessment: personnel competency/performance. Supportive Care of the Dying: A Coalition for Compassionate Care:1–4. Rec #: 468
4 Organizational Assessment: system grid and assumptions. Supportive Care of the Dying: A Coalition for Compassionate Care. 2001:1–9. Rec #: 467
5 Quality improvement guidelines for the treatment of acute pain and cancer pain. American Pain SocietyQuality of Care Committee. JAMA. 1995 Dec 20; 274(23):1874–80.Rec #: 296
6 Questions and answers on breast cancer: guideline 10- the management of persistant pain. 2001 Jul 3. Rec #: 727
7 Abrahm J. L. Management of pain and spinal cord compression in patients with advanced cancer. ACP-ASIM End-of-life Care Consensus Panel. American College of Physicians-American Society of Internal Medicine. Ann Intern Med. Jul 6. 1999;131(1):37-46. Rec #: 278. [pmid: 10391814].
8 Addington-Hall J, Altmann D, McCarthy M. Which terminally ill cancer patients receive hospice in-patient care?. Social Science & Medicine. 1998;46(8):1011-6. Rec #: 623. [pmid: 9579752].
9 Addington-Hall J, McCarthy M. Dying from cancer: results of a national population-based investigation. Palliat Med. Oct. 1995;9(4):295-305. Rec #: 301. [pmid: 8548091].
10 Ahmedzai S. Recent clinical trials of pain control: impact on quality of life. Eur J Cancer. 1995;31A(Suppl 6):S2-7. Rec #: 306. [pmid: 8534526].
11 Ahronheim J. C, Morrison R. S, Baskin S. A, Morris J, Meier D. E. Treatment of the dying in the acute care hospital. Advanced dementia and metastatic cancer. Arch Intern Med. Oct 14. 1996;156(18):2094-100. Rec #: 606. [pmid: 8862102].
12 Allcock N, McGarry J, Elkan R. Management of pain in older people within the nursing home: a preliminary study. Health Soc Care Community. Nov. 2002;10(6):464-71. Rec #: 251. [pmid: 12485133].
13 Allen R. S, DeLaine S. R, Chaplin W. F, Marson D. C, Bourgeois M. S, Dijkstra K, Burgio L. D. Advance care planning in nursing homes: correlates of capacity and possession of advance directives. Gerontologist. Jun. 2003;43(3):309-17. Rec #: 524. [pmid: 12810894].
14 Alpert H. R, Hoijtink H, Fischer G. S, Emanuel L. Psychometric analysis of an advance directive. Med Care. Oct. 1996;34(10):1057-65. Rec #: 607. [pmid: 8843930].
15 American Academy of Pain Medicine (AAPM). Acute pain and cancer pain. 1998. Rec #: 204
16 American Academy of Pain Medicine (AAPM). Basic principles of ethics for the practice of pain medicine. 1999. Rec #: 203
17 American Acaemy of Hospice and Pallliative Medicine (AAHPM). Position statements: definitions of palliative care and palliative medicine [Web Page]. Accessed 2005 Jan 24. Rec #: 479
18 American Geriatrics Society Clinical Practice, Committee. Management of cancer pain in older patients.Journal of the American Geriatrics Society. 1997; 45(10):1273–1276 URL http //www.blackwell-science.com/~cgilib/bsinc.bin?Journal=geriatricsRec #: 375
19 American Pain Society (APS). Guideline for the management of cancer pain in adults and children. 2005. Rec #: 651
20 American Pain Society (APS). Principles of analgesic use in the treatment of acute pain and cancer pain. 5th Ed. ed.; 2003. Rec #: 650
21 Arcangeli G, Giovinazzo G, Saracino B, D'Angelo G, Giannarelli L, Arcangeli G, Micheli A. Radiation therapy in the management of symptomatic bone metastases: the effect of total dose and histology on pain relief and response duration. Int J Radiat Oncol Biol Phys. Dec 1. 1998;42(5):1119-26. Rec #: 285. [pmid: 9869238].
22 Bach W. M, Schrag D, Begg C. B. Resurrecting treatment histories of dead patients: a study design that should be laid to rest. JAMA. Dec 8. 2004;292(22):2765-70. Rec #: 758. [pmid: 15585737].
23 Baer W. M, Hanson L. C. (Division of General Medicine, School of Medicine, University of North Carolina, Chapel Hill, North Carolina.). Families' perception of the added value of hospice in the nursing home. Journal of the American Geriatrics Society. Aug. 2000;48(8):879-82. Rec #: 338. [pmid: 10968290].
24 Bailly D. J, DePoy E. Older people's responses to education about advance directives. Health Soc Work. Aug. 1995;20(3):223-8. Rec #: 615. [pmid: 7557727].
25 Barnato A. E, Angus D. C. Value and role of intensive care unit outcome prediction models in end-of-life decision making. Crit Care Clin. Jul. 2004;20(3):345-62. vii-viii. Rec #: 512. [pmid: 15183207].
26 Barton M. B, Dawson R, Jacob S, Currow D, Stevens G, Morgan G. Palliative radiotherapy of bone metastases: an evaluation of outcome measures. J Eval Clin Pract. Feb. 2001;7(1):47-64. Rec #: 269. [pmid: 11240839].
27 BC Cancer Agency. Cancer management guidelines [Web Page]. Accessed 2005 May 3. Rec #: 744
28 Beeber L. S., Shea J., McCorkle R. The Center for Epidemiologic Studies Depression Scale as a measure of depressive symptoms in newly diagnosed patients. Journal of Psychosocial Oncology. 1998;16(1):1-20. http //www.haworthpressinc.com/store/product.asp?sku=J077. Rec #: 388.
29 Bell, R.; Eccleston, C., and Kalso, E. Ketamine as an adjuvant to opioids for cancer pain. Cochrane Database Syst Rev. 2003; (1):CD003351. Rec #: 250
30 Benditt, J. O. Noninvasive ventilation at the end of life Respir Care. 2000 Nov; 45(11): 1376–81; discussion 1381–4. Rec #: 214
31 Bentley D. W, Bradley S, High K, Schoenbaum S, Taler G, Yoshikawa T. T. Practice guideline for evaluation of fever and infection in long-term care facilities. J Am Geriatr Soc. Feb. 2001;49(2):210-22. Rec #: 556. [pmid: 11207876].
32 Berghmans R. L. L. Ethical hazards of the substituted judgement test in decision making concerning the end of life of dementia patients. Int J Geriatr Psychiatry. Mar. 1997;12(3):283-7. Rec #: 602. [pmid: 9152709].
33 Bernabei R, Gambassi G, Lapane K, Landi F, Gatsonis C, Dunlop R, Lipsitz L, Steel K, Mor V. Management of pain in elderly patients with cancer. SAGE Study Group. Systematic Assessment of Geriatric Drug Use via Epidemiology. JAMA. Jun 17. 1998;279(23):1877-82. Rec #: 286. [pmid: 9634258].
34 Berry, P. H. Getting ready for JCAHO--just meeting the standards or really improving pain management. Clin J Oncol Nurs. 2001 May-2001 Jun 30; 5(3):110–2. Rec #: 255
35 Blasi, Z. V.; Hurley, A. C., and Volicer, L. (Northeastern University, School of Nursing, Boston, MA.). End-of-life care in dementia: a review of problems, prospects, and solutions in practice. Journal of the American Medical Directors Association. 2002 Mar-2002 Apr 30; 3(2):57–65. Rec #: 557
36 Bookbinder M, Coyle N, Kiss M, Goldstein M. L, Holritz K, Thaler H, Gianella A, Derby S, Brown M, Racolin A, Ho M. N, Portenoy R. K. Implementing national standards for cancer pain management: program model and evaluation. J Pain Symptom Manage. Dec. 1996;12(6):334-47. discussion 331–3. Rec #: 292. [pmid: 8973043].
37 Bottomley A. (Coordinator, Quality of Life, European Organization for Research and Treatment of Cancer, avenue E. Mounier 83 Bte 11, 1200 Brussels, Belgium.). Depression in cancer patients: a literature review. European Journal of Cancer Care. Sep. 1998;7(3):181-91. Rec #: 414. [pmid: 9793010].
38 Bradley EH, Hallemeier AG, Fried TR, Johnson-Hurzeler R, Cherlin EJ, Kasl SV, Horwitz SM. Documentation of discussions about prognosis with terminally ill patients. Am J Med. Aug 15. 2001;111(3):218-23. Rec #: 520. [pmid: 11530033].
39 Breen C. M, Abernethy A. P, Abbott K. H, Tulsky J. A. Conflict associated with decisions to limit life-sustaining treatment in intensive care units. J Gen Intern Med. May. 2001;16(5):283-9. Rec #: 546. [pmid: 11359545].
40 Briggs, L. A.; Kirchhoff, K. T.; Hammes, B. J.; Song, M., and Colvin, E. R. (Assistant Director for Advance Care Planning, Gundersen Lutheran Medical Foundation, 1836-1910 South Ave., La Crosse, Wisconsin 54601; labriggs@gundluth.org.). Patient-centered advance care planning in special patient populations: a pilot study. Journal of Professional Nursing. 2004 Jan-2004 Feb 28; 20(1):47–58. Rec #: 540
41 Butow P. N, Maclean M, Dunn S. M, Tattersall M. H, Boyer M. J. The dynamics of change: cancer patients' preferences for information, involvement and support. Annals of Oncology. 1997;8(9):857-63. Rec #: 50312. [pmid: 9358935].
42 Campbell M. L, Guzman J. A. A proactive approach to improve end-of-life care in a medical intensive care unit for patients with terminal dementia. Crit Care Med. Sep. 2004;32(9):1839-43. Rec #: 499. [pmid: 15343010].
43 Cancer Care Ontario. Cancer system quality index: cancer in Ontario- the facts. Ontario, Canada: Cancer Care Ontario; 2005. Rec #: 734
44 Caraceni A, Cherny N, Fainsinger R, Kaasa S, Poulain P, Radbruch L, De Conno F. (Neurology Unit, Rehabilitation and Palliative Care Unit, National Cancer Institute of Milan, via Venezian 1, 20133 Milan, Italy.). Pain measurement tools and methods in clinical research in palliative care: recommendations of an expert working group of the European Association of Palliative Care. Journal of Pain and Symptom Management. Mar. 2002;23(3):239-55. Rec #: 309. [pmid: 11888722].
45 Carlson J, Youngblood R, Dalton J. A, Blau W, Lindley C. (School of Nursing, CB# 7460, Carrington Hall, University of North Carolina at Chapel Hill, Chapel Hill, NC 27599-7460.). Is patient satisfaction a legitimate outcome of pain management?. Journal of Pain and Symptom Management. Mar. 2003;25(3):264-75. Rec #: 327. [pmid: 12614961].
46 Carr D. B. The development of national guidelines for pain control: synopsis and commentary. Eur J Pain. 2001;5 Suppl A:91-8. Rec #: 259. [pmid: 11798226].
47 Centeno-Cortes C, Nunez-Olarte JM. Questioning diagnosis disclosure in terminal cancer patients: a prospective study evaluating patients' responses. Palliat Med. 1994;8(1):39-44. Rec #: 10138. [pmid: 8180739].
48 Center for Practical Bioethics. Guidelines for the determination of decisional incapacity. Center for Practical Bioethcis; 1996. Rec #: 710
49 Chan A, Woodruff RK. Comparison of palliative care needs of English- and non-English-speaking patients. J Palliat Care. Spring. 1999;15(1):26-30. Rec #: 409. [pmid: 10333661].
50 Chang S. M, Parney I. F, Huang W, Anderson F. A Jr, Asher A. L, Bernstein M, Lillehei K. O, Brem H, Berger M. S, Laws E. R. Patterns of care for adults with newly diagnosed malignant glioma. JAMA. Feb 2. 2005;293(5):557-64. Rec #: 716. [pmid: 15687310].
51 Chang V. T, Hwang S. S, Kasimis B. Longitudinal documentation of cancer pain management outcomes: a pilot study at a VA medical center. J Pain Symptom Manage. Nov. 2002;24(5):494-505. Rec #: 249. [pmid: 12547049].
52 Cherry D. L, Vickrey B. G, Schwankovsky L, Heck E, Plauchm M, Yep R. Interventions to improve quality of care: the Kaiser Permanente-alzheimer's Association Dementia Care Project. Am J Manag Care. Aug. 2004;10(8):553-60. Rec #: 626. [pmid: 15352531].
53 Chochinov H. M, Wilson K. G, Enns M, Lander S. “Are you depressed?” Screening for depression in the terminally ill. Am J Psychiatry. May. 1997;154(5):674-6. Rec #: 439. [pmid: 9137124].
54 Clarke, E. B.; Curtis, J. R.; Luce, J. M.; Levy, M.; Danis, M.; Nelson, J., and Solomon, M. Z. Seven end-of-life care domains associated quality indicators and related clinician and organizational itnerventions/behaviors. 2003. Rec #: 104
55 Cleeland, C. S.; Reyes-Gibby, C. C.; Schall, M.; Nolan, K.; Paice, J.; Rosenberg, J. M.; Tollett, J. H., and Kerns, R. D. Rapid improvement in pain management: the Veterans Health Administration and the institute for healthcare improvement collaborative. Clin J Pain. 2003 Sep-2003 Oct 31; 19(5):298–305. Rec #: 242
56 Cohen L. M, Germain M, Poppel D. M, Woods A, Kjellstrand C. M. Dialysis discontinuation and palliative care. Am J Kidney Dis. Jul. 2000;36(1):140-4. Rec #: 564. [pmid: 10873883].
57 Cohen, L. M. and Germain, M. J. Measuring quality of dying in end-stage renal disease. Semin Dial. 2004 Sep-2004 Oct 31; 17(5):376–9. Rec #: 498
58 Cohen-Mansfield J, Libin A, Lipson S. Differences in presenting advance directives in the chart, in the minimum data set, and through the staff's perceptions. Gerontologist. Jun. 2003;43(3):302-8. Rec #: 1376. [pmid: 12810893].
59 Covinsky KE, Fuller JD, Yaffe K, Johnston CB, Hamel MB, Lynn J, Teno JM, Phillips RS. Communication and decision-making in seriously ill patients: findings of the SUPPORT project. The Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Am Geriatr Soc. May. 2000;48(5 Suppl):S187-93. Rec #: 1501. [pmid: 10809474].
60 Crispell K. A. Common cardiovascular issues encountered in geriatric critical care. Crit Care Clin. Oct. 2003;19(4):677-91. Rec #: 521. [pmid: 14601714].
61 Cull A, Gould A, House A, Smith A, Strong V, Velikova G, Wright P, Selby P. Validating automated screening for psychological distress by means of computer touchscreens for use in routine oncology practice. Br J Cancer. Dec 14. 2001;85(12):1842-9. Rec #: 417. [pmid: 11747324].
62 Cullen D. L, Rodak B. Clinical utility of measures of breathlessness. Respir Care. Sep. 2002;47(9):986-93. Rec #: 423. [pmid: 12188932].
63 Curtis J. R. Communicating with patients and their families about advance care planning and end-of-life care. Respir Care. Nov. 2000;45(11):1385-94. discussion 1394–8. Rec #: 215. [pmid: 11063526].
64 Curtis J. R, Engelberg R. A, Nielsen E. L, Au D. H, Patrick D. L. Patient-physician communication about end-of-life care for patients with severe COPD. Eur Respir J. Aug. 2004;24(2):200-5. Rec #: 502. [pmid: 15332385].
65 Curtis J. R, Patrick D. L, Caldwell E, Greenlee H, Collier A. C. The quality of patient-doctor communication about end-of-life care: a study of patients with advanced AIDS and their primary care clinicians. AIDS. Jun 18. 1999;13(9):1123-31. Rec #: 584. [pmid: 10397544].
66 Curtis J. R, Patrick D. L, Caldwell E. S, Collier A. C. Why don't patients and physicians talk about end-of-life care? Barriers to communication for patients with acquired immunodeficiency syndrome and their primary care clinicians. Arch Intern Med. Jun 12. 2000;160(11):1690-6. Rec #: 1587. [pmid: 10847263].
67 Curtis J. R, Patrick D. L, Engelberg R. A, Norris K, Asp C, Byock I. A measure of the quality of dying and death. Initial validation using after-death interviews with family members. J Pain Symptom Manage. Jul. 2002;24(1):17-31. Rec #: 1588. [pmid: 12183092].
68 Dalrymple J. L, Levenback C, Wolf J. K, Bodurka D. C, Garcia M, Gershenson D. M. Trends among gynecologic oncology inpatient deaths: is end-of-life care improving?. Gynecol Oncol. May. 2002;85(2):356-61. Rec #: 533. [pmid: 11972400].
69 Dalton J. A, Blau W, Lindley C, Carlson J, Youngblood R, Greer S. M. (School of Nursing, CB# 7460, University of North Carolina at Chapel Hill, Chapel Hill, NC 27599.). Changing acute pain management to improve patient outcomes: an educational approach. Journal of Pain and Symptom Management. Apr. 1999;17(4):277-87. Rec #: 347. [pmid: 10203880].
70 Dawson R, Spross J. A, Jablonski E. S, Hoyer D. R, Sellers D. E, Solomon M. Z. Probing the paradox of patients' satisfaction with inadequate pain management. Journal of Pain & Symptom Management. 2002;23(3):211-20. Rec #: 367. [pmid: 11888719].
71 de Graeff A, de Leeuw J. R, Ros W. J, Hordijk G. J, Blijham G. H, Winnubst J. A. Sociodemographic factors and quality of life as prognostic indicators in head and neck cancer. Eur J Cancer. Feb. 2001;37(3):332-9. Rec #: 421. [pmid: 11239754].
72 de Rond M, de Wit R, van Dam F. The implementation of a Pain Monitoring Programme for nurses in daily clinical practice: results of a follow-up study in five hospitals. J Adv Nurs. Aug. 2001;35(4):590-8. Rec #: 265. [pmid: 11529959].
73 de Wit R, van Dam F, Abu-Saad HH, Loonstra S, Zandbelt L, van Buuren A, van der Heijden K, Leenhouts G. Empirical comparison of commonly used measures to evaluate pain treatment in cancer patients with chronic pain. J Clin Oncol. Apr. 1999;17(4):1280. Rec #: 356. [pmid: 10561190].
74 de Wit R, van Dam F, Loonstra S, Zandbelt L, van Buuren A, van der Heijden K, Leenhouts G, Duivenvoorden H, Huijer Abu-Saad H. Improving the quality of pain treatment by a tailored pain education programme for cancer patients in chronic pain. Eur J Pain. 2001;5(3):241-56. Rec #: 264. [pmid: 11558980].
75 de Wit R, van Dam F, Vielvoye-Kerkmeer A, Mattern C, Abu-Saad H. H. (Division of Psychosocial Research and Epidemiology, Netherlands Cancer Institute/Antoni van Leeuwenhoek Hospital, Amsterdam, The Netherlands.). The treatment of chronic cancer pain in a cancer hospital in the Netherlands. Journal of Pain and Symptom Management. May. 1999;17(5):333-50. Rec #: 341. [pmid: 10355212].
76 de Wit R, van Dam F, Zandbelt l, van Buuren A, van der Heijden K, Leenhouts G, Loonstra S. A pain education program for chronic cancer pain patients: follow-up results from a randomized controlled trial. Pain. Oct. 1997;73(1):55-69. Rec #: 288. [pmid: 9414057].
77 DeLaGarza, V. W.; Andersen, R. E.; Mach, J., and Bennett, R. G. (Johns Hopkins University School of Medicine, Division of Geriatric Medicine and Gerontology, Johns Hopkins Geriatrics Center, Baltimore, MD.). Improving rates of advance directive discussions among managed care nursing home enrollees. Journal of the American Medical Directors Association. 2001 May-2001 Jun 30; 2(3):105–9. Rec #: 566
78 Della Santina C, Bernstein R. H. Whole-patient assessment, goal planning, and inflection points: their role in achieving quality end-of-life care. Clin Geriatr Med. Nov. 2004;20(4):595-620. v. Rec #: 496. [pmid: 15541615].
79 Desbiens N. A, Mueller-Rizner N, Connors A. F Jr, Wenger N. S, Lynn J. (University of Tennessee College of Medicine, Chattanooga Unit, 921 East Third St., Suite 400, Chattanooga, TN 37403.). The symptom burden of seriously ill hospitalized patients. Journal of Pain and Symptom Management. Apr. 1999;17(4):248-55. Rec #: 346. [pmid: 10203877].
80 Detterbeck F. C, Jones D. R, Kernstine K. H, Naunheim K. S. Lung cancer. Special treatment issues. Chest. Jan. 2003;123(1 Suppl):244S-258S. Rec #: 167. [pmid: 12527583].
81 Devine, E. C. Meta-analysis of the effect of psychoeducational interventions on pain in adults with cancer. Oncol Nurs Forum. 2003 Jan-2003 Feb 28; 30(1):75–89. Rec #: 365
82 Devlen J, Maguire P, Phillips P, Crowther D. Psychological problems associated with diagnosis and treatment of lymphomas. II: Prospective study. British Medical Journal Clinical Research Ed. 1987;295(6604):955-7. Rec #: 455. [pmid: 3119124]. [pmcid: 1248003].
83 Devlen J, Maguire P, Phillips P, Crowther D, Chambers H. Psychological problems associated with diagnosis and treatment of lymphomas. I: Retrospective study. British Medical Journal Clinical Research Ed. 1987;295(6604):953-4. Rec #: 456. [pmid: 3119123]. [pmcid: 1248002].
84 Dolan C. S. Putting guidelines to work in an ambulatory care setting. Oncol Nurs Forum. Oct. 1995;22(9):1436. Rec #: 302. [pmid: 8539186].
85 Donner C. F, Muir J. F. Selection criteria and programmes for pulmonary rehabilitation in COPD patients. Rehabilitation and Chronic Care Scientific Group of the European Respiratory Society. Eur Respir J. Mar. 1997;10(3):744-57. Rec #: 447. [pmid: 9073018].
86 Donovan KA, Greene PG, Shuster JL, Partridge EE, Tucker DC. Treatment preferences in recurrent ovarian cancer. Gynecol Oncol. Aug. 2002;86(2):200-11. Rec #: 1899. [pmid: 12144829].
87 Du Pen A. R, Du Pen S, Hansberry J, Miller-Kraybill B, Millen J, Everly R, Hansen N, Syrjala K. An educational implementation of a cancer pain algorithm for ambulatory care. Pain Manag Nurs. Dec. 2000;1(4):116-28. Rec #: 261. [pmid: 11709865].
88 Du Pen S. L, Du Pen A. R, Polissar N, Hansberry J, Kraybill B. M, Stillman M, Panke J, Everly R, Syrjala K. Implementing guidelines for cancer pain management: results of a randomized controlled clinical trial. J Clin Oncol. Jan. 1999;17(1):361-70. Rec #: 277. [pmid: 10458255].
89 Dudgeon D. J, Kristjanson L, Sloan J. A, Lertzman M, Clement K. Dyspnea in cancer patients: prevalence and associated factors. Journal of Pain & Symptom Management. 2001;21(2):95-102. Rec #: 457. [pmid: 11226761].
90 Dufault M. A, Willey-Lessne C. (Associate Professor, College of Nursing, University of Rhode Island, Kingston, Rhode Island.). Using a collaborative research utilization model to develop and test the effects of clinical pathways for pain management. Journal of Nursing Care Quality. Apr. 1999;13(4):19-33. Rec #: 345. [pmid: 10330788].
91 Dy, S. and Teno, J. Palliative care/end of life measures background paper. IOM. Rec #: 750
92 Emery C, Gallagher R, Hugi M, Levine M. Clinical practice guidelines for the care and treatment of breast cancer: the management of chronic pain in patients with breast cancer (summary of the 2001 update). CMAJ. Oct 30. 2001;165(9):1218-9. Rec #: 720. [pmid: 11706911]. [pmcid: 81584].
93 Evers M. M, Meier D. E, Morrison R. S. Assessing differences in care needs and service utilization in geriatric palliative care patients. J Pain Symptom Manage. May. 2002;23(5):424-32. Rec #: 532. [pmid: 12007760].
94 Extreme Care, Humane Options ECHO. Recommendations for improving end-of-life care for persons residing in California skilled nursing and intermediate care facilities. Sacramento, CA: California Coalition for Compassionate Care; 2000 Jan(Nursing Faclity Recommendations). Rec #: 474
95 Farrar J. T, Berlin J. A, Strom B. L. Clinically important changes in acute pain outcome measures: a validation study. J Pain Symptom Manage. May. 2003;25(5):406-11. Rec #: 247. [pmid: 12727037].
96 Fellowes, D.; Barnes, K., and Wilkinson, S. Aromatherapy and massage for symptom relief in patients with cancer. Cochrane Database Syst Rev. 2004; (2):CD002287. Rec #: 232
97 Ferrell, B. R.; Juarez, G., and Borneman, T. (Nursing Research and Education Department, City of Hope National Medical Center, Duarte, CA.). Use of routine and breakthrough analgesia in home care. Oncology Nursing Forum. 1999 Nov-1999 Dec 31; 26(10):1655–60. Rec #: 340
98 Fischer G. S, Alpert H. R, Stoeckle J. D, Emanuel L. L. Can goals of care be used to predict intervention preferences in an advance directive?. Arch Intern Med. Apr 14. 1997;157(7):801-7. Rec #: 600. [pmid: 9125014].
99 Fortner B. V, Okon T. A, Ashley J, Kepler G, Chavez J, Tauer K, Clements-Thompson M, Schwartzberg L, Demarco G, Houts A. C. The Zero Acceptance of Pain (ZAP) Quality Improvement Project: evaluation of pain severity, pain interference, global quality of life, and pain-related costs. J Pain Symptom Manage. Apr. 2003;25(4):334-43. Rec #: 248. [pmid: 12691685].
100 Fried T. R, Mor V. Frailty and hospitalization of long-term stay nursing home residents. J Am Geriatr Soc. Mar. 1997;45(3):265-9. Rec #: 41137. [pmid: 9063269].
101 Fried TR, Bradley EH. What matters to seriously ill older persons making end-of-life treatment decisions?: A qualitative study. J Palliat Med. Apr. 2003;6(2):237-44. Rec #: 2435. [pmid: 12854940].
102 Fried TR, Bradley EH, O'Leary J. Prognosis communication in serious illness: perceptions of older patients, caregivers, and clinicians. J Am Geriatr Soc. Oct. 2003;51(10):1398-403. Rec #: 2436. [pmid: 14511159].
103 Fried TR, Bradley EH, Towle VR. Assessment of patient preferences: integrating treatments and outcomes. J Gerontol B Psychol Sci Soc Sci. Nov. 2002;57(6):S348-54. Rec #: 2437. [pmid: 12426443].
104 Fried TR; Bradley EH; Towle VR Allore H. Understanding the treatment preferences of seriously ill patients. N Engl J Med. 2002 Apr 4; 346(14):1061–6. Comment in: N Engl J Med. 2002 Apr 4;346(14):1087–9. PMID: 11932479. Comment in: N Engl J Med. 2002 Aug 15;347(7):533–-5; author reply 533–5. PMID: 12181411. Comment in: N Engl J Med 2002 Aug 15 347 (7) 533–5 ; author reply 533–5. PMID: 12182184. Co. Rec #: 2439
105 Gessert C. E, Mosier M. C, Brown E. F, Frey B. (Office of Primary Care, University of Kansas Medical Center, Kansas City, Kansas.). Tube feeding in nursing home residents with severe and irreversible cognitive impairment. Journal of the American Geriatrics Society. Dec. 2000;48(12):1593-600. Rec #: 582. [pmid: 11129748].
106 Gifford, D. and Schmidt, L. Breast cancer diagnosis and treatment. Asch, S. M.; Kerr, E. A.; Hamilton, E. G.; Reifel, J. L., and McGlynn, E. A. Quality of care for oncologic condition and HIV: a review of the literature and quality indicators. RAND; 2000; pp. 33–45. Rec #: 704
107 Golant M, Altman T, Martin C. (Wellness Community-National, 2716 Ocean Park Blvd, Suite 1040, Santa Monica, CA 90405; golant@la.wellnesscommunity.org.). Managing cancer side effects to improve quality of life: a cancer psychoeducation program. Cancer Nursing. Feb. 2003;26(1):37-46. Rec #: 400. [pmid: 12556711].
108 Golin C. E, Wenger N. S, Liu H, Dawson N. V, Teno J. M, Desbiens N. A, Lynn J, Oye R. K, Phillips R. S. A prospective study of patient-physician communication about resuscitation. J Am Geriatr Soc. May. 2000;48(5 Suppl):S52-60. Rec #: 570. [pmid: 10809457].
109 Goodlin, S. J.; Zhong, Z.; Lynn, J.; Teno, J. M.; Fago, J. P.; Desbiens, N.; Connors, A. F. Jr; Wenger, N. S., and Phillips, R. S. Factors associated with use of cardiopulmonary resuscitation in seriously ill hospitalized adults. JAMA. 1999 Dec 22-1999 Dec 29; 282(24):2333–9. Rec #: 577
110 Goodman M. D, Tarnoff M, Slotman G. J. Effect of advance directives on the management of elderly critically ill patients. Crit Care Med. Apr. 1998;26(4):701-4. Rec #: 591. [pmid: 9559607].
111 Gordon D. B, Pellino T. A, Miaskowski C, McNeill J. A, Paice J. A, Laferriere D, Bookbinder M. A. 10-year review of quality improvement monitoring in pain management: recommendations for standardized outcome measures. Pain Manag Nurs. Dec. 2002;3(4):116-30. Rec #: 252. [pmid: 12454804].
112 Grande GE, McKerral A, Todd CJ. Which cancer patients are referred to Hospital at Home for palliative care?. Palliat Med. Mar. 2002;16(2):115-23. Rec #: 2777. [pmid: 11969142].
113 Grant M, Ferrell B. R, Rivera L. M, Lee J. Unscheduled readmissions for uncontrolled symptoms. A health care challenge for nurses. Nurs Clin North Am. Dec. 1995;30(4):673-82. Rec #: 299. [pmid: 7501535].
114 Grant M, Rivera L. M, Alisangco J, Francisco L. Improving cancer pain management using a performance improvement framework. J Nurs Care Qual. Apr. 1999;13(4):60-72. Rec #: 280. [pmid: 10330791].
115 Grant S, Aitchison T, Henderson E, Christie J, Zare S, McMurray J, Dargie H. (Institute of Biomedical and Life Sciences, University of Glasgow, 64 Oakfield Ave, Glasgow, G12 8LT, UK; e-mail: S.Grant@bio.gla.ac.uk.). A comparison of the reproducibility and the sensitivity to change of visual analogue scales, Borg scales, and Likert scales in normal subjects during submaximal exercise. Chest. Nov. 1999;116(5):1208-17. Rec #: 395. [pmid: 10559077].
116 Greenberg, A.; Angus, H.; Sullivan, T., and Brown, A. D. Development of a set of strategy-based system-level cancer care performance indicators in Ontario, Canada. Int J Qual Health Care. 2005 Jan 21. Rec #: 209
117 Greenberg, D. B. Barriers to the treatment of depression in cancer patients. J Natl Cancer Inst Monogr. 2004; (32):127–35. Rec #: 391
118 Griffin J. P, Nelson J. E, Koch K. A, Niell H. B, Ackerman T. F, Thompson M, Cole F. H Jr. End-of-life care in patients with lung cancer. Chest. Jan. 2003;123(1 Suppl):312S-331S. Rec #: 101. [pmid: 12527587].
119 Grond S, Zech D, Lynch J, Diefenbach C, Schug SA, Lehmann KA. Validation of World Health Organization guidelines for pain relief in head and neck cancer. A prospective study. Ann Otol Rhinol Laryngol. May. 1993;102(5):342-8. Rec #: 357. [pmid: 7683853].
120 Grond S, Zech D, Schug SA, Lynch J, Lehmann KA. Validation of World Health Organization guidelines for cancer pain relief during the last days and hours of life. J Pain Symptom Manage. Oct. 1991;6(7):411-22. Rec #: 358. [pmid: 1940485].
121 Gunnarsdottir S, Donovan H. S, Serlin R. C, Voge C, Ward S. Patient-related barriers to pain management: the Barriers Questionnaire II (BQ-II). Pain. Oct. 2002;99(3):385-96. Rec #: 253. [pmid: 12406513].
122 Guyatt G. H, King D. R, Feeny D. H, Stubbing D, Goldstein R. S. Generic and specific measurement of health-related quality of life in a clinical trial of respiratory rehabilitation. J Clin Epidemiol. Mar. 1999;52(3):187-92. Rec #: 444. [pmid: 10210235].
123 Hagan S. Using guidelines for education, policy making, and assessing quality of care. Oncol Nurs Forum. Oct. 1995;22(9):1435-6. Rec #: 303. [pmid: 8539185].
124 Haidet P, Hamel M. B, Davis R. B, Wenger N, Reding D, Kussin P. S, Connors A. F Jr, Lynn J, Weeks J. C, Phillips R. S. Outcomes, preferences for resuscitation, and physician-patient communication among patients with metastatic colorectal cancer. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. Am J Med. Sep. 1998;105(3):222-9. Rec #: 587. [pmid: 9753025].
125 Hakim R. B, Teno J. M, Harrell F. E Jr, Knaus W. A, Wenger N, Phillips R. S, Layde P, Califf R, Connors A. F Jr, Lynn J. Factors associated with do-not-resuscitate orders: patients' preferences, prognoses, and physicians' judgments. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. Ann Intern Med. Aug 15. 1996;125(4):284-93. Rec #: 608. [pmid: 8678391].
126 Hanks GW, Robbins M, Sharp D, Forbes K, Done K, Peters TJ, Morgan H, Sykes J, Baxter K, Corfe F, Bidgood C. The imPaCT study: a randomised controlled trial to evaluate a hospital palliative care team. Br J Cancer. Sep 23. 2002;87(7):733-9. Rec #: 425. [pmid: 12232756].
127 Hann D, Winter K, Jacobsen P. Measurement of depressive symptoms in cancer patients: evaluation of the Center for Epidemiological Studies Depression Scale (CES-D). J Psychosom Res. May. 1999;46(5):437-43. Rec #: 433. [pmid: 10404478].
128 Hansen-Flaschen J. H. Dyspnea in the ventilated patient: a call for patient-centered mechanical ventilation. Respir Care. Dec. 2000;45(12):1460-4. discussion 1464–7. Rec #: 217. [pmid: 11107212].
129 Hansen-Flaschen J. H. Palliative home care for advanced lung disease. Respir Care. Dec. 2000;45(12):1478-86. discussion 1486–9. Rec #: 219. [pmid: 11107214].
130 Hanson L. C, Henderson M, Menon M. As individual as death itself: a focus group study of terminal care in nursing homes. J Palliat Med. Feb. 2002;5(1):117-25. Rec #: 536. [pmid: 11839234].
131 Hardin S. B, Yusufaly Y. A. Difficult end-of-life treatment decisions: do other factors trump advance directives? Arch Intern Med. Jul 26. 2004;164(14):1531-3. Rec #: 505.
132 Harter M, Reuter K, Aschenbrenner A, Schretzmann B, Marschner N, Hasenburg A, Weis J. Psychiatric disorders and associated factors in cancer: results of an interview study with patients in inpatient, rehabilitation and outpatient treatment. Eur J Cancer. Jul. 2001;37(11):1385-93. Rec #: 419. [pmid: 11435069].
133 Hawryluck L. A, Harvey W. R, Lemieux-Charles L, Singer P. A. Consensus guidelines on analgesia and sedation in dying intensive care unit patients. BMC Med Ethics. Aug 12. 2002;3(1):E3. Rec #: 469. [pmid: 12171602].
134 Heffner J. E. Role of pulmonary rehabilitation in palliative care. Respir Care. Nov. 2000;45(11):1365-71. discussion 1371–5. Rec #: 213. [pmid: 11063524].
135 Heiman H, Bates D. W, Fairchild D, Shaykevich S, Lehmann L. S. Improving completion of advance directives in the primary care setting: a randomized controlled trial. Am J Med. Sep 1. 2004;117(5):318-24. Rec #: 501. [pmid: 15336581].
136 Hester N. O, Miller K. L, Foster R. L, Vojir C. P. Symptom management outcomes. Do they reflect variations in care delivery systems?. Med Care. Nov. 1997;35(11 Suppl):NS69-83. Rec #: 289. [pmid: 9366881].
137 Higginson I. J, Finlay I, Goodwin D. M, Cook A. M, Hood K, Edwards A. G. K, Douglas H, Norman C. E. (Department of Palliative Care & Policy, King's College London, Weston Education Center, Cutcombe Road, Denmark Hill, London SE5 9RJ, United Kingdom.). Do hospital-based palliative teams improve care for patients or families at the end of life?. Journal of Pain and Symptom Management. Feb. 2002;23(2):96-106. Rec #: 314. [pmid: 11844629].
138 Hinkka H, Kosunen E, Metsanoja R, Lammi UK, Kellokumpu-Lehtinen P. Factors affecting physicians' decisions to forgo life-sustaining treatments in terminal care. J Med Ethics. 2002;28(2):109-14. Rec #: 3231. [pmid: 11934941]. [pmcid: 1733551].
139 Hofmann J. C, Wenger N. S, Davis R. B, Teno J, Connors A. F Jr, Desbiens N, Lynn J, Phillips R. S. Patient preferences for communication with physicians about end-of-life decisions. SUPPORT Investigators. Study to Understand Prognoses and Preference for Outcomes and Risks of Treatment. Ann Intern Med. Jul 1. 1997;127(1):1-12. Rec #: 599. [pmid: 9214246].
140 Holland, J. C. and Chertkov, L. Clinical practice guidelines for the management of psychosocial and physical symptoms of cancer. Improving Palliative Care for Cancer. Washington, DC: National Academy Press; 2001. Rec #: 485
141 Hollen PJ, Gralla RJ, Kris MG, Eberly SW, Cox C. Normative data and trends in quality of life from the Lung Cancer Symptom Scale (LCSS). Support Care Cancer. May. 1999;7(3):140-8. Rec #: 452. [pmid: 10335932].
142 Holzheimer A, McMillan S. C, Weitzner M. Improving pain outcomes of hospice patients with cancer. Oncology Nursing Forum. Oct. 1999;26(9):1499-504. Rec #: 339. [pmid: 11064881].
143 Hooke, C.; Hellsten, M. B.; Stutzer, C., and Forte, K. Pain management for the child with cancer in end-of-life care: APON position paper. Journal of Pediatric Oncology Nursing. 2002 Mar 8–2002 Apr 8; 19(2):43–7. Rec #: 308
144 Hopwood P, Howell A, Maguire P. Psychiatric morbidity in patients with advanced cancer of the breast: prevalence measured by two self-rating questionnaires. British Journal of Cancer. 1991;64(2):349-52. Rec #: 458. [pmid: 1892762].
145 Hopwood P, Howell A, Maguire P. Screening for psychiatric morbidity in patients with advanced breast cancer: validation of two self-reportquestionnaires. British Journal of Cancer. 1991;64(2):353-6. Rec #: 459. [pmid: 1892763].
146 Hopwood P, Stephens RJ. Depression in patients with lung cancer: prevalence and risk factors derived from quality-of-life data. J Clin Oncol. Feb. 2000;18(4):893-903. Rec #: 431. [pmid: 10673533].
147 Huang, H.; Wilkie, D. J.; Zong, S.; Berry, D.; Hairabedian, D.; Judge, M. K.; Farber, S., and Chabal, C. (Dept of Biobehavioral Nursing and Health Systems, Box 357266, University of Washington, Seattle, WA 98195–7266; hyhuang@u.washington.edu.). Developing a computerized data collection and decision support system for cancer pain management. CIN: Computers, Informatics, Nursing. 2003 Jul–2003 Aug 31; 21(4):206–17. Rec #: 329
148 Hwang S. S, Chang V. T, Cogswell J, Alejandro Y, Osenenko P, Morales E, Srinivas S, Kasimis B. Study of unmet needs in symptomatic veterans with advanced cancer: incidence, independent predictors and unmet needs outcome model. J Pain Symptom Manage. Nov. 2004;28(5):421-32. Rec #: 385. [pmid: 15504619].
149 Hwang S. S, Chang V. T, Fairclough D. L, Cogswell J, Kasimis B. (Section of Hematology/Oncology (111), VA New Jersey Health Care System, 385 Tremont Ave., East Orange, NJ 07018.). Longitudinal quality of life in advanced cancer patients: pilot study results from a VA Medical Cancer Center. Journal of Pain and Symptom Management. Mar. 2003;25(3):225-35. Rec #: 328. [pmid: 12614957].
150 Hwang S. S, Chang V. T, Fairclough D. L, Kasimis B. (Section of Hematology/Oncology (111), VA New Jersey Health Care System at East Orange, 385 Tremont Avenue, East Orange, NJ 07018.). Development of a cancer pain prognostic scale. Journal of Pain and Symptom Management. Oct. 2002;24(4):366-78. Rec #: 334. [pmid: 12505205].
151 Hwang S. S, Chang V. T, Kasimis B. (Section Hematology/Oncology (111), VA New Jersey Health Care System at East Orange, 385 Tremont Avenue, East Orange, NJ 07018.). Dynamic cancer pain management outcomes: the relationship between pain severity, pain relief, functional interference, satisfaction and global quality of life over time. Journal of Pain and Symptom Management. Mar. 2002;23(3):190-200. Rec #: 311. [pmid: 11888717].
152 Ibbotson T, Maguire P, Selby P, Priestman T, Wallace L. Screening for anxiety and depression in cancer patients: the effects of disease and treatment. European Journal of Cancer. 1994;30A(1):37-40. Rec #: 460. [pmid: 8142161].
153 Ingram S. S, Seo P. H, Martell R. E, Clipp E. C, Doyle M. E, Montana G. S, Cohen H. J. (Box 3085, Dept of Radiation Oncology, Duke University Medical Center, Durham, NC 27710; ingram@radonc.duke.edu.). Comprehensive assessment of the elderly cancer patient: the feasibility of self-report methodology. Journal of Clinical Oncology. Feb 1. 2002;20(3):770-5. Rec #: 406. [pmid: 11821460].
154 Jacobs L. G, Bonuck K, Burton W, Mulvihill M. (Department of Medicine, Division of Geriatrics, Montefiore Medical Center, 111 East 210th Street, Bronx, New York 10467.). Hospital care at the end of life: an institutional assessment. Journal of Pain and Symptom Management. Sep. 2002;24(3):291-8. Rec #: 333. [pmid: 12458110].
155 Jadad A. R, Browman G. P. The WHO analgesic ladder for cancer pain management. Stepping up the quality of its evaluation. JAMA. Dec 20. 1995;274(23):1870-3. Rec #: 297. [pmid: 7500538].
156 Jadlos, M. A.; Kelman, G. B.; Marra, K., and Lanoue, A. (- Samaritan Hospital, Troy, NY). - Documentation. A pain management documentation tool. - Oncology Nursing Forum. 23(9):1451–4, 1996 Oct. (7 Ref). 1996 Oct. Rec #: 307
157 Jefford M, Mileshkin L, Richards K, Thomson J, Matthews J. P, Zalcberg J, Jennens R, McLachlan S. A, Wein S, Antill Y, Clarke D. M. Rapid screening for depression--validation of the Brief Case-Find for Depression (BCD) in medical oncology and palliative care patients. Br J Cancer. Aug 31. 2004;91(5):900-6. Rec #: 390. [pmid: 15305199].
158 Jennings, A-L; Davies, A. N.; Higgins, J. P. T.; Gibbs, J. S. R., and Broadley, K. E. A systematic review of the use of opioids in the management of dyspnoea. Thorax. 2002; (57):939–44. Rec #: 157
159 Jensen M. P. (Department of Rehabilitation Medicine, Box 356490, University of Washington School of Medicine, Seattle, WA 98195–6490; mjensen@u.washington.edu.). The validity and reliability of pain measures in adults with cancer. Journal of Pain. Feb. 2003;4(1):2-21. Rec #: 330. [pmid: 14622723].
160 Johnston S. C, Pfeifer M. P, McNutt R. The discussion about advance directives. Patient and physician opinions regarding when and how it should be conducted. End of Life Study Group. Arch Intern Med. May 22. 1995;155(10):1025-30. Rec #: 617. [pmid: 7748044].
161 Joint Commission on Accreditation of Healthcare Organizations (JCAHO) and National Pharmaceutical Council, Inc. NPC. Improving the quality of pain management through measurement and action. 2003 Mar. Rec #: 745
162 Kaiser Permanente, Care Management Institute's Cancer Initiative Guidelines Workgroup and Care Management Institute Kaiser Permanente. Evidence-based guidelines for the management of chemotherapy-induced nausea & vomiting and moderate to severe cancer-associated pain. 2003 Mar. Rec #: 175
163 Kane R. S, Burns E. A. Cardiopulmonary resuscitation policies in long-term care facilities. J Am Geriatr Soc. Feb. 1997;45(2):154-7. Rec #: 41723. [pmid: 9033512].
164 Keay T. J, Taler J, Fredman L, Levenson S. A. Assessing medical care of dying residents in nursing homes. Am J Med Qual. Fall. 1997;12(3):151-6. Rec #: 3779. [pmid: 9287453].
165 Keenan S. P, Busche K. D, Chen L. M, McCarthy L, Inman K. J, Sibbald W. J. A retrospective review of a large cohort of patients undergoing the process of withholding or withdrawal of life support. Crit Care Med. Aug. 1997;25(8):1324-31. Rec #: 50514. [pmid: 9267945].
166 Introduction. Kerr, E. A.; Asch, S. M.; Hamilton, E. G., and McGlynn, E. A. Quality of care for cardiopulmonary conditions: a review of the literature and quality indicators. RAND; 2000; pp. 1–27. Rec #: 737
167 Kerridge I. H, Pearson S. A, Rolfe I. E, Lowe M. Decision making in CPR: attitudes of hospital patients and healthcare professionals. Med J Aust. Aug 3. 1998;169(3):128-31. Rec #: 3855. [pmid: 9734507].
168 Kirchhoff K. T, Anumandla P. R, Foth K. T, Lues S. N, Gilbertson-White S. H. Documentation on withdrawal of life support in adult patients in the intensive care unit. Am J Crit Care. Jul. 2004;13(4):328-34. Rec #: 503. [pmid: 15293586].
169 Kurtz, M. E.; Kurtz, J. C.; Stommel, M.; Given, C. W., and Given, B. (Professor, Department of Family and Community Medicine, Michigan State University, B211 West Fee Hall, East Lansing, MI 48824.). Physical functioning and depression among older persons with cancer. Cancer Practice: A Multidisciplinary Journal of Cancer Care. 2001 Jan–2001 Feb 28; 9(1):11–8. Rec #: 411
170 Laakkonen, M. L.; Pitkala, K. H.; Strandberg, T. E.; Berglind, S., and Tilvis, R. S. Living will, resuscitation preferences, and attitudes towards life in an aged population. Gerontology. 2004 Jul–2004 Aug 31; 50(4):247–54. Rec #: 506
171 Lacasse, Y.; Brosseau, L.; Milne, S.; Martin, S.; Wong, E.; Guyatt, G. H., and Goldstein, R. S. Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2002; (3):CD003793. Rec #: 428
172 Lacasse Y, Wong E, Guyatt G. H, King D, Cook D. J, Goldstein R. S. Meta-analysis of respiratory rehabilitation in chronic obstructive pulmonary disease. Lancet. Oct 26. 1996;348(9035):1115-9. Rec #: 448. [pmid: 8888163].
173 Lamy O, Jenzer-Closuit A, Burckhardt P. Hypercalcaemia of malignancy: an undiagnosed and undertreated disease. J Intern Med. Jul. 2001;250(1):73-9. Rec #: 267. [pmid: 11454145].
174 Landi, F.; Onder, G.; Cesari, M.; Gambassi, G.; Steel, K.; Russo, A.; Lattanzio, F., and Bernabei, R. Pain management in frail, community-living elderly patients. Arch Intern Med. 2001 Dec 10–2001 Dec 24; 161(22):2721–4. Rec #: 628
175 Larue F, Colleau S. M, Brasseur L, Cleeland C. S. Multicentre study of cancer pain and its treatment in France. BMJ. Apr 22. 1995;310(6986):1034-7. Rec #: 304. [pmid: 7728056]. [pmcid: 2549429].
176 Larue F, Colleau S. M, Fontaine A, Brasseur L. Oncologists and primary care physicians' attitudes toward pain control and morphine prescribing in France. Cancer. Dec 1. 1995;76(11):2375-82. Rec #: 298. [pmid: 8635046].
177 Lee M. A, Brummel-Smith K, Meyer J, Drew N, London M. R. Physician orders for life-sustaining treatment (POLST): outcomes in a PACE program. Program of All-Inclusive Care for the Elderly. J Am Geriatr Soc. Oct. 2000;48(10):1219-25. Rec #: 561. [pmid: 11037008].
178 Lee Y. C, Baumann M. H, Maskell N. A, Waterer G. W, Eaton T. E, Davies R. J, Heffner J. E, Light R. W. Pleurodesis practice for malignant pleural effusions in five English-speaking countries: survey of pulmonologists. Chest. Dec. 2003;124(6):2229-38. Rec #: 759. [pmid: 14665505].
179 Levy, C. R.; Fish, R., and Kramer, A. M. (Division of Health Care Policy and Research, University of Colorado, 13611 E. Colfax Ave., Suite 100, Aurora, CO 80011; cari.levy@uchsc.edu.). Site of death in the hospital versus nursing home of Medicare skilled nursing facility residents admitted under Medicare's Part A Benefit. Journal of the American Geriatrics Society. 2004 Aug; 52(8):1247–54. Rec #: 542
180 Lorenz K. A, Lynn J. Oregon's lessons for improving advance care planning. J Am Geriatr Soc. Sep. 2004;52(9):1574-5. Rec #: 500. [pmid: 15341565].
181 Mancini I, Body J. J. Assessment of dyspnea in advanced cancer patients. Support Care Cancer. Jul. 1999;7(4):229-32. Rec #: 443. [pmid: 10423048].
182 Manfredi P. L, Chandler S, Pigazzi A, Payne R. Outcome of cancer pain consultations. Cancer. 2000;89(4):920-4. Rec #: 368. [pmid: 10951358].
183 Manning H. L. Dyspnea treatment. Respir Care. Nov. 2000;45(11):1342-50. discussion 1350–4. Rec #: 211. [pmid: 11063522].
184 Marik P. E, Craft M. An outcomes analysis of in-hospital cardiopulmonary resuscitation: the futility rationale for do not resuscitate orders. J Crit Care. Sep. 1997;12(3):142-6. Rec #: 594. [pmid: 9328854].
185 Markson L, Clark J, Glantz L, Lamberton V, Kern D, Stollerman G. The doctor's role in discussing advance preferences for end-of-life care: perceptions of physicians practicing in the VA. J Am Geriatr Soc. Apr. 1997;45(4):399-406. Rec #: 4791. [pmid: 9100706].
186 Martinez, M. J.; Roque, M.; Alonso-Coello, P.; Catala, E.; Garcia, J. L., and Ferrandiz, M. Calcitonin for metastatic bone pain. Cochrane Database Syst Rev. 2003; (3):CD003223. Rec #: 244
187 Maunsell E, Allard P, Dorval M, Labbe J. A brief pain diary for ambulatory patients with advanced cancer: acceptability and validity. Cancer. May 15. 2000;88(10):2387-97. Rec #: 275. [pmid: 10820363].
188 McDonald M. V, Passik S. D, Dugan W, Rosenfeld B, Theobald D. E, Edgerton S. Nurses' recognition of depression in their patients with cancer. Oncol Nurs Forum. Apr. 1999;26(3):593-9. Rec #: 434. [pmid: 10214600].
189 McGlynn, E. A. Applying the strategic framework board's model to select national goals and core measures for stimulating improved care for cancer. 2002 Aug 21; RAND Health. Rec #: 105
190 McGlynn, E. A. and Malin, J. Selecting national goals and core measures of cancer care quality (Background paper #2). RAND. 2002 Aug 21. Rec #: 103
191 McLachlan, S.; Allenby, A.; Matthews, J.; Wirth, A.; Kissane, D.; Bishop, M.; Beresford, J., and Zalcberg, J. (Family Cancer Centre, Peter MacCallum Cancer Institute, Locked Bag 1, A'Beckett St PO, Melbourne, Victoria 8006, Australia; mclachsa@svhm.org.au.). Randomized trial of coordinated psychosocial interventions based on patient self-assessments versus standard care to improve the psychosocial functioning of patients with cancer. Journal of Clinical Oncology. 2001 Nov 1; 19(21):4117–25. Rec #: 408
192 McMillan, S. C. (University of South Florida, College of Nursing, MDC 22, 12901 Bruce B Downs Boulevard, Tampa, FL 33612.). Pain and pain relief experienced by hospice patients with cancer. Cancer Nursing. 1996 Aug; 19(4):298–307. Rec #: 336
193 McNicol E, Horowicz-Mehler N, Fisk R. A, Bennett K, Gialeli-Goudas M, Chew P. W, Lau J, Carr D. Management of opioid side effects in cancer-related and chronic noncancer pain: a systematic review. J Pain. Jun. 2003;4(5):231-56. Rec #: 237. [pmid: 14622694].
194 McParland E, Likourezos A, Chichin E, Castor T, Paris B. E. Stability of preferences regarding life-sustaining treatment: a two-year prospective study of nursing home residents. Mt Sinai J Med. Mar. 2003;70(2):85-92. Rec #: 42225. [pmid: 12634900].
195 McQuay, H. J.; Moore, R. A.; Eccleston, C.; Morley, S., and Williams, A. C. Systematic review of outpatient services for chronic pain control. Health Technol Assess. 1997; 1(6):i–iv, 1–135. Rec #: 287
196 Mercadante S. Pain treatment and outcomes for patients with advanced cancer who receive follow-up care at home. Cancer. Apr 15. 1999;85(8):1849-58. Rec #: 282. [pmid: 10223581].
197 Mercadante, S.; Agnello, A.; Armata, m. G., and Pumo, S. (Pain Relief and Palliative Care, SAMOT, via Liberta 191, 90141, Palermo, Italy.). Clinical note. The inappropriate use of the epidural route in cancer pain. Journal of Pain and Symptom Management. 1997 Apr; 13(4):233–7. Rec #: 351
198 Mercadante S, Radbruch L, Caraceni A, Cherny N, Kaasa S, Nauck F, Ripamonti C, De Conno F. Episodic (breakthrough) pain: consensus conference of an expert working group of the European Association for Palliative Care. Cancer. Feb 1. 2002;94(3):832-9. Rec #: 258. [pmid: 11857319].
199 Meuser T, Pietruck C, Radbruch L, Stute P, Lehmann K. A, Grond S. Symptoms during cancer pain treatment following WHO-guidelines: a longitudinal follow-up study of symptom prevalence, severity and etiology. Pain. Sep. 2001;93(3):247-57. Rec #: 266. [pmid: 11514084].
200 Meyer H. A, Sinnott C, Seed P. T. Depressive symptoms in advanced cancer. Part 2. Depression over time; the role of the palliative care professional. Palliat Med. Oct. 2003;17(7):604-7. Rec #: 450. [pmid: 14594151].
201 Mezey, M, Kluger, M, Maislin, G, Mittelman, M. Life-sustaining treatment decisions by spouses of patients with Alzheimer's disease. J Am Geriatr Soc. Feb. 1996;44(2):144-50. Rec #: 613. [pmid: 8576503].
202 Mezey Mathy, Teresi Jeanne, Ramsey Gloria, Mitty Ethel, Bobrowitz Tracy. Decision-making capacity to execute a heath care proxy: Development and testing of guidelines. Journal of the American Geriatrics Society. 2000;48(2):179-187. http //www.blackwell-science.com/~cgilib/bsinc.bin?Journal=geriatricsRec #: 493. [pmid: 10682947].
203 Miaskowski C. New approaches for evaluating the quality of cancer pain management in the outpatient setting. Pain Manag Nurs. Mar. 2001;2(1):7-12. Rec #: 262. [pmid: 11705164].
204 Miaskowski, C.; Mack, K. A.; Dodd, M.; West, C.; Paul, S. M.; Tripathy, D.; Koo, P.; Schumacher, K., and Facione, N. (School of Nursing, University of California, San Francisco, CA, Chris.Miaskowski@nursing.ucsf.edu.). Oncology outpatients with pain from bone metastasis require more than around-the-clock dosing of analgesics to achieve adequate pain control. Journal of Pain. 2002 Feb; 3(1):12–20. Rec #: 313
205 Midewest Bioethics Center. Health care treatment decision-making guidelines for minors. Midwest Bioethics Center. Rec #: 711
206 Miller E. H, Belgrade M. J, Cook M, Portu J. B, Shepherd M, Sierzant T, Sallmen P, Fraki S. Institutionwide pain management improvement through the use of evidence-based content, strategies, resources, and outcomes. Qual Manag Health Care. Winter. 1999;7(2):28-40. Rec #: 279. [pmid: 10346460].
207 Mitchell, S. L. and Kiely, D. K. (Division of Geriatrics, Loeb Health Research Institute, Ottawa Hospital,University of Ottawa, Ottawa, Ontario.). A cross-national comparison of institutionalized tube-fedolder persons: the influence of contrasting healthcare systems. Journal of the American MedicalDirectors Association. 2001 Jan-2001 Feb 28; 2(1):10–4.Rec #: 568
208 Morita T, Hirai K, Sakaguchi Y, Maeyama E, Tsuneto S, Shima Y. Measuring the quality of structure and process in end-of-life care from the bereaved family perspective. J Pain Symptom Manage. Jun. 2004;27(6):492-501. Rec #: 392. [pmid: 15165647].
209 Morrison, R. S, Siu A. L, Leipzig R. M, Cassel C. K, Meier D. E. The hard task of improving the quality of care at the end of life. Arch Intern Med. Mar 27. 2000;160(6):743-7. Rec #: 13876. [pmid: 10737273].
210 Murdaugh, C.; Parsons, M.; Gryb-Wysocki, T.; Palmer, J.; Glasby, C.; Bonner, J., and Tavakoli, A. (College of Nursing, University of South Carolina.). Implementing a quality of care model in a restructured hospital environment. National Academies of Practice Forum: Issues in Interdisciplinary Care (NAPF). 1999 Jul; 1(3):219–26. Rec #: 342
211 Mystakidou K, Parpa E, Tsilika E, Katsouda E, Kouloulias V, Kouvaris J, Georgaki S, Vlahos L. Pain management of cancer patients with transdermal fentanyl: A study of 1828 step I, II, & III transfers. J Pain. Mar. 2004;5(2):119-32. Rec #: 360. [pmid: 15042520].
212 National Comprehensive Cancer Network (NCCN). Cancer pain. Clinical Practice Guidelines in Oncology. 2004(1). Rec #: 108
213 National Comprehensive Cancer Network (NCCN). Central nervous system cancers. National Comprehensive Cancer Network; 2005 Jan 1(Practice Guidelines in Oncology; version 1.2204 ). Rec #: 662
214 National Comprehensive Cancer Network (NCCN). Chronic Myelogenous Leukemia. National Comprehensive Cancer Network (NCCN); 2004 Nov 23(Practice Guidelines in Oncology; version 2.2005). Rec #: 664
215 National Comprehensive Cancer Network (NCCN). Gastric cancer. National Comprehensive Cancer Network; 2005 Jan 12(Practice Guidleines in Oncology; version 1.2005). Rec #: 667
216 National Comprehensive Cancer Network (NCCN). Kidney cancer. National Comprehensive Cancer Network; 2005 Feb 7(Practice Guidelines in Oncology; version 2.2005). Rec #: 671
217 National Comprehensive Cancer Network (NCCN). Multiple Myeloma. National Comprehensive Cancer Network; 2004 Nov 1(Practice Guidelines in Oncology; version 1.2005). Rec #: 674
218 National Comprehensive Cancer Network (NCCN). Senior adult oncology. Clinical Practice Guidelines in Oncology. 2004(1). Rec #: 107
219 National Institute for Clinical Excellence. Improving outcomes in breast cancer manual update. London: National Institute for Clinical Excellence; 2002 Aug(Guidance on Cancer Services). Rec #: 171
220 National Institute for Clinical Excellence. Improving outcomes in colorectal cancers manual update. London: National Institute for Clinical Excellence; 2004 May(Guidance on Cancer Services). Rec #: 172
221 National Pharmaceutical Council, Inc. NPC and Joint Commission on Accreditation of Healthcare Organizations (JCAHO). Pain: current understanding of assessment, management and treatments. 2001 Dec. Rec #: 746
222 Nicholson, A. B. Methadone for cancer pain. Cochrane Database Syst Rev. 2004; (2):CD003971. Rec #: 231
223 Norris P. Discontinuing life support in the midst of doubt. Health Care Ethics USA. Spring. 1996;4(2):4-5. Rec #: 538.
224 Nowels D, Lee JT. Cancer pain management in home hospice settings: a comparison of primary care and oncologic physicians. J Palliat Care. Autumn. 1999;15(3):5-9. Rec #: 361. [pmid: 10540791].
225 O'Driscoll M, Corner J, Bailey C. The experience of breathlessness in lung cancer. Eur J Cancer Care (Engl). Mar. 1999;8(1):37-43. Rec #: 453. [pmid: 10362952].
226 O'Shea, E. M.; Penson, R. T.; Stern, T. A.; Younger, J.; Chabner, B. A., and Lynch, T. J. Jr. (Hematology-Oncology Department, Massachusetts General Hospital Cancer Center, Boston, MA.). Schwartz Center rounds. A staff dialogue on do not resuscitate orders: psychosocial issues faced by patients, their families, and caregivers. Oncologist. 1999 Jul; 4(3):256–62. Rec #: 586
227 Oliver, D. P.; Porock, D., and Zweig, S. End-of-life care in U.S. nursing homes: a review of the evidence. J Am Med Dir Assoc. 2004 May-2004 Jun 30; 5(3):147–55. Rec #: 515
228 Oncology Nursing Society. Cancer pain management; 2004 Oct(Oncology Nursing Society Position). Rec #: 134
229 Osse B. H, Vernooij M. J, Schade E, Grol R. P. Towards a new clinical tool for needs assessment in the palliative care of cancer patients: the PNPC instrument. J Pain Symptom Manage. Oct. 2004;28(4):329-41. Rec #: 227. [pmid: 15471650].
230 Owen, J. E.; Klapow, J. C.; Hicken, B., and Tucker, D. C. Psychosocial interventions for cancer: review and analysis using a three-tiered outcomes model. Psychooncology. 2001 May-2001 Jun 30; 10(3):218–30. Rec #: 420
231 Pacala J. T, Kane R. L, Atherly A. J, Smith M. A. Using structured implicit review to assess quality of care in the Program of All-Inclusive Care for the Elderly (PACE). J Am Geriatr Soc. Aug. 2000;48(8):903-10. Rec #: 636. [pmid: 10968293].
232 Paice, J. A.; Toy, C., and Shott, S. (Department of Neurosurgery, Rush Medical Center, 1725 West Harrison Street, Suite 755, Chicago, IL 60612.). Barriers to cancer pain relief: fear of tolerance and addiction. Journal of Pain and Symptom Management. 1998 Jul; 16(1):1–9. Rec #: 349
233 Palliative Care and Ethics Committees. Do not resusciate orders. Guidelines for Physician Staff Froedtert Hospital, Milwaukee, Wisconsin:1–5. Rec #: 138
234 Palliative Care and Ethics Committees. Managing conflicts concerning requests to withhold or withdraw life-sustaining medical treatment. Guidelines for Physician Staff Froedtert Hospital, Milwaukee, Wisconsin:1–5. Rec #: 137
235 Palliative Care Committee. Use of pentobarbital for total sedation and ventilator withdrawal. Guidelines for Physicia Staff Froedtert Hospital, Milwaukee, Wisconsin:1–3. Rec #: 135
236 Pasacreta, J. V. (Associate Professor, Yale University School of Nursing, New Haven, Connecticut.). Review: psychoeducational interventions reduce depressive symptoms in cancer. Evidence-Based Nursing. 2002 Oct; 5(4):113. Rec #: 398
237 Passik S. D, Dugan W, McDonald M. V, Rosenfeld B, Theobald D. E, Edgerton S. Oncologists' recognition of depression in their patients with cancer. J Clin Oncol. Apr. 1998;16(4):1594-600. Rec #: 438. [pmid: 9552071].
238 Passik, S. D.; Kirsh, K. L.; Theobald, D.; Donaghy, K.; Holtsclaw, E.; Edgerton, S., and Dugan, W. (Symptom Management and Palliative Care Program, University of Kentucky College of Medicine, 800 Rose Street, Lexington, KY 40536-0093.). Use of a depression screening tool and a fluoxetinebased algorithm to improve the recognition and treatment of depression in cancer patients: a demonstration project. Journal of Pain and Symptom Management. 2002 Sep; 24(3):318–27. Rec #: 399
239 Patrick, D. L.; Ferketich, S. L.; Frame, P. S.; Harris, J. J.; Hendricks, C. B.; Levin, B.; Link, M. P.; Lustig, C.; McLaughlin, J.; Ried, L. D.; Turrisi, A. T. 3rd; Unutzer, J., and Vernon, S. W. National Institutes of Health State-of-the-Science Conference Statement: Symptom Management in Cancer: Pain, Depression, and Fatigue, July 15-17, 2002. J Natl Cancer Inst. 2003 Aug 6; 95(15):1110–7.Rec #: 245
240 Patrick D. L, Pearlman R. A, Starks H. E, Cain K. C, Cole W. G, Uhlmann R. F. Validation of preferences for life-sustaining treatment: implications for advance care planning. Ann Intern Med. Oct 1. 1997;127(7):509-17. Rec #: 5877. [pmid: 9313018].
241 Payne R. Practice guidelines for cancer pain therapy. Issues pertinent to the revision of national guidelines. Oncology (Huntingt). Nov. 1998;12(11A):169-75. Rec #: 284. [pmid: 10028511].
242 Percy, M. E. and Llewellyn-Thomas, H. Assessing preferences about the DNR order: does it depend on how you ask? Med Decis Making. 1995 Jul-1995 Sep 30; 15(3):209–16. Rec #: 616
243 Phillips R. S, Wenger N. S, Teno J, Oye R. K, Youngner S, Califf R, Layde P, Desbiens N, Connors A. F Jr, Lynn J. Choices of seriously ill patients about cardiopulmonary resuscitation: correlates and outcomes. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. Am J Med. Feb. 1996;100(2):128-37. Rec #: 612. [pmid: 8629646].
244 Phipps E. J, True G, Murray G. F. Community perspectives on advance care planning: report from the Community Ethics Program. J Cult Divers. Winter. 2003;10(4):118-23. Rec #: 6016. [pmid: 15000054].
245 Portenoy, R. K. and Itri, L. M. (Department of Pain Medicine and Palliative Care, Beth Israel Medical Center, New York, NY 10003; e-mail: RPortenoy@BethIsraelNY.org.). Cancer-related fatigue: guidelines for evaluation and management. Oncologist. 1999; 4(1):1–10. Rec #: 412
246 Prendergast T. J. Advance care planning: pitfalls, progress, promise. Crit Care Med. Feb. 2001;29(2 Suppl):N34-9. Rec #: 555. [pmid: 11228571].
247 Program in Evidence-Based Care. Radiopharmaceuticals for the palliation of painful bone metastases. Practice Guideline Report #14-1. Program in Evidence-Based Care; 2004 Jun 15(Cancer Care ONtario Practice Guidelines Initiative). Rec #: 206
248 Puchalski C. M, Zhong Z, Jacobs M. M, Fox E, Lynn J, Harrold J, Galanos A, Phillips R. S, Califf R, Teno J. M. Patients who want their family and physician to make resuscitation decisions for them: observations from SUPPORT and HELP. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. Hospitalized Elderly Longitudinal Project. J Am Geriatr Soc. May. 2000;48(5 Suppl):S84-90. Rec #: 569. [pmid: 10809461].
249 Quigley, C. Hydromorphone for acute and chronic pain. Cochrane Database Syst Rev. 2002; (1):CD003447. Rec #: 257
250 Quigley C, Wiffen P. A. systematic review of hydromorphone in acute and chronic pain. Journal of Pain & Symptom Management. 2003;25(2):169-78. Rec #: 369. [pmid: 12590032].
251 Ramsey, G. and Mitty, E. L. Advance directives: protecting patient's rights. Mezey, M.; Fulmer, T.; Abraham, I., and Zwicker, D. A. Geriatric nursing protocols for best practice. New York (NY): Springer Publishing Company, Inc.; 2003; pp. 265–291. Rec #: 649
252 Ratanatharathorn V, Powers W. E, Moss W. T, Perez C. A. Bone metastasis: review and critical analysis of random allocation trials of local field treatment. Int J Radiat Oncol Biol Phys. Apr 1. 1999;44(1):1-18. Rec #: 283. [pmid: 10219789].
253 Ratner E, Norlander L, McSteen K. Death at home following a targeted advance-care planning process at home: the kitchen table discussion. J Am Geriatr Soc. Jun. 2001;49(6):778-81. Rec #: 6278. [pmid: 11454117].
254 Redman B. K. Ethical issues in the development and use of guidelines for clinical practice. J Clin Ethics. Fall. 1996;7(3):251-6. Rec #: 295. [pmid: 8981196].
255 Reifel, J. Cancer pain and palliation. Asch, S. M.; Kerr, E. A.; Hamilton, E. G.; Reifel, J. L., and McGlynn, E. A. Quality of care for oncologic condition and HIV: a review of the literature and quality indicators. RAND; 2000; pp. 227–33. Rec #: 656
256 Reifel, J. L. Lung cancer. Asch, S. M.; Kerr, E. A.; Hamilton, E. G.; Reifel, J. L., and McGlynn, E. A. Quality of care for oncologic condition and HIV: a review of the literature and quality indicators. RAND; 2000; pp. 133–71. Rec #: 657
257 Reilly B. M, Wagner M, Magnussen C. R, Ross J, Papa L, Ash J. Promoting inpatient directives about life-sustaining treatments in a community hospital. Results of a 3-year time-series intervention trial. Arch Intern Med. Nov 27. 1995;155(21):2317-23. Rec #: 614. [pmid: 7487256].
258 Renal Physicians Association. Shared decision-making in the appropriate initiation of and withdrawal from dialysis: Renal Physicians Association and American Society of Nephrology; 2000 Feb(Clinical Practice Guideline; 2). Rec #: 751
259 Rischer J. B, Childress S. B. Cancer pain management: pilot implementation of the AHCPR guideline in Utah. Jt Comm J Qual Improv. Oct. 1996;22(10):683-700. Rec #: 293. [pmid: 8923168].
260 Rita, J. Palliative treatment of cancer. Duodecim Medical Publications Ltd.; 2003 May 30(EBM Guidelines). Rec #: 644
261 Roos D. E. Continuing reluctance to use single fractions of radiotherapy for metastatic bone pain: an Australian and New Zealand practice survey and literature review. Radiother Oncol. Sep. 2000;56(3):315-22. Rec #: 273. [pmid: 10974380].
262 Roque, M.; Martinez, M. J.; Alonso-Coello, P.; Catala, E. ; Garcia, J. L., and Ferrandiz, M. Radioisotopes for metastatic bone pain. The Cochrane Library, (Oxford) ** (4)2004. 2004; (ID #CD003347). Rec #: 320
263 Roque, M.; Martinez, M. J.; Alonso, P.; Catala, E.; Garcia, J. L., and Ferrandiz, M. Radioisotopes for metastatic bone pain. Cochrane Database Syst Rev. 2003; (4):CD003347. Rec #: 239
264 Rosenfeld K, Wenger N. S. (Dept of General Medicine (111G), VA Greater Los Angeles Healthcare System, 11301 Wilshire Blvd., Los Angeles, CA 90012.). Measuring quality in end-of-life care. Clinics in Geriatric Medicine. May. 2000;16(2):387-400. Rec #: 576. [pmid: 10783435].
265 Rosenfeld K. E, Wenger N. S, Phillips R. S, Connors A. F, Dawson N. V, Layde P, Califf R. M, Liu H, Lynn J, Oye R. K. Factors associated with change in resuscitation preference of seriously ill patients. The SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. Arch Intern Med. Jul 22. 1996;156(14):1558-64. Rec #: 610. [pmid: 8687264].
266 Roter, D. L.; Larson, S.; Fischer, G. S.; Arnold, R. M., and Tulsky, J. A. Experts practice what they preach: A descriptive study of best and normative practices in end-of-life discussions. Arch Intern Med. 2000 Dec 11-2000 Dec 25; 160(22):3477–85. Rec #: 6541
267 Roth A. J, Kornblith A. B, Batel-Copel L, Peabody E, Scher H. I, Holland J. C. Rapid screening for psychologic distress in men with prostate carcinoma: a pilot study. Cancer. May 15. 1998;82(10):1904-8. Rec #: 437. [pmid: 9587123].
268 Rustoen T, Fossa S. D, Skarstein J, Moum T. (Oslo University College, Faculty of Nursing, Falbesgt 5, 0167 Oslo, Norway.). The impact of demographic and disease-specific variables on pain in cancer patients. Journal of Pain and Symptom Management. Aug. 2003;26(2):696-704. Rec #: 331. [pmid: 12906954].
269 Saliba D, Kington R, Buchanan J, Bell R, Wang M, Lee M, Herbst M, Lee D, Sur D, Rubenstein L. (Geriatric Research Education and Clinical Center, VA Greater Los Angeles Health Care System, CA.). Appropriateness of the decision to transfer nursing facility residents to the hospital. Journal of the American Geriatrics Society. Feb. 2000;48(2):154-63. Rec #: 581. [pmid: 10682944].
270 Saliba, D.; Solomon, D.; Rubenstein, L.; Young, R.; Schnelle, J.; Roth, C., and Wenger, N. Quality indicators for the management of medical conditions in nursing home residents. J Am Med Dir Assoc. 2004 Sep-2004 Oct 31; 5(5):297–309. Rec #: 625
271 Santa-Emma P. H, Roach R, Gill M. A, Spayde P, Taylor R. M. Development and implementation of an inpatient acute palliative care service. Journal of Palliative Medicine. 2002;5(1):93-100. Rec #: 370. [pmid: 11839231].
272 Sarna L. Effectiveness of structured nursing assessment of symptom distress in advanced lung cancer. Oncol Nurs Forum. Jul. 1998;25(6):1041-8. Rec #: 435. [pmid: 9679262].
273 Schmidt K. L, Alpen M. A, Rakel B. A. Implementation of the Agency for Health Care Policy and Research Pain Guidelines. AACN Clin Issues. Aug. 1996;7(3):425-35. Rec #: 294. [pmid: 8826404].
274 Schonwetter R. S, Walker R. M, Solomon M, Indurkhya A, Robinson B. E. Life values, resuscitation preferences, and the applicability of living wills in an older population. J Am Geriatr Soc. Aug. 1996;44(8):954-8. Rec #: 609. [pmid: 8708307].
275 Schwartz C. E, Merriman M. P, Reed G. W, Hammes B. J. Measuring patient treatment preferences in end-of-life care research: applications for advance care planning interventions and response shift research. J Palliat Med. Apr. 2004;7(2):233-45. Rec #: 514. [pmid: 15130201].
276 Scottish Intercollegiate Guidelines Network (SIGN) and Scottish Cancer Therapy Network. Control of pain in patients with cancer. 2000. Rec #: 717
277 Sheard T, Maguire P. The effect of psychological interventions on anxiety and depression in cancer patients: results of two meta-analyses. Br J Cancer. Aug. 1999;80(11):1770-80. Rec #: 430. [pmid: 10468295].
278 Shega J. W, Levin A, Hougham G. W, Cox-Hayley D, Luchins D, Hanrahan P, Stocking C, Sachs G. A. Palliative Excellence in Alzheimer Care Efforts (PEACE): a program description. J Palliat Med. Apr. 2003;6(2):315-20. Rec #: 50732. [pmid: 12854952].
279 Silvestri G. A. Palliation for the dying patient with lung cancer. Respir Care. Dec. 2000;45(12):1490-6. discussion 1497–500. Rec #: 220. [pmid: 11107215].
280 Sloan P. A, Vanderveer B. L, Snapp J. S, Johnson M, Sloan D. A. (Department of Anesthesiology, University of Kentucky Hospital, 800 Rose St., Lexington, KY 40536.). Cancer pain assessment and management recommendations by hospice nurses. Journal of Pain and Symptom Management. Aug. 1999;18(2):103-10. Rec #: 344. [pmid: 10484857].
281 Smith, E. L, Whedon M. B, Bookbinder M. (Dartmouth-Hitchcock Medical Center/Norris Cotton Cancer Center, One Medical Center Dr, Lebanon, NH 03756.). Quality improvement of painful peripheral neuropathy. Seminars in Oncology Nursing. Feb. 2002;18(1):36-43. Rec #: 312. [pmid: 11878038].
282 Somogyi-Zalud E, Zhong Z, Hamel M. B, Lynn J. The use of life-sustaining treatments in hospitalized persons aged 80 and older. J Am Geriatr Soc. May. 2002;50(5):930-4. Rec #: 531. [pmid: 12028183].
283 Somogyi-Zalud E, Zhong Z, Lynn J, Hamel M. B. Elderly persons' last six months of life: findings from the Hospitalized Elderly Longitudinal Project. J Am Geriatr Soc. May. 2000;48(5 Suppl):S131-9. Rec #: 7221. [pmid: 10809466].
284 Song, M. K. Effects of end-of-life discussions on patients' affective outcomes. Nurs Outlook. 2004 May-2004 Jun 30; 52(3):118–25. Rec #: 510
285 Sorenson H. M. Dyspnea assessment. Respir Care. Nov. 2000;45(11):1331-8. discussion 1338–41. Rec #: 210. [pmid: 11063521].
286 Sorenson H. M. Managing secretions in dying patients. Respir Care. Nov. 2000;45(11):1355-63. discussion 1363–4. Rec #: 212. [pmid: 11063523].
287 Spector N, Klein D. (Assistant Professor, Loyola University, 6525 N Sheridan Road, Chicago, IL 60626.). Chronic critically ill dyspneic patients: mechanisms and clinical measurement. AACN Clinical Issues: Advanced Practice in Acute and Critical Care. May. 2001;12(2):220-33. Rec #: 383.
288 Srebnik, D.; Appelbaum, P. S., and Russo, J. Assessing competence to complete psychiatric advance directives with the competence assessment tool for psychiatric advance directives. Compr Psychiatry. 2004 Jul-2004 Aug 31; 45(4):239–45. Rec #: 508
289 Stein W. M, Miec R. P. Cancer pain in the elderly hospice patient. J Pain Symptom Manage. Oct. 1993;8(7):474-82. Rec #: 362. [pmid: 7963774].
290 Sterman, E.; Gauker, S., and Krieger, J. (Clinical Nurse Specialist, Newark Beth Israel Medical Center, New Jersey; eers619@aol.com.). A comprehensive approach to improving cancer pain management and patient satisfaction. Oncology Nursing Forum. 2003 Sep-2003 Oct 31; 30(5):857–64. Rec #: 323
291 Stiefel R, Die Trill M, Berney A, Olarte J. M, Razavi A. Depression in palliative care: a pragmatic report from the Expert Working Group of the European Association for Palliative Care. Support Care Cancer. Oct. 2001;9(7):477-88. Rec #: 725. [pmid: 11680829].
292 Strasser F, Sweeney C, Willey J, Benisch-Tolley S, Palmer J. L, Bruera E. Impact of a half-day multidisciplinary symptom control and palliative care outpatient clinic in a comprehensive cancer center on recommendations, symptom intensity, and patient satisfaction: a retrospective descriptive study. J Pain Symptom Manage. Jun. 2004;27(6):481-91. Rec #: 393. [pmid: 15165646].
293 Straton J. B, Wang N. Y, Meoni L. A, Ford D. E, Klag M. J, Casarett D, Gallo J. J. Physical functioning, depression, and preferences for treatment at the end of life: the Johns Hopkins Precursors Study. J Am Geriatr Soc. Apr. 2004;52(4):577-82. Rec #: 7406. [pmid: 15066074].
294 Stromgren A. S, Goldschmidt D, Groenvold M, Petersen M. A, Jensen P. T, Pedersen L, Hoermann L, Helleberg C, Sjogren P. Self-assessment in cancer patients referred to palliative care: a study of feasibility and symptom epidemiology. Cancer. Jan 15. 2002;94(2):512-20. Rec #: 416. [pmid: 11900236].
295 Stromgren A. S, Groenvold M, Pedersen L, Olsen A. K, Spile M, Sjogren P. (Department of Palliative Medicine, Bispebjerg Hospital, DK-2400 Copenhagen NV, Denmark.). Does the medical record cover the symptoms experienced by cancer patients receiving palliative care? A comparison of the record and patient self-rating. Journal of Pain and Symptom Management. Mar. 2001;21(3):189-96. Rec #: 410. [pmid: 11239737].
296 Stromgren A. S, Groenvold M, Petersen M. A, Goldschmidt D, Pedersen L, Spile M, Irming-Pedersen G, Sjogren P. (Department of Palliative Medicine, Bispebjerg Hospital, DK-2400 Copenhagen NV, Denmark.). Pain characteristics and treatment outcome for advanced cancer patients during the first week of specialized palliative care. Journal of Pain and Symptom Management. Feb. 2004;27(2):104-13. Rec #: 317. [pmid: 15157034].
297 Stromgren A. S, Groenvold M, Sorensen A, Andersen L. Symptom recognition in advanced cancer. A comparison of nursing records against patient self-rating. Acta Anaesthesiol Scand. Oct. 2001;45(9):1080-5. Rec #: 263. [pmid: 11683656].
298 Sulmasy D. P, Dwyer M, Marx E. Do the ward notes reflect the quality of end-of-life care?. J Med Ethics. Dec. 1996;22(6):344-8. Rec #: 15638. [pmid: 8961119]. [pmcid: 1377116].
299 Sulmasy D. P, McIlvane J. M. Patients' ratings of quality and satisfaction with care at the end of life. Arch Intern Med. Oct 14. 2002;162(18):2098-104. Rec #: 7440. [pmid: 12374518].
300 Sulmasy D. P, Sood J. R, Ury W. A. The quality of care plans for patients with do-not-resuscitate orders. Arch Intern Med. Jul 26. 2004;164(14):1573-8. Rec #: 504. [pmid: 15277292].
301 Sulmasy Daniel P, McIlvane Jessica M, Pasley Peter M, Rahn Maike. A scale for measuring patient perceptions of the Quality of End-of-Life Care and Satisfaction with Treatment: The reliability and validity of QUEST. Journal of Pain & Symptom Management. 2002;23(6):458-470. http //www.elsevier.com/inca/publications/store/5/0/5/7/7/5/ Rec #: 492. [pmid: 12067770].
302 Sze W. M, Shelley M. D, Held I, Wilt T. J, Mason M. D. Palliation of metastatic bone pain: single fraction versus multifraction radiotherapy--a systematic review of randomised trials. Clin Oncol (R Coll Radiol). Sep. 2003;15(6):345-52. Rec #: 240. [pmid: 14524489].
303 Tarzian, A. J. and Hoffmann, D. E. Barriers to managing pain in the nursing home: findings from a statewide survey. J Am Med Dir Assoc. 2004 Mar-2004 Apr 30; 5(2):82–8. Rec #: 235
304 Tattersall MH, Gattellari M, Voigt K, Butow PN. When the treatment goal is not cure: are patients informed adequately?. Support Care Cancer. May. 2002;10(4):314-21. Rec #: 7561. [pmid: 12029431].
305 Teno, J.; Lynn, J.; Wenger, N.; Phillips, R. S.; Murphy, D. P.; Connors, A. F. Jr; Desbiens, N.; Fulkerson, W.; Bellamy, P., and Knaus, W. A. Advance directives for seriously ill hospitalized patients: effectiveness with the patient self-determination act and the SUPPORT intervention. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Am Geriatr Soc. 1997 Apr; 45(4):500–7. Comment in: J Am Geriatr Soc. 1997 Apr;45(4):519–20. PMID: 9100724. Rec #: 43327
306 Teno J. M, Branco K. J, Mor V, Phillips C. D, Hawes C, Morris J, Fries B. E. (Center for Gerontology and Health Care Research, Brown University, Providence, RI.). Changes in advance care planning in nursing homes before and after the Patient Self-Determination Act: report of a 10-state survey. Journal of the American Geriatrics Society. Aug. 1997;45(8):939-44. Rec #: 592. [pmid: 9256845].
307 Teno J. M, Clarridge B, Casey V, Edgman-Levitan S, Fowler J. Validation of Toolkit After-Death Bereaved Family Member Interview. J Pain Symptom Manage. Sep. 2001;22(3):752-8. Rec #: 7592. [pmid: 11532588].
308 Teno J. M, Kabumoto G, Wetle T, Roy J, Mor V. Daily pain that was excruciating at some time in the previous week: prevalence, characteristics, and outcomes in nursing home residents. J Am Geriatr Soc. May. 2004;52(5):762-7. Rec #: 234. [pmid: 15086658].
309 The International Psychooncology Society (IPOS). Psychosocial component in cancer control. 2004 Aug. Rec #: 488
310 The Robert Wood Johnson Foundation. Completing the continuum of ALS care: a consensus document: The Robert Wood Johnson Foundation; 2004 Jan(Promoting Excellence in End-of-Life Care). Rec #: 752
311 Tilden V. P, Tolle S. W, Drach L. L, Perrin N. A. Out-of-hospital death: advance care planning, decedent symptoms, and caregiver burden. J Am Geriatr Soc. Apr. 2004;52(4):532-9. Rec #: 7664. [pmid: 15066067].
312 Tilden, V. P.; Tolle, S. W.; Nelson, C. A., and Fields, J. Family decision-making to withdraw life-sustaining treatments from hospitalized patients. Nurs Res. 2001 Mar-2001 Apr 30; 50(2):105–15.Rec #: 50907
313 Todd J, Edmonds P. Caring for patients wanting a home death. Practitioner. Jun. 2000;244(1611):580-6. Rec #: 15873. [pmid: 10962851].
314 Tolle S. W, Tilden V. P, Nelson C. A, Dunn P. M. A prospective study of the efficacy of the physician order form for life-sustaining treatment. J Am Geriatr Soc. Sep. 1998;46(9):1097-102. Rec #: 588. [pmid: 9736102].
315 Tolle SW, Rosenfeld AG, Tilden VP, Park Y. Oregon's low in-hospital death rates: what determines where people die and satisfaction with decisions on place of death?. Ann Intern Med. Apr 20. 1999;130(8):681-5. Rec #: 15876. [pmid: 10215565].
316 Tong E, McGraw SA, Dobihal E, Baggish R, Cherlin E, Bradley EH. What is a good death? Minority and non-minority perspectives. J Palliat Care. Fall. 2003;19(3):168-75. Rec #: 15884. [pmid: 14606328].
317 Treadwell M. J, Franck L. S, Vichinsky E. Using quality improvement strategies to enhance pediatric pain assessment. Int J Qual Health Care. Feb. 2002;14(1):39-47. Rec #: 256. [pmid: 11871628].
318 Treece P. D, Engelberg R. A, Crowley L, Chan J. D, Rubenfeld G. D, Steinberg K. P, Curtis J. R. Evaluation of a standardized order form for the withdrawal of life support in the intensive care unit. Crit Care Med. May. 2004;32(5):1141-8. Rec #: 511. [pmid: 15190964].
319 Trowbridge R, Dugan W, Jay S. J, Littrell D, Casebeer L. L, Edgerton S, Anderson J, O'Toole J. B. Determining the effectiveness of a clinical-practice intervention in improving the control of pain in outpatients with cancer. Acad Med. Sep. 1997;72(9):798-800. Rec #: 290. [pmid: 9311323].
320 Truog R. D, Cist A. F, Brackett S. E, Burns J. P, Curley M. A, Danis M, DeVita M. A, Rosenbaum S. H, Rothenberg D. M, Sprung C. L, Webb S. A, Wlody G. S, Hurford W. E. Recommendations for end-of-life care in the intensive care unit: The Ethics Committee of the Society of Critical Care Medicine. Crit Care Med. Dec. 2001;29(12):2332-48. Rec #: 471. [pmid: 11801837].
321 Tulsky J. A, Chesney M. A, Lo B. See one, do one, teach one? House staff experience discussing do-not-resuscitate orders. Arch Intern Med. Jun 24. 1996;156(12):1285-9. Rec #: 15939. [pmid: 8651836].
322 Tulsky J. A, Fischer G. S, Rose M. R, Arnold R. M. Opening the black box: how do physicians communicate about advance directives?. Ann Intern Med. Sep 15. 1998;129(6):441-9. Rec #: 50788. [pmid: 9735081].
323 Uitterhoeve R. J, Vernooy M, Litjens M, Potting K, Bensing J, De Mulder P, van Achterberg T. Psychosocial interventions for patients with advanced cancer - a systematic review of the literature. Br J Cancer. Sep 13. 2004;91(6):1050-62. Rec #: 389. [pmid: 15316564].
324 Vainio A, Auvinen A. (Finnish Cancer Registry, Liisankatu 21B, 00170 Helsinki, Finland.). Prevalence of symptoms among patients with advanced cancer: an international collaborative study. Journal of Pain and Symptom Management. Jul. 1996;12(1):3-10. Rec #: 335. [pmid: 8718910].
325 Vigano A, Bruera E, Suarez-Almazor M. E. Age, pain intensity, and opioid dose in patients with advanced cancer. Cancer. 1998;83(6):1244-50. Rec #: 371. [pmid: 9740092].
326 Volicer L. Management of severe Alzheimer's disease and end-of-life issues. Clin Geriatr Med. May. 2001;17(2):377-91. Rec #: 7946. [pmid: 11375141].
327 Volicer, L.; Hurley, A. C., and Blasi, Z. V. (Clinical Director, Geriatric Research Education Clinical Center, EN Rodgers Memorial Veteans Hospital, Bedford, Massachusetts.). Characteristics of dementia end-of-life care across care settings. American Journal of Hospice and Palliative Care. 240 May-240 Jun 30; 20(3):191–200. Rec #: 553
328 Waldron D, O'Boyle C. A, Kearney M, Moriarty M, Carney D. Quality-of-life measurement in advanced cancer: assessing the individual. J Clin Oncol. Nov. 1999;17(11):3603-11. Rec #: 580. [pmid: 10550160].
329 Wallace J, Desbiens N. A. Evaluation of a labeling system to indicate the presence of an advance directive in a hospital medical record. Int J Qual Health Care. Aug. 2004;16(4):333-5. Rec #: 43541. [pmid: 15252008].
330 Walsh D, Donnelly S, Rybicki L. The symptoms of advanced cancer: relationship to age, gender, and performance status in 1,000 patients. Support Care Cancer. May. 2000;8(3):175-9. Rec #: 426. [pmid: 10789956].
331 Ward S, Donovan M, Max M. B. (University of Wisconsin-Madison, School of Nursing, K6/348, 600 Highland Ave., Madison, WI 53792.). A survey of the nature and perceived impact of quality improvement activities in pain management. Journal of Pain and Symptom Management. Jun. 1998;15(6):365-73. Rec #: 348. [pmid: 9670637].
332 Washington-Alaska Cancer Pain Initiative (WACPI). Joint commission on accreditation of healthcare organizations pain standards for 2001: pain assessment [Web Page]. Accessed 2005 Feb 3. Rec #: 205
333 Weiler, K. and Garand, L. Advance directives. University of Iowa Gerontological Nursing Interventions Research Center (RDC); 1999(Evidence-based protocol). Rec #: 712
334 Wenger N. S, Phillips R. S, Teno J. M, Oye R. K, Dawson N. V, Liu H, Califf R, Layde P, Hakim R, Lynn J. Physician understanding of patient resuscitation preferences: insights and clinical implications. J Am Geriatr Soc. May. 2000;48(5 Suppl):S44-51. Rec #: 8134. [pmid: 10809456].
335 Wenzel L. B, Fairclough D. L, Brady M. J, Cella D, Garrett K. M, Kluhsman B. C, Crane L. A, Marcus A. C. Age-related differences in the quality of life of breast carcinoma patients after treatment. Cancer. Nov 1. 1999;86(9):1768-74. Rec #: 429. [pmid: 10547550].
336 White D. B, Luce J. M. Palliative care in the intensive care unit: barriers, advances, and unmet needs. Crit Care Clin. Jul. 2004;20(3):329-43. , vii. Rec #: 513. [pmid: 15183206].
337 Wiffen, P.; Collins, S.; McQuay, H.; Carroll, D.; Jadad, A., and Moore, A. Anticonvulsant drugs for acute and chronic pain. Cochrane Database Syst Rev. 2000; (3):CD001133. Rec #: 274
338 Wiffen, P.; Collins, S.; McQuay, H.; Carroll, D.; Jadad, A., and Moore, A. Anticonvulsant drugs for acute and chronic pain. The Cochrane Library, (Oxford) ** (4)2004. 2004; (ID #CD001133). Rec #: 318
339 Wolfe J, Klar N, Grier H. E, Duncan J, Salem-Schatz S, Emanuel E. J, Weeks J. C. Understanding of prognosis among parents of children who died of cancer: impact on treatment goals and integration of palliative care. JAMA. Nov 15. 2000;284(19):2469-75. Rec #: 559. [pmid: 11074776].
340 Wong, R. and Wiffen, P. J. Bisphosphonates for the relief of pain secondary to bone metastases. Cochrane Database Syst Rev. 2002; (2):CD002068. Rec #: 254
341 Wong, R. and Wiffen, P. J. Bisphosphonates for the relief of pain secondary to bone metastases. The Cochrane Library, (Oxford) ** (4)2004. 2004; (ID #CD002068). Rec #: 322
342 World Health Organization (WHO). Cancer pain relief: with a guide to opioid availability. 1996. Rec #: 719
343 Worthington, H. V.; Clarkson, J. E., and Eden, O. B. Interventions for treating oral mucositis for patients with cancer receiving treatment. Cochrane Database Syst Rev. 2004; (2):CD001973. Rec #: 233
344 Yurk R, Morgan D, Franey S, Stebner J. B, Lansky D. Understanding the continuum of palliative care for patients and their caregivers. J Pain Symptom Manage. Nov. 2002;24(5):459-70. Rec #: 8401. [pmid: 12547046].
345 Zabora, J.; BrintzenhofeSzoc, K.; Curbow, B.; Hooker, C., and Piantadosi, S. The prevalence of psychological distress by cancer site. Psychooncology. 2001 Jan-2001 Feb 28; 10(1):19–28. Rec #: 424
346 Zech D. F, Grond S, Lynch J, Hertel D. Lehmann, K. A. Validation of World Health Organization Guidelines for cancer pain relief: a 10-year prospective study. Pain. Oct. 1995;63(1):65-76. Rec #: 300. [pmid: 8577492].
347 Zhukovsky DS, Gorowski E, Hausdorff J, Napolitano B, Lesser M. Unmet analgesic needs in cancer patients. J Pain Symptom Manage. Feb. 1995;10(2):113-9. Rec #: 364. [pmid: 7537317].

## Rejected: Guidelines With No Methiods

1 American Medical Directors Association (AMDA). Pain management in the long-term care setting. Clinical Practice Guideline. 2003. Rec #: 648
2 Caraceni A, Martini C, Zecca E, Portenoy R. K, Ashby M. A, Hawson G, Jackson K. A, Lickiss N, Muirden N, Pisasale M, Moulin D, Schulz V. N, Rico Pazo M. A, Serrano J. A, Andersen H, Henriksen H. T, Mejholm I, Sjogren P, Heiskanen T, Kalso E, Pere P, Poyhia R, Vuorinen E, Tigerstedt I, Ruismaki P, Bertolino M, Larue F, Ranchere J. Y, Hege-Scheuing G, Bowdler I, Helbing F, Kostner E, Radbruch L, Kastrinaki K, Shah S, Vijayaram S, Sharma K. S, Devi P. S, Jain P. N, Ramamani P. V, Beny A, Brunelli C, Maltoni M, Mercadante S, Plancarte R, Schug S, Engstrand P, Ovalle A. F, Wang X, Alves M. F, Abrunhosa M. R, Sun W. Z, Zhang L, Gazizov A, Vaisman M, Rudoy S, Gomez Sancho M, Vila P, Trelis J, Chaudakshetrin P, Koh M. L, Van Dongen R. T, Vielvoye-Kerkmeer A, Boswell M. V, Elliott T, Hargus E, Lutz L. Breakthrough pain characteristics and syndromes in patients with cancer pain. An international survey. Palliat Med. Apr. 2004;18(3):177-83. Rec #: 229. [pmid: 15198130].
3 Jenkins, Catherine, Bruera, Eduardo. Assessment and management of medically ill patients who refuse life-prolonging treatments: Two case reports and proposed guidelines. Journal of Palliative Care. 1998;14(1):18-24. Rec #: 495. [pmid: 9575709].
4 Mahler D. A, Tomlinson D, Olmstead E. M, Tosteson A. N, O'Connor G. T. Changes in dyspnea, health status, and lung function in chronic airway disease. Am J Respir Crit Care Med. Jan. 1995;151(1):61-5. Rec #: 449. [pmid: 7812573].
5 Pain and Palliative Care Committees. Analagesic prescribing guidelines. Guidelines for Physician Staff Froedtert Hospital, Milwaukee, Wisconsin:1–4. Rec #: 131

## Rejected: Duplicate Article

1 Glinder J. G, Persons J. B. (San Francisco Bay Area Center for Cognitive Therapy, Oakland, California.). Review: psychoeducational interventions reduce depressive symptoms in cancer. Evidence-Based Mental Health. Nov. 2002;5(4):105. Rec #: 401. [pmid: 12440441].
2 Wu J. S, Wong R. K, Lloyd N. S, Johnston M, Bezjak T, Whelan T. Radiotherapy fractionation for the palliation of uncomplicated painful bone metastases - an evidence-based practice guideline. Program in Evidence-Based Care: A Cancer Care Ontario Program. Mar. 2003;14:1-25. Rec #: 461.

## Rejected: Useful for Background Only

1 Farrar J. T, Portenoy R. K, Berlin J. A, Kinman J. L, Strom B. L. Defining the clinically important difference in pain outcome measures. Pain. Dec 1. 2000;88(3):287-94. Rec #: 271. [pmid: 11068116].
2 University of Ottawa Evidence-based Practice Center. Measuring the quality of breast cancer care in women. Agency of Healthcare Research and Quality; 2004 Oct. Rec #: 743