# Appendix G. Peer Reviewer Comments

[underlined: Item] | [underlined: Name] | [underlined: Institution] | [underlined: Role] | - | - | - | -
| | | | [underlined: Page] | [underlined: Section] | [underlined: Comment] | [underlined: Response]
1 | Adalsteinn Brown, AB, D.Phil | University of Toronto | Reviewer | 2 | Introduction | When we review performance measures with complex continuing (chronic) care hospitals and rehabilitation hospitals in Ontario they often ask us to think about measures of caregiver burden and health status. When I read your comments about depression on page 2 and how both patients and care-givers maintain hope, I thought it might be important to point out that measures of how care-givers are doing might be important (at least as predictors of patients' capacities) but that they would be difficult to incorporate into the assessment, treatment, and follow-up paradigm and might be also be subject to a lot of exclusions in measurement. | We agree that measures of caregiver burden are important elements of palliative cancer care not addressed within the scope of the current task order. However, we have been reminded to stress the need to consider these in future work in the Discussion.
2 | Adalsteinn Brown, AB, D.Phil | University of Toronto | Reviewer | | | We have just completed an assessment of recall or reliability in complex continuing care hospital patients in relation to their ability toreport on their perceptions of care. It was awful. But the important thing out of the study was the fact that repeated assessment, in this case by a trained interviewer, actually caused some of the patients anxiety as they worried that they “hadn't gotten it right the first time” or wouldn't be able to answer the same again. I think it might be useful to point out some of the issues associated with repeated measurement that might happen in some surveying programs in chronically ill patients. | Your comment raises the caution that application of measures that require patient report will have to be tested carefully as there are unique challenges given the frailty of the population. We have now emphasized this in our Discussion.
3 | Adalsteinn Brown, AB, D.Phil | University of Toronto | Reviewer | 30 | CCO- Measure | CCO patient satisfaction survey. All the NRC surveys go through a very primitive form of psychometric validation (alpha) before they go into widespread use. I don't know whether you believe the Picker surveys are reflexive surveys or not, but you might want to note that there has been some validation. Also, we have used a cut-off of 100 responses for a long time in Ontario for virtually all our other surveys (for no better reason that than the confidence intervals were reasonable at that point). I wouldn't be surprised that CCO (you note 300 surveys) goes that route shortly as well. We will be publishing two papers on oncology satisfaction shortly (one has been accepted at Annals of Oncology and the other is under revision) but I do not believe they will be of much use to you. Let me know if you want to see them confidentially regardless. | We have now noted this in the text discussion of the measure- thank you.
6 | Ellen Stovall, PhD/ Mark Gorman | National Coalition for Cancer Survivorship (NCCS) | Reviewer | | Stage of Illness | Evidence discussed is derived from end of life, hospice or a narrowly defined “palliative” stage of a cancer patient's illness. Numerous IOM evidence-based findings point out, cancer patients need comprehensive symptom management at all phases of their treatment beginning with their diagnosis and continuing throughout the remainder of their lives. | We raise this concern in the introduction, although it is true that many measures do not speak to earlier stages of illness explicitly. We have emphasized this shortcoming in the Discussion.
7 | Ellen Stovall, PhD/ Mark Gorman | National Coalition for Cancer Survivorship (NCCS) | Reviewer | | Settings of Care | Many measures discussed in this report are derived from an inpatient setting and some are derived from the highly specialized setting of an ICU. A majority of US cancer patients are treated in ambulatory settings, and most of those are treated completely outside a hospital setting in private community oncology practices. Therefore, there is a need for development of measures and indicators relevant to physician office settings where most of cancer care is provided. | We now raise this issue in the Discussion.
8 | Ellen Stovall, PhD/ Mark Gorman | National Coalition for Cancer Survivorship (NCCS) | Reviewer | | Sources | One source of data that does not appear, namely information from the 60 NCI designated cancer centers. Most if not all of these centers have formal guidelines pertaining to at least some of the domains dealt with in this report. | While we reviewed the NCCN guidelines, these recommendations unfortunately did not meet our standard of being able to be operationalized.
9 | Ellen Stovall, PhD/ Mark Gorman | National Coalition for Cancer Survivorship (NCCS) | Reviewer | | Task Order | Processes vs. Outcomes: Task order for this study directed a focus on processes, from the patient's perspective outcomes are more important. While it is useful that the study has included some outcome measures for “completeness,” assigning such secondary importance to outcomes measures represents a misplacement of priorities. Particularly in the domains of symptom management, which so dramatically impact a cancer patient's quality of life, having good measures of whether particular interventions are resulting in better patient outcomes is vital. | We agree that the process-outcome link is a critical assumption. We have not commented directly on that issue here, although you have reminded us to raise it in our conceptual discussion.
10 | Ellen Stovall, PhD/ Mark Gorman | National Coalition for Cancer Survivorship (NCCS) | Reviewer | | Overall | Progress in setting quality measures fro cancer will need to focus on both process and patient outcomes, be based on the real world settings where most of cancer care is provided, and be applicable to all stages of patient's treatment. | We acknowledge that evaluation of process measurement implementation should include validation of the effects on patient and caregiver outcomes.
11 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | 10 | Methods | Search strategy: what was the rationale for starting the search in 1995? Some justification is warranted. | Our prior experience with the topic of palliative care and quality indicators suggested that relevant literature would be found in the past decade. Empirically, Shekelle et.al., have found that the lifetime of guidelines in general is ~3 years.
12 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | 16 | Results | re statement on ORYX, JCAHO, NCQA - should you at least include them in Table 1? | We decided not to include them since we did not abstract these measures or indicators.
13 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | 18 | Table 1 | Description of CCNS qualitative phase - the most important component of this phase is the focus groups with patients with metastatic cancer and bereaved caregivers, and the modified Delphi process with health care providers (oncologists, palliative care physicians, cancer nurses, social workers, community family physicians) to determine their views on the 19 quality indicators being measured in the quantitative component of the study. You may want to add this to your description of the qualitative phase of this project. (NB: These have now all been conducted and analysis is nearing completion.) | Thank you - we have amended this description.
14 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | 28 | Pain | re: treatment for painful bony metastases. We have now examined this indicator both in terms of its acceptability to stakeholders (i.e., through the Delphi with health care providers) and through attempting to calculate it using administrative datasets. Based on these two processes, it is now clear that we will not adopt this as a useful QI despite the evidence that it is an effective treatment. The primary difficulty is that we are not able to measure when the pain is no longer controlled by medications and requires radiotherapy. The one week window was considered appropriate by the stakeholder group but they did not agree with our denominator for the same reason given above. | Thank you - we have amended information about this indicator.
15 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | 46–50 | ACP | the measures included here (those used by Dana Farber and CCNS) do not appropriately fit under ACP since they do not measure when these aspects of care are in keeping with the patients'/caregivers' preferences. In fact, in our Delphi process the principal objection was that measuring these indictors in isolation of knowledge of patients' preferences does not necessarily reflect good quality of care. | You have pointed out an important limitation of these indicators and we have noted it. At the same time, it is not clear that they should not be included for completeness sake. We felt that it was reasonable to consider treatments or healthcare utilization under care planning since much of the literature on care planning focuses on utilization outcomes and their avoidance (e.g., resuscitation) or facilitation (e.g., hospice use) through care planning. Indeed, others might have made a reasonable decision to exclude them.
16 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | 54, Para1 | ACP | I think this is a very important point. Where are these indictors being used to actually improve quality of care? | We agree that this is important. Unfortunately, we found little evidence related to actual current use of these indicators. Where we did find such information it is discussed in the Results.
17 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | Appendix | Reviewer list | Please note the correction to your reviewer list: Dr. Grunfeld, MD, DPhil | Done
18 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | Depression | Consideration might be given to include an indicator for screening/treatment of depression in caregivers | See response to Item #1
19 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | Title | I find the title not sufficiently specific. Suggest either end-of-life cancer measures (as originally termed) or measures of cancer symptom management. | We changed the title to reflect the task order.
20 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | | In some instances you discuss the issue of benchmarking which essentially aims to define how one concludes whether an institution/organization/region is doing a good job. When is it enough, when is it too much, or too little? A general discussion about this point and potential approaches to benchmarking would enhance the usefulness of the report. | Unless it is used in reference to a specific project or title, we have eliminated use of the term ‘benchmarking’ since our report is spherically addressing quality performance and we find more specific terminology more helpful, in general.
21 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | Suggestions | Perhaps a table summarizing those indicators you conclude are most helpful could be added. | While it was out of scope for us to make specific recommendations about preferred measures or indicators, we did try to provide similar information about their attributes for the comparability of readers.
22 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | Evidence Tables | Tables - description of CCNS indictors: For all indicators - Patient characteristics should read “all patients in the population with cancer”. The data sources are: cancer registry, administrative claims data, hospital discharge abstracts. | We have amended these descriptions.
23 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | Chapter 4 | The major gap is raised by your statement in the first paragraph of Chapter 4: where is the evidence that quality measures are actually being used to measure and promote quality of care. Two possible examples are the National Comprehensive Cancer Network (Weeks et al) which uses a measurement and feedback system with the goal of improving adherence to guidelines (as a process measure of quality of care); and the Cancer Care Ontario quality initiative (your references 54, 113 and 114).. | We highlight these examples in the Discussion.
24 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | Measurement tools and data capture methods. | The principal point of QIs is that they are measurable. The report does not specifically discuss the issue of measurement instruments (for example, is asking the patient if they have pain equal in value to using a validated pain assessment tool?) or data capture methods (chart abstraction vs prospective data capture using validate instruments vs administrative datasets). There is a general discussion within the text of some of the QIs but no overarching discussion. The validity, reliability and feasibility of measuring QIs will vary with each of the different data capture techniques and their useful is contingent on how the data is captured and how accessible it is to use. Just to give one example, the QI ‘effective treatment of pain’ (p.81). The denominator for this indicator is “number of cancer patients who are not comatose”. The rationale for this definition is self-evident. However, precisely how an institution would capture the information is questionable. Institutions may be able to know precisely how many cancer patients they see in a given period of time. They are much less likely to be able to subtract from the denominator the number that are comatose (or, at least not without a detailed chart review). Hence the value of the intended precision of this QI is reduced by the difficulty of actually capturing the data. | We have amended the Discussion to include these limitations of the descriptions. Unfortunately, a higher level of description was not possible for these indicators - either because it was unpublished and / or it was not provided by developers.
25 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | Scope of the report | The questions posed in the task order indicate that the scope of the report is at any point of the cancer trajectory (i.e., not just end-of-life). This is a very wide scope. However, the review seems to focus on end-of-life/palliative care (EOL/PC). For example the majority of the indicator sets you have identified relate to EOL/PC. This raises some confusion in my mind whether the broader scope is being adequately addressed or whether, in fact, it is the narrower scope that is really intended for the report. If EOL/PC really is the focus, it should be specified clearly (for example, in the title of the report). If it is intended to be the entire cancer trajectory then the other periods (e.g., diagnosis, treatment, and survivorship) have not be adequately addressed or a statement should be made that no quality indicators (QIs) were identified for these periods. | See response to Item #6
26 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | | While a comprehensive discussion about measurement is probably beyond the scope of the task order, you do touch on it in a general way on pages 54–55. I think the usefulness of the report would be enhanced by a slightly more detailed discussion about measurement within each of the domains. | We have expanded on generic challenges related to measurement as suggested.
27 | Eva Grunfeld, MD, Dphil | Cancer Care Nova Scotia | Reviewer | | Suggestions | You identify many of the indicators as ‘not in current use’. A separate table listing those indicators that are currently being used would be helpful | For brevity's sake, we decided not to provide an additional table, although we have provided this information in the report.
28 | Joanne Wolfe, MD, MPH | Harvard University-Pediatrics | Reviewer | 11 | Methods | With regard to the Grey Literature - Internet Search the following sites could have also been included: | We did review the APON guidelines but they did not meet our definitions as indicators or measures. We requested a reviewer from ASPHO but there was no response from several inquiries with the organization. We acknowledge that we did not access some of the other sources, although we should have identified published information about indicators or measures promulgated by these organizations.
| | | | | | American Society of Pediatric Hematology/Oncology www.aspho.org
| | | | | | The Association for Children with Life-Threatening or Terminal Conditions and
| | | | | | Their Families (ACT) www.act.org.uk
| | | | | | Children's Oncology Group
| | | | | | http://www.childrensoncologygroup.org/
| | | | | | Children's Hospice International www.chionline.org/
| | | | | | http://www.apon.org/files/public/last_acts_precepts.pdf
| | | | | | http://www.aps-spr.org
29 | Joanne Wolfe, MD, MPH | Harvard University-Pediatrics | Reviewer | 13, para 4 | Methods | I suspect you intended to include “Canada” inside parentheses. | Corrected
30 | Joanne Wolfe, MD, MPH | Harvard University-Pediatrics | Reviewer | | Gaps/articles | Consider including the attached article (Beal A. Quality Measures for Children's Health Care. Pediatrics 2004;113(1) 199–209 | We reviewed this article, however, it did not meet our criteria (disease not cancer)
31 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 3 | Summary/ Conclusion | The sentence: “Palliative care is a term that is sometimes used interchangeably, except that it is focused on living with the more advanced stages of illness.” I would question this description of palliative care- is a component of care from diagnosis and increasing in focus. | We agree that these distinctions and definitions are inexact, and therefore we have not attempted to define them more precisely.
32 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 19 | Table 1 | VHA- Spell out VHA, no reference found | VHA is the actual name of the system.
33 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 30 | First paragraph | “...PE.1.4; and the National Consensus Project for Quality Palliative...” add Project | Corrected
34 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 32 | Under Treatment, second paragraph, last sentence | “...the reviewers concluded that improved adherence with long-acting drugs in clinical practice improved outcomes.” is an incomplete sentence | The sentence beginning with “Although” is complete.
35 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 35 | Dyspnea QA Tools | end of paragraph, “ ...Association of Palliative Medicine.” Reference country here- could be confused with AAHPM. | It is true, but these are distinct organizations.
36 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 36 | Dyspnea- PI- Assessment | ACCP, spell out somewhere, found on page 37 but should also be reference here, should also be listed on page 11. | Corrected
37 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 48 | ACP- Chemo in last 14 days measure | "A high proportion (> 10%) of cancer patients receiving chemotherapy in the last 14 days of life indicates poor quality care. This is the indicator? | Yes, that is the implications of the measure according to the developers.
38 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 50 | ACP- safe dying in hospice measure | “This indicator is based on the assumption that caregivers who lack confidence or...” consider adding this to your sentence. | Corrected
| | | | | | This is also an indicator of caregiver competence.
39 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | 52 | ACP - PI | What about POLST (Physicians Order for Life Sustaining Treatment) In use in Oregon and West Virginia, close to being used in NY. Nationwide rollout in 2006+. Probably should have some mention. | The team is familiar with the POLST, but not its use as an indicator or measure.
40 | Judi L. Person, MPH | National Hospice and Palliative Care Organization | Reviewer | | Reviewer list | Organization incorrect, change to National Hospice and Palliative Care Organization. Also, Kaiser is spelled incorrectly. | Done
43 | Lindsey Bramwell, MPH, RN, CDR, USPHS | CMS (Fed Reviewer) | Reviewer | | Symptom Management | Symptom management measures for pain, dyspnea, and depression disappoint in their failure to adequately examine patients freed from these symptoms, as well as the other processes of care such as assessment, treatment, and follow-up. | We agree and have modified our discussion of the limitations of the measures to point out that indicators or measures of follow-up are particularly lacking.
44 | Lindsey Bramwell, MPH, RN, CDR, USPHS | CMS (Fed Reviewer) | Reviewer | | General | The Report identifies gaps in the research--- the majority of the measures and indicators which are mentioned in this report have not specified the reliability and/or validity of these measures and have only been tested, not implemented. | Thank you.
45 | Lindsey Bramwell, MPH, RN, CDR, USPHS | CMS (Fed Reviewer) | Reviewer | | Dyspnea Measures | Your innovative approach of using dyspnea measures developed for chronic obstructive pulmonary disease in view of the lack of specific cancer population dyspnea research is to be commended. You have identified the need for new Cancer Care measurement research, but in the meanwhile, you have promoted the concept of cross-cutting measures which apply to multiple diseases to move towards broadening the applicability and aligning Cancer Care measures with measurement research projects and guidelines. | Thank you.
46 | Anna M. Lythgoe, RN, MSN | VHACO | Reviewer | | | The review of the literature for quality indicators related to cancer care was broad enough to capture relevant information but stringent enough to focus on particular areas of interest: pain, depression, dyspnea, and advance care planning/patient as decision-maker. | Thank you.
| | | | | | It was surprising that there were not more quality of care indicators related to cancer care noted in the literature.
47 | Anna M. Lythgoe, RN, MSN | VHACO | Reviewer | 8 | | Symptom management included assessment of “frequency, severity, and bother or functional impact” (pg 8). Recently reviewed studies for development of home care indicators indicate patients feel that loss of independence/function is critical to their perceptions of the quality of their lives. Clinical review of functional impact of symptoms (pain, depression, dyspnea) would potentially improve symptom assessment and impact of treatment for those with cancer. | We agree that it is relevant, although no indicators account for functional status at the present time in measuring clinical improvement.
| | | | | | The VHA “pain management workgroup” is currently discussing how to measure improvement in function as pain management improves. It would seem that this would also be relevant for the cancer patient.
48 | Anna M. Lythgoe, RN, MSN | VHACO | Reviewer | | | Potential indicators discussed that could be used to address the gaps in the literature were fairly global as currently stated. However, with refinement, they may be well utilized to drive ongoing assessment and treatment of symptoms related to cancer care. Many could be readily operationalized (almost) as written (e.g. physician documentation of pain assessment, patient education regarding pain management, routine assessment for dyspnea) while others may require clinical evidence to support change in practice (e.g. use of long acting opiates with as-needed opiates, indicators supporting specific interventional modalities). In summary, the suggested indicators based on the literature reviewed were more hopeful than the indicators currently in place. | We agree that there are many gaps in current knowledge not addressed by the available measure or indicator sets.
49 | Anna M. Lythgoe, RN, MSN | VHACO | Reviewer | | | Mention is made of the burden of cancer on patients and caregivers (pg 1) but the caregivers are not addressed in the review. The significant fiscal impact of (unpaid) family caregivers on the healthcare system begs their inclusion in the quality of care review. Also, the clinical responsibility to ensure that the family caregiver has the education, support, and resources needed to successfully provide this care is heavy and must be addressed at some level. | We agree, and it is unfortunate that caregiver concerns were out of the scope of this report.
50 | Anna M. Lythgoe, RN, MSN | VHACO | Reviewer | | | Table 2 (Processes potentially relevant to symptom care and advance care planning) - Assessment - Advance Care Planning: If a family caregiver will be providing care, assessing his/her ability and willingness to provide care, educational needs, support systems, and identifying the limitations of their abilities may need to be assessed. | Thank you. This issue is addressed in the actual indicators under NHPCO client and caregiver assessment for unmet needs and care preferences. No need to add to potential indicators, except perhaps as a supplemental citation and reference.
53 | Phil Madvig, MD (Paul Feigenbaum and Jann Dorman) | Kaiser Permanente | Reviewer | | | For those metrics where the denominator is a population associated with an institution or delivery system, e.g., “all deceased cancer patients” at Dana Farber there may be a concern that the metric would be driven by the unique characteristics of the institutional population in addition to the practice patterns applied to the numerator population. For example, the patient population attracted to an academic medical center with a reputation for clinical trials may be different than the patient population at a regional medical center. How would these 2 institutions compare their performance on a single metric? | We agree and have broadened our discussion of limitations to suggest that the populations tested may need to account for or examine differences in institutional bias with this difference in mind.
54 | Phil Madvig, MD (Paul Feigenbaum and Jann Dorman) | Kaiser Permanente | Reviewer | | | The listings of measures and indicators appeared relatively complete to us. We are not aware of additional sources of measures or indicators which you have not included. | Thank you.
55 | Phil Madvig, MD (Paul Feigenbaum and Jann Dorman) | Kaiser Permanente | Reviewer | | Comment | We face several challenges in developing quality metrics at Kaiser Permanente. We need metrics that are: | This is helpful and we have highlighted these needs in our Discussion.
| | | | | | *Feasible to collect on a scale basis. Metrics which are dependent upon chart review present tremendous resource challenges to measure in a large population.
| | | | | | *Low risk for perverse incentives. For example, the percentage of patients referred to hospice in the last 3 days of life can be decreased by not referring patients to hospice in the last 3 days of life.
| | | | | | *Timely. We need performance feedback that can be used to manage operations. The metric must be reported within a time frame that is meaningful to make operational improvements.
56 | Phil Madvig, MD (Paul Feigenbaum and Jann Dorman) | Kaiser Permanente | Reviewer | | ACP | We question if the logic of the conceptual framework for the processes of care used for symptom management holds up for advance care planning. As an example, you have labeled the second step in the conceptual framework “application”, but refer to “application of preferences...” in the third step for ACP. Given the well known challenges in operationalizing advance care planning on a scale basis, an accurate framework for the processes of advance care planning would be a great asset in understanding how to be successful. | We agree that this is somewhat awkward, and we have changed ‘application’ to ‘implementation’.
59 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 2 | Last paragraph | "...varies significantly among elderly cancer patients.." only among elderly, or all cancer patients? | The citations for this statement are from the work of Fisher et.al. in the Medicare population. We are unaware of analyses that have addressed this directly in younger populations, although we would not be surprised if variation were found here as well.
60 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 2 | Last paragraph | “Cancer treatment at any stage commonly requires potentially difficult interventions such as chemotherapy or surgery.” Not sure what "difficult means. | We have clarified this language.
61 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 2 | Last paragraph | “Now, quality practice endorses advance care planning for a number of reasons: to allow patients to shape care to their preferences, to avoid imposition of [unwanted?] treatment in urgent situations, to relieve patient and family anxiety...” | Corrected
62 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 3 | Summary/ Conclusion | “...that is sometimes used interchangeably, except that it is focused...” Interchangeably with what? Supportive care? | Clarified
63 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 5 | Overview | Staff conducted an extensive grey literature and Web search..." Will the readers know what “grey literature” is? | This is a standard systematic review term, but we have added some descriptive language to clarify it for readers unfamiliar with it.
64 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 6 | Third paragraph | “Concerns were related relative to the feasibility of conducting a systematic review of distress.” Consider “Concerns were expressed relative to the feasibility of conducting a systematic review of distress.” | Clarified
65 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 9 | Last paragraph | "Elements of care planning include prediction of the clinical situation,.." Not sure what this means? Prognostication? | Yes. Clarified
66 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 10 | Table 2, first row under Symptom Management | “...preferences for evaluation and treatment;...” Does this include patients desired level of relief? | Yes, among other considerations. Clarified in Table 2.
67 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 17 | Table 1, Dana Farber | The Dana-Farber Cancer Center at Harvard University has pursued an effort to develop a set of administrative data-based indicators for palliative cancer care as part of its recent research agenda.- Are these intended as quality measures, or for some other purpose? | We are not certain if there are other intended uses besides quality assessment, although they have been reported as quality measures.
68 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 19 | Table 1, GCC | 1. Pain assessment and management. 2. Use of hospice care. Why only mention these 2 of the 80 measures? Are none other relevant to this project? | Yes that is correct. Our discussion of the indicator and measure sets highlights how we selectively used these sets to identify indicators or measures relevant to this project.
69 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 19 | Table 1, CCO | Measures relevant to palliative [cancer?] care include those that address: | Corrected
70 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 20 | Table 1, VHA | o Assess pain regularly o Manage pain optimally Do these not continue across the ICU stay/measurement period? Are they only measured at day 1? | The VHA bundle is designed so that each measure is targeted to a day of admission. The pain measures are targeted to day 1 and are only measured for that period.
71 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 21 | Literature flow | “...we found 389 articles from the database...” Unique from the 4580? | Yes, and we have clarified this description.
72 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 21 | Table 1, NHPCO | Quality measures included: 1. Comfortable dying 2. Self-determined life closure 3. Safe dying 4. Effective grieving 5. Family evaluation of hospice care Any need to define any of these? | Corrected-We have provided a reference so that readers can explore these definitions themselves.
73 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 24 | Pain, Introduction- | Two last paragraphs of the introduction, Can this be presented as a table instead? Somewhat difficult to follow in text? | Corrected-We embedded a reference to the Evidence Tables which essentially present this in tabular form.
74 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 25 | Measures and Indicators | Section is somewhat difficult to follow in text but is a nice description of these measures. | Thank you.
75 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 25 | Measures and Indicators | Suggest add, Measures and Indicators: Pain as the section header. Did I miss somewhere a statement of the structure for this section (re measures/indicators in italics) | We have changed our Chapter and section headings for smoother reading of the report.
76 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 31 | Potential Indicators and Measurement Gaps | Any data that physician documentation actually translates into improved pain management? | This is addressed in a limited fashion in the Discussion.
77 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 31 | Potential Indicators and Measurement Gaps | Suggest add Potential Indicators and Measurement Gaps: Pain as section title | We have changed our Chapter and section headings for smoother reading of the report.
78 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 32 | Potential Indicators and Measurement Gaps | First paragraph “Disparities in pain assessment” What about age related differences/disparities? Are also data that geriatrics population (especially in [illegible]) receives inadequate pain control. | This is addressed in a limited fashion in the Discussion.
79 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 32 | Treatment-Measurement gap | Treatment. “Procedure-related pain in children paragraph.” Should this one be limited to children? Is it not a relevant issue for adults? | We agree that such an indicator would be reasonable to consider for adults by analogy and have suggested so.
80 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 32 | Treatment | Treatment. Education. “The numerator is patients who are educated about pain management..” Does this need to be defined any more (e.g.. Person is printed materials) | We agree this is ambiguous and this would be required as part of trying to operationalize these potential indicators.
81 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 33 | Dyspnea- Introduction | First paragraph. Again, can this be formatted differently for ease of following? | We embedded a reference to the Evidence Tables which essentially present this in tabular form.
82 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 33 | Measures and Indicators | Measures and Indicators: Dyspnea. Suggest adding Dysnea to section title | We have changed our Chapter and section headings for smoother reading of the report.
83 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 34 | Treatment-Measurement gap | Treatment: Pain. Suggest adding Dysnea to section title | We have changed our Chapter and section headings for smoother reading of the report.
84 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 35 | Follow-up | Follow-up: Dysnea. Suggest adding Dyspnea to section title. | We have changed our Chapter and section headings for smoother reading of the report.
85 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 36 | Potential Indicators and Measurement Gaps | "Assessment for treatable causes of dyspnea" I like the measure, but am concerned that there are sufficient data to support a list of defined “treatable” causes. | Agree that this would require further clarification. The potential indicators are meant to suggest informed opinion, not definitive evidence in that regard.
86 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 36 | Potential Indicators and Measurement Gaps | footnote 1, Nice summary and important to include | Thank you.
87 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 36 | Potential Indicators and Measurement Gaps | Suggest adding Dyspnea to section title | We have changed our Chapter and section headings for smoother reading of the report.
88 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 37 | Treatment | “Treatment for malignant pleural effusions. The numerator is patients who have ...” “Bronchoscopic therapy: The numerator is patients who have had...” “Palliative radiation and chemotherapy. The numerator is patients who have received....” Would it be “who have been offered” to respect patients choice? | We agree that it is correct to consider patients who were ‘offered’ a treatment as part of an indicator or measure. Making this suggested indicator into a measure would require resolving that consideration.
89 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 37 | Treatment | Treatment: Dyspnea. Suggest adding Dyspnea to title section | We have changed our Chapter and section headings for smoother reading of the report.
90 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 39 | Measures and Indicators | Suggest adding Depression to title section. | We have changed our Chapter and section headings for smoother reading of the report.
91 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 41 | Measures and Indicators | Suggest adding Advance Care Planning to title section. | We have changed our Chapter and section headings for smoother reading of the report.
92 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 45 | Application | Suggest adding Advance Care Planning to title section. | We have changed our Chapter and section headings for smoother reading of the report.
93 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 46 | Follow-up | Suggest adding Advance Care Planning to title section. | We have changed our Chapter and section headings for smoother reading of the report.
94 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 50 | First paragraph | (Measure- site of death) paragraph. "...(greater than 4%)... Is this number correct? | The paper actually states that high performing systems will have less than 4% with multiple hospitalizations or emergency room visits or are admitted to the ICU in the last month of life (p.11 in Earle) and sentence clarified in Report.
95 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 51 | Potential Indicators | Not ruse what is being addressed here- is this the “gaps” section? Where are the actual potential indicators? Did I miss something? | This section has been completed in the final draft.
96 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 51 | Potential Indicators | Suggest adding Advance Care Planning to title section. | We have changed our Chapter and section headings for smoother reading of the report.
97 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 54 | Chapter 4 | Last paragraph. " Symptom assessment requires efficient indicators that can become part of the dashboard of quality monitors for care settings. Is this a comment enough terminology? | The language has been clarified
98 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 55 | Chapter 4 | Second Paragraph. Consider the following revision: Pediatric [cancer] cases represent the second leading cause of death among children ages 5–15 in the United States. | Clarified
99 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 55 | Chapter 4, Last paragraph | there is an extra closing parenthesis after dying that need not be there. | No error found in current draft.
100 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 56 | Chapter 4, Second to last paragraph | It is important to define subgroups of cancer by stage of illness and to understand the performance of indicators among major subgroups. Issues such as timeliness of care and how side effects are tolerated or managed may vary in importance across groups distinguished by type or severity of illness. This seems to be a separate issue than the disparities addressed above,$ | We modified the language to unify these considerations.
101 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 56 | Chapter 4 | Third paragraph, first sentence. “We found insufficient evidence to comment on important difference by gender, race/ethnicity...” Age, should geriatric population have separate consideration? What about language issues? If measures that require patients report are only available in English, are less useful? | We agree and have added language as a consideration in the Discussion.
102 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | 57 | Chapter 4 | Last paragraph. Starting with the sentence “However, unlike other tools...” Should this be separate paragraph? Is really a distinct issue from measurement availability. | Agree and we separated these issues
103 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | | | Conceptual Issues and processes of care? Quite complete. One area that I did not see mentioned (expect in an ACOVE measure related to advance care planning) is the coordination of these symptom management and advance care planning areas across specialty and primary care. This may be beyond the scope of this project, but perhaps worth addressing or at least acknowledging. | We agree that coordination is an important element of care that was not addressed within the scope of the current project.
104 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | | | How complete is the listing of relevant measures or indicators? Quite complete. Appropriate attention is paid to the need for pediatric-specific measures and those that address potential racial. ethnic disparities. I question whether specific attention needs to e paid to geriatric-specific issues as well. | We agree and have added some language to our discussion of population differences in the Discussion to highlight the need for further information on this topic.
105 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | | | The “take home” message being that there are sufficient measures to begin assessment/monitoring in these areas, but that additional research is necessary to fill in the gaps. | Thanks for highlighting this important conclusion, and we have underscored it more strongly in our Discussion.
106 | Jean Kutner, MD, MSPH | University of Colorado Health Sciences Center | TEP | | Overall | The Evidence tables are especially well-constructed and useful | Thank you.
107 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 32 | | Proposed indicator for patient education regarding pain management - how would “education” be operationalized? Would this be based upon physician/nurse documentation in the chart? Or would patients' and or their caregivers be assessed for their knowledge? | See response to Item #78.
108 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 32 | | Why is the procedure-related pain indicator limited to children? Seems like it should apply to adults also. | See response to Item #77.
109 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 36 | | Routine dyspnea assessment in cancer - the denominator “all cancer encounters” is too broad - many patients with a diagnosis of cancer will not have active disease (i.e. routine follow-up of early stage breast cancer treated 5 years ago). Even limiting this indicator to “all encounters in patients with metastatic disease” is probably too broad. Perhaps “all encounters in patients with lung involvement with cancer or a prior complaint of dyspnea” would be a reasonable starting place for routine assessment of dyspnea. What would constitute assessment? Is recording of a respiratory rate in the chart assessment or does the clinician need to question the patient regarding the presence or absence of dyspnea? | We did not intend to resolve these ambiguities in posing this as a ‘potential indicator’ We did clarify language around these ambiguities somewhat in the discussion of this particular item. We also added further description of potential indicators in our Methods so that readers would understand our intent of offering only reasoned suggestions in this section of potential indicators.
110 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 36 | | Assessment for treatable causes of dyspnea - consider making this numerator more specific - perhaps # of patients who have had all of the following performed within xx weeks of the complaint of dyspnea: vital signs, lung exam, O2 saturation, Hb, chest imaging, DVT/PE assessment (documentation of physical exam of legs or Doppler/UTZ lower extremities or CT angio or VQ or D-dimer). The other challenge here is longitudinal assessment - what if patient has dyspnea in July and is evaluated and treated for pneumonia with resolution of symptoms and then in September has dyspnea again? | See response to #107.
111 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 37 | | Treatment of malignant pleural effusions. I would urge you to consider being more cautious in the recommendation of pleurodesis as a quality indicator. In my own experience, there tends to be overuse not underuse of pleurodesis - use in patients who are not symptomatic or where the production of malignant fluid is occurring at such a rapid rate that pleurodesis cannot be successful. Many of the published reports tend to overstate the effectiveness observed in actual practice and rarely provide the rates of continued success 1–2 months later. I'm attaching a survey of pulmonologists regarding their views of the procedure which I think echoes the uncertainty regarding its effectiveness. | Treatment of malignant effusions were taken from ACCP and are the state-of-the-art and most current recommendations - limitations are noted and we only propose this as a potential indicator supported by available data. The limitations will need to be addressed in subsequent work
112 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 37 | | Broncoschopic therapy - other treatment modalities for central airway obstruction are not mentioned. Brachytherapy and external beam radiation can often be quite effective and may be more widely available than bronchoscopic therapy. In selected cancers (small cell lung cancer, lymphoma), chemotherapy is the most effective approach. Also, steroids may provide significant relief of symptoms and if patients are in a terminal phase of their disease, this may be enough to provide them palliation until death. | These other modalities are briefly mentioned proportionate to the available data identified in the systematic review.
113 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 37 | | Patient education - same comment as pain indicator regarding education. | See response to Item #78.
114 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 46 | | Late life hospital use - it may be worth explaining under what circumstances this may or may not be a good quality measure. It likely reflects structural as much if not more than process quality - without high quality in home care or inpatient hospices or nursing homes that really address the needs of the dying, hospitalization may actually provide patients with a more comfortable death experience and more support for families. Given the daily capitation rate for hospice, current home hospice provides very little in the way of support - and is really not viable for patients who do not have informal caregivers or the resources to pay for round the clock care. | Thank you - we agree that it is important to stress these limitations and we have added language to make that clear to readers (P41) Also, see response to Item # 17.
| | | | | | In addition, there is a catch-22 that as not been fully addressed by the work of the proponents of this and other similar measures: patients hospitalized late in life and/or who die in the hospital is asked may have had a preference for hospitalization at that time. Those same patients may also have had a preference to die at home. However, at the time of hospitalization, they may not yet accepted that death was imminent even if this was communicated to them. I cannot tell you how many times in my own practice, I have talked with patients and or family of members of patients at home receiving hospice care while the paramedics were waiting to take them to ER (even after making a home visit earlier in the day...).
| | | | | | The issue of the limitations posed by the retrospective “look back” of a number of these quality measures should also be addressed (see article by Bach et al.). Research efforts should focus on developing quality measures that allow prospective identification of the denominator, for example by using performance status or some other predictor of death. My own experience caring for patients at the end-of-life has been limited to patients with breast cancer. And, except in a rare case, I have been struck by how patients have lived with good quality of life and excellent performance status for several years before having quite a precipitous decline over 3–6 weeks prior to dying. I imagine that different cancers have different trajectories and that for our quality measures to improve the care of patients we need to be able to account for these differences in disease trajectory -- as well as patient preferences - neither of which can be accomplished with these global “look back” measures.
| | | | | | Finally, there may be cultural differences regarding preferences for place of death that have yet to be fully explored.
115 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 8 | para 2 | "Self report" may be jargon and not readily understood by all readers - it may be worth explaining a few more words the first time you use it. | Clarified
116 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 11 | para 2 | We also searched for ‘related articles’ for citations that described measures..." -- I found this sentence confusing. I was not sure what ‘related articles’ were or how they pertained to ACOVE. | Clarified
117 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 12 | Last paragraph | It might be clearer to state “We searched the database of the End of Life Care and Outcomes Project, a systematic review recently completed by this report's authors, for articles coded as 'cancer.” | Clarified
118 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 23 | | Figure only mentions indicators and potential indicators not measures | Corrected
119 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 25 | | Consider reminding reader of the distinction between measure and indicator. Also I found the use of the parentheses in the headings somewhat distracting - consider using heading and subheadings: | We have changed our Chapter and section headings for smoother reading of the report.
| | | | | | Measures Identified
| | | | | | Regular Assessment of Pain: Quality Assessment Tools proposed
120 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 25 | | last paragraph refers to the second UHC “pain assessment indicator” but this appears to be a measure? | Corrected
121 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 26 | para 3 | “As with other pain outcome measures...” - Is the proposed measure “regular pain assessment,” which would be a process measure, or the score (average, final, change in?), which would be an outcome measure? | More information on the specification of the measure is not available.
122 | Jennifer Malin, MD | UCLA School of Medicine, RAND | TEP | 31 | para 2 | Have the numerator and denominator been reversed? | No error found in current draft.
124 | Joan Teno, MD, MS | Brown Medical School | TEP | | Indicators | You need to move away chart based indicators | Agree that this is a consideration that should affect the use of the current set and implications for future research. We have stressed that chart-based and administrative data based indicators may not provide adequate information for quality assessment and improvement, and that these limitations should be understood as part of better population studies. Obviously, the merits of specific indicators and data sources must be understood individually.
125 | Joan Teno, MD, MS | Brown Medical School | TEP | | Literature Search | The literature searching strategy that restricted everything to cancer was unneeded for symptoms, pain, and cancer. They do not need to be cancer specific processes. There is nothing that is inherent to the disease trajectory that warrant a different process of care. So you indicators that could go forward that has been used in other research and quality improvement efforts. | While we went beyond the scope of our task order in searching dyspnea and ACP, we agree this would have been a consideration had resources permitted it. We have tried to acknowledge this as a limitation and have suggested how that might be mitigated by the NQF process.
126 | Joan Teno, MD, MS | Brown Medical School | TEP | | Measurement Set | My overall assessment is that the current measurement set is very weak and potentially, should not go forward - information on reliability and validity is missing. Even more important, I did not see information on responsiveness, discriminate validity.. all things that are very important prior to the use of accountability. | We have stressed the need for additional evaluation in populations to address these attributes and that the use of measures should be concordant with the strength of information on their applicability within clinical settings and across systems.
127 | June Dahl, PhD | University of Wisconsin-Madison | TEP | 31 | Pain | I found the comment at the end of page 31: “improvements in pain assessment by non-physician staff may not lead to improved outcomes because the physician may not attend to the report of pain.” I need to explore that reference source because if that statement is true, we are in deep trouble. Physicians rarely see patients in LTC and in the post-op period it is obviously non-physician clinicians who have the responsibility to assess and document pain. | It is true that assessment must be linked to clinically meaningful outcomes to assure relevance to patients.
128 | June Dahl, PhD | University of Wisconsin-Madison | TEP | 32 | Pain | there is a statement: “the reviewers concluded that improved adherence with long-acting drugs in clinical practice improved outcomes.” Is there any rationale for this conclusion? What outcomes are the reviewers referring to? | They are referring to pain and the application of expert opinion. We have clarified the statement.
129 | June Dahl, PhD | University of Wisconsin-Madison | TEP | 43 | General Edits | Data is a plural noun and yet sometimes use as a singular noun, e.g., line 2 page 43 ...."validity data is available." | The final report has been reviewed by a medical editor.
130 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | General Edits | Dangling participles are another issue. I am a purist about those, but only mention two. On page 26, line 5: what or who is “using an appropriate rating scale?” On page 49, 10th line from bottom, who is “using the highest performing decile of this measure?” I am certain you will catch the others as you edit. | The final report has been reviewed by a medical editor.
131 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | Pain | An important measure identified: how many patients being treated with opioids are on a bowel regimen was also identified by the JCAHO-NCQA-AMA Task Force. I think JACHO's field trial showed there was lots of room for improvement. | In our discussion with JCAHO about this project, they felt that these were not yet ready to be measures since they still needed further development. This information has been added to this section: “A similar potential measure has also undergone some field testing in a population including cancer patients as part of the JCAHO-AMA-NCQA pain management performance measure development project {#8404}.”
132 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | Dana Farber Guidelines | I was very interested in measures developed at Dana Farber: of new chemotherapy in the last 30 days of life, of patients receiving chemotherapy in the last 14 days of life, and late referral to hospice. Unfortunately, in our area, some of the more recently developed chemotherapies are being offered to patients with very advanced disease which results in a delay in their admission to hospice. My comment adds nothing to your review - it is just a reflection of our realities and makes me question how implementing these measures could improve quality given the forces in the oncology profession that are pushing for more therapy. | Agree these might be useful, although we have added some caveats about the use of utilization outcomes as measures in Discussion and introduction to ACP measures.
133 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | General Edits | Inconsistency in use of terms related to opioid analgesics. Opioid would be preferred, but narcotic appears (e.g., page 27) as does the term opiate (e.g., page 32). | We have changed all opiate(s) to opiod(s).
134 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | Numeric rating scales | Is it intended that numeric rating scales be 1–10 (page 26)? The numeric pain rating scale is 0–10. On page 33, there is reference to a 10-point dyspnea scale. Is it indeed a 10 point scale or an 11 point scale? | Corrected VHA lists this as a 1–10 rating scale so that is what is reported here.
135 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | Pain | It is interesting that none of the studies you cited used pharmacy department data. If pain is the symptom of interest, one could measure the percentage of patients with a diagnosis of cancer and moderate to severe pain who are/were being treated with opioids. | We agree that there are additional data sources and indicators that should be considered.
136 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | Future research | Obviously data collection is a huge challenge. The data have to be easy to obtain. The advent of electronic medical records, should enable collection of accurate data so as to make measurement possible. | We do now provide some additional discussion of measurement issues in the Discussion
137 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | Pain | The cognitively impaired are a special assessment challenge. We need to develop measures that don't rely on self reports if we are to assess pain in that population. We are working on a scale based on items in MDS 2.0; certain behaviors suggest the presence of pain. | Agree and we have highlighted the challenge of those who cannot self-report in our Discussion.
138 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | Pain | The critical first step is assessment. And as your report emphasizes, waiting 48 hours to do the assessment makes no sense. I would prefer the JCAHO standard: ask about pain on admission: All patients with a diagnosis of cancer who are admitted to hospital should be screened for pain on admission regardless of the reason for their admission. If pain is present, the intensity and quality of the pain should be assessed. The focus in all of the literature available is on assessment of pain intensity. Quality should be assessed as well so as to determine whether the patient has neuropathic pain. A measure of the presence of neuropathic pain is critical to development of an effective treatment plan. Krause and Backonja (Clinical J of Pain, 2003) have developed a short form of a neuropathic pain questionnaire which involves rating of numbness, tingling, increased pain due to touch. A comprehensive pain assessment involves asking questions about quality; should be possible to add two or three boxes to check or numbers to circle to provide data for this assessment. We haven't made an effort to create appropriate forms to make this additional component of assessment a practical reality. | We agree that symptom assessment is a complex task. We have added some language to address other aspects of assessment that are not covered in the existing indicators and measures to the potential pain indicators discussion.
139 | June Dahl, PhD | University of Wisconsin-Madison | TEP | | Sources | The recent recommendations from the American Pain Society (Archives Int Med 2005; 165: 1574–1580) were published after you finished your intensive review. They deal with acute and cancer pain; the recommendations for acute pain reflect what was in reference #87 of your draft. | The updated information from this new article has been added in several places in the report to update reference #87, for example: “A related outcome potential measure, that patients should be adequately informed and knowledgeable about pain management, is included in the 2005 American Pain Society Recommendations for Improving the Quality of Acute and Cancer Pain Management {#8404} based on an expert review of the measurement tools used in 20 quality improvement studies in pain management.87”
140 | Laura Hanson, MD, MPH | University of North Carolina at Chapel Hill | TEP | | Process vs. Outcome Measures | Consider adding to the report whether a measure is a process measure which primarily addresses quality of care, vs. an outcome measure which directly addresses the patient experience. | These are sometimes hard to qualify or categorize exactly. There is also the concern that some measures may reflect structure (see Item # ). We agree that it is important to stress that measures should ideally reflect the patient experience. We have added additional language to highlight these issues in the Discussion.
141 | Laura Hanson, MD, MPH | University of North Carolina at Chapel Hill | TEP | | | I would encourage addition of the absence of reliable and valid measures for cognitively impaired patients to your lists of gaps in quality measurement. | Thank you and this is discussed in the current version (as those who cannot self report).
142 | Laura Hanson, MD, MPH | University of North Carolina at Chapel Hill | TEP | | | In addition to reporting reliability and validity of individual measures, it would be very valuable to report on the responsiveness of these measures. It will not be true for all measures, but for any that have repeated measures over time and/or in relations to interventions, adding evidence that a measure has dynamic properties adds its relevance to clinical quality improvement. | We agree and have highlighted the need for more research on this as an issue in the Discussion.
143 | Laura Hanson, MD, MPH | University of North Carolina at Chapel Hill | TEP | | Pain | The text would benefit from an introduction to measurement issues from pain, the best studied of all these symptoms, so that the measures are in a broader context of certain limitations. I would include the following aspects: | We agree that it might be helpful to illustrate these challenges in the context of pain care. We have added some language to highlight these considerations in the conceptual discussion.
| | | | | | Measurement systems need to specify exclusion or use of alternative measures for patients unable to self-rate symptoms due to cognitive impairment
| | | | | | Effect of depression, symptom interpretation and addiction history may modify treatment approaches; settings may vary in the frequency with which these effects influence measurement
| | | | | | Pain literature shows a discrepancy between pain severity scores and patient satisfaction with pain treatment- perhaps due to low expectations for relief, OR due to positive responses to attention to pain even when it is not fully relieved. You might want to address the dilemma of symptom scores as measures vs. satisfaction with care.
144 | Marilyn Bookbinder, RN, PhD | Beth Israel Medical Center | TEP | | Future research | If benchmarks are to represent best practice and serve as the “gold standard” for practitioners to emulate - more rigorous research designs and larger homogeneous samples are needed to strengthen the evidence base and persuade those allocating funds to increase “quality” care research dollars. | This is a helpful point and we have stressed the need for testing of the measures in cancer populations in our Discussion.
145 | Marilyn Bookbinder, RN, PhD | Beth Israel Medical Center | TEP | | Sources | Revised indicators for measuring outcomes of pain management have recently been published (Arch Intern Med. 2005 Jul 25;165(14):1574–80) by the American Pain Society Task Force on Quality. They include items such as how often the patient had moderate to severe pain in the last 24 hours; how much interference did pain have with their function (able to do what they needed to do) interference with sleep, interference with mood. No data has been published to date, although we at Beth Israel and colleagues at University of Wisconsin have data on selected indicators. | We have included this in our review.
146 | Marilyn Bookbinder, RN, PhD | Beth Israel Medical Center | TEP | | Potential Indicators | The potential indicators lists are relevant and are an excellent approach to using data available (not meeting the criteria). The indicators selected and approach used to target vulnerable populations (DRG, LOS, Adm) is excellent and I think will give others the guidance and tools needed to measure and improve symptom management and ACP in problem- prone high risk groups. | Thank you.
147 | Molla Donaldson, DrPH, MS | National Cancer Institute (Fed Reviewer) | TEP | 0 | Title | Make the title more specific as there are two other EPC reports on cancer measures - perhaps along the line of Cancer Quality of Care Measures for Supportive care and End of Life | See Response to Item # 19
148 | Molla Donaldson, DrPH, MS | National Cancer Institute (Fed Reviewer) | TEP | 3 | Introduction | The term “utilization outcomes” is a little strange without explanation - I think of utilization as just that (e.g., admissions, length of stay, hospice use), so that sentence could be clarified. | We have added additional discussion to explain our inclusion of these items and why we placed them in Advance Care Planning. We also modified the description in the Introduction.
149 | Molla Donaldson, DrPH, MS | National Cancer Institute (Fed Reviewer) | TEP | 5 | Chapter 2 | Under the 1. RFTO question, you might explain that after further discussion distress was dropped in favor of dyspnea - something along those lines so that it is clear you were responsive to the task order. | We have clarified this under the task order questions.
150 | Patricia Ganz, MD | UCLA Schools of Medicine and Public Health | TEP | | | It looks like you have found quite a few measures, but overall, I was very disappointed to see that so few had been implemented or tested. Have you contacted the measure developers in follow-up to see if they can give you any information on their use? For that reason, I worry that many of the measures may look good from an academic or measurement perspective, but may not be ready for prime time. I see this as a real limitation. | Yes, we contacted measure developers for all measure sets except the Georgia Cancer Coalition.
151 | Patricia Ganz, MD | UCLA Schools of Medicine and Public Health | TEP | | | Did you find any references to the pain thermometer scales that are being widely used in hospitals as required for hospital accreditation? We also use them in our outpatient department. I don't know how reliable and valid they are as measures, but they are now in wide use and seem practical. | No, we did not.
152 | Patricia Ganz, MD | UCLA Schools of Medicine and Public Health | TEP | | | I think Chapter 4 does a good job talking about the limitations of the measures and indeed the issue of obtaining self-report data from seriously ill patients is a real challenge. | Thank you.
153 | Patricia Ganz, MD | UCLA Schools of Medicine and Public Health | TEP | | | In summary, I think you have done a fine job, but I have concerns about how practical a lot of these measures will be for implementation. | We agree that further testing is of the highest priority before the potential of these measures can be fully realized.
154 | Perry Fine, MD | University of Utah | TEP | 11 | Internet Search | Under the section listing “Studies or Internet documents....”, the first bullet point omits Canadian references. Was this purposeful or an unintended omission? | Unintended, now corrected
155 | Perry Fine, MD | University of Utah | TEP | 32 | Treatment-Measurement gap | Might I suggest that a more broadly applicable potential indicator (measurement gap) would be (numerator) patients with moderate-severe pain who receive prescriptions for opioid analgesics (denominator = all patients with moderate-severe pain scores). This might be simplified further to the % of all cancer patients in a given practice who are prescribed opioids, with a benchmark extrapolated from exigent literature on the prevalence of moderate-severe pain in cancer patients. | Thank you. Our pain reviewers concur and we have added it to the list of potential indicators. This is also a potential indicator from a project including JCAHO, AMA, & NCQA.
156 | Perry Fine, MD | University of Utah | TEP | 40 | Depression | I was very surprised to see that there were no potential indicators/ measurement gaps enumerated for depression. Is there really no basis to elaborate upon this section (assessment, treatment and follow-up)? | This section has been completed in the final draft.
157 | Perry Fine, MD | University of Utah | TEP | | Chapter 4 | You rightly elaborate upon the clinically significant and problematic area of pain assessment in non-self-reporting patients. There may be the opportunity to round out the pain assessment section with additional potential indicators from (non-cancer) dementia studies. I would refer you to Dr. Keela Herr, who chairs the gerontological nursing division in the U. of Iowa College of Nursing, whose area of focus is pain assessment in cognitively impaired older patients. She may be able to point quickly to a rich little vein of literature that was not easily uncovered in your search. Her email address is keela-herr@uiowa.edu | Corrected-Thanks you - we were unable to expound upon this information for the draft report, but we have cited it for readers so that they can avail themselves of it
158 | Roger Winn, PhD | National Quality Forum | TEP | | Overall | I think the reviewers have done an admirable job of collecting available measures and analyzing them in a well conceptualized framework. I found the division between measures, indicators, and potential indicators useful and operationally sound. The analyses of the specific measures appears to be balanced and to target the major strengths and weaknesses. The conclusions of the report are justified by the body of evidence reported. | Thank you.
159 | Roger Winn, PhD | National Quality Forum | TEP | 1 | 1 | Mention scope: limited to pain, dyspnea, depression, advanced directives | The scope is covered in the introduction
160 | Roger Winn, PhD | National Quality Forum | TEP | 3 | para 2, line 13 | toxic instead of taxing | Changed to ‘difficult’
161 | Roger Winn, PhD | National Quality Forum | TEP | 7 | para 2, line 2–3 | I think this statement is a little too strong, For example the number of trained social workers or psychologists might have an impact on depression. I think it's more the case that it's difficult to directly establish the linkages between structure and outcomes. | Modified
162 | Roger Winn, PhD | National Quality Forum | TEP | 7 | para 2 | Although I think it's implied, you might want to point out that for symptom-related measures, the data collection is usually a patient response instrument, which from a measure perspective is much harder than trying to capture data from administrative sources or even the medical record. {I see you make the point later in the report} | Thank you.
163 | Roger Winn, PhD | National Quality Forum | TEP | 16 | 1 | I don't understand the decision not to abstract JCAHO, ORYX, or NCQA measures of relevance | This decision was made because these are widely available measure sets and in light of resources, it was felt to be more helpful for NQF's purposes to enumerate less visible indicator and measure sets. This decision was made in consultation with our task order officer.
164 | Roger Winn, PhD | National Quality Forum | TEP | 34 | | ACOVE effective dyspnea measure: I'm confused about the numerator: shouldn't the denominator be all patients with dyspnea? | No, the specifications are correct as described
165 | Roger Winn, PhD | National Quality Forum | TEP | 39 | | ACOVE spiritual assessment: Numerator and denominator definitions are reversed | Corrected
166 | Roger Winn, PhD | National Quality Forum | TEP | 41 | | ACOVE surrogates for poor cognition measure: how does the measure operationalize “dementia and altered mental state” to determine the denominator? How is impairment assessed, i.e standard tests, etc? Similar consideration for regular assessment of inpatients with severe dementia (p 42). | We have now included a definition.
167 | Roger Winn, PhD | National Quality Forum | TEP | 46 | | ACOVE documentation of specific life sustaining preferences. Why is the denominator restricted to those who state they do not want life-prolonging measures? Shouldn't the preference of those who do want aggressive therapy also be documented? | Since the default of providing these treatments is typical in clinical practice, documentation is not typically required to assure these interventions. Certainly, effective communication should be the standard for patients and families whether or not they elect specific treatments. However, the specification reflects the actual indicator.
168 | Roger Winn, PhD | National Quality Forum | TEP | 46 | | ACOVE consistency of preferences and mechanical ventilation. 1) As stated, the numerator doesn't seem to get at the consistency (concordance) issue: isn't the measure all those who are receiving ventilation in the denominator and all those who stated they did not want it in the numerator? 2) The discussion appears to be about withdrawal of ventilation not its institution. | In this case, the numerator reflects a discussion of preferences having occurred in patients who qualify for mechanical ventilation, regardless of whether or not they declined it.
169 | Roger Winn, PhD | National Quality Forum | TEP | 47 | | Dana Farber hospital use and ICU use measures: both discussions quote the norm in terms of use of emergency visits. This applies only to the ER measure. | The paper actually states that high performing systems will have less than 4% with multiple hospitalizations or emergency room visits or are admitted to the ICU in the last month of life (p.11 in Earle) and sentence clarified in Report.
170 | Roger Winn, PhD | National Quality Forum | TEP | 48 | | Dana Farber new chemo measure: does it exclude acute leukemias (10–15%) die from drug toxicity and hospitals with large leukemia practices might therefore suffer from this measure. | This information was not available, but we have addressed the concern that institutional variation and care mix adjustment needs to be strongly considered with these measures. See response to Item # 51
171 | Roger Winn, PhD | National Quality Forum | TEP | 49 | | Dana Farber admission to hospice measure: the Earle paper gives reasons for the low sensitivity (24%) and this should probably be included. | Agree and this is now included.
172 | Roger Winn, PhD | National Quality Forum | TEP | 49 | | Site of death Dana Farber late referral to hospice: does this need to be a composite measure with the % hospice admission? If two hospitals both have 9% late admissions of all the patients who die, i.e. poor quality, is this the same measure of quality for hospital A who has a 50% hospice admission rate and hospital B who has a (% admission rate (all late)? | While this measure does not address it, we agree that this measure has to be interpreted in light of the total hospice referrals of an organization.
173 | Roger Winn, PhD | National Quality Forum | TEP | 50 | | Dana Farber site of death , line 7 should be “(greater than 17%)” not 4% | Corrected
174 | Roger Winn, PhD | National Quality Forum | TEP | 51 | | Need NEJM reference for Danis. | Corrected
175 | Roger Winn, PhD | National Quality Forum | TEP | 54 | para 4 line 1: | I really have trouble understanding: “Symptom assessment requires efficient indicators that can become part of the dashboard of quality monitors for care settings”. What are efficient indicators? | We have clarified this sentence.
176 | Steve Asch, MD, MPH | VAGLHS | TEP | | | No comments received. | N/A
177 | William Lawrence, MD | AHRQ | TOO | 5 | Task Order questions | I think this would read easier to start with the final key questions in the task order questions section (if you'd like, you can even change the subhead to final questions). I'd rather the emphasis for the report were placed on the questions you actually answer in the report, not the ones that you were originally asked. If you'd like, I think it would be quite reasonable to put the initial questions (unbolded) in the approach to the report section, if you want to detail how we arrived at the final questions. At the moment, the only stand-alone key questions section lists questions that you only answer some of. | We agree and have presented the final, modified task order questions in the introduction - with a note that they were modified. We decided not to include all of the original questions since they are largely duplicative and we thought this presentation would be clearer for readers.
178 | William Lawrence, MD | AHRQ | TOO | 24 | Pain | the mention of an XRT measure in relation to pain was a bit confusing - I presume this was palliative XRT specifically? | Yes, XRT for symptom management.
179 | William Lawrence, MD | AHRQ | TOO | 25 | Pain | First measure (as general comment). “The measure is not in use” - I appreciate having this bit of data, but this means not in use anywhere? Not in use by the organization that has proposed it? | That is correct - to our knowledge.
180 | William Lawrence, MD | AHRQ | TOO | 37 | Dyspnea | treatment of malignant pleural effusions. Despite having worked in a cancer center, I don't have enough clinical experience here to judge, so I'll ask you - does this happen with enough frequency that you think it will be usable as a quality measure (i.e. will the rates be made from enough cases for a particular entity, be it practice, hospital, health plan, that the rate is stable enough to judge quality from the number)? This would get at the importance of the measure. | See our response to item #113
181 | William Lawrence, MD | AHRQ | TOO | 39 | Depression | assessment of psychosocial well-being. Is “formal assessment” defined? Is a screening survey sufficient? Must it be an assessment by a psychologic specialist? | We have clarified that this generally meant an assessment by a social woker.
182 | William Lawrence, MD | AHRQ | TOO | 39 | Depression | Spiritual assessment. Looks like you have your numerator and denominator backward. Also, I presume the numerator is specifically those with a spiritual assessment and have died? Otherwise, numerator is not a subset of the denominator. | Corrected
183 | William Lawrence, MD | AHRQ | TOO | 40 | ACP | first measure. Watch the measure/indicator terminology - you refer to this first as a measure, then as an indicator. | Corrected
184 | William Lawrence, MD | AHRQ | TOO | 40 | Gaps | Would appreciate this section sooner or later, preferably sooner. While I'm thinking about it, I thought your gaps sections (at least the ones that exist) were excellent in both content and writing. | Thank you,.
185 | William Lawrence, MD | AHRQ | TOO | 41 | ACP | regular identification of surrogate. Numerator is “vulnerable” elderly. How do we define vulnerable? This section in general seems to have a several terms with a similar degree of vagueness. | Vulnerable elders are conceptually defined as those persons 65 years or older who are at increased risk of death or functional decline in the next 2 years. Vulnerable elders are specifically defined as those scoring 3 or greater on the VE-13 scale, a self-report that gives points for age, self-reported general health and activity limitations( Saliba et al. JAGS 49:1691–1699, 2001). In practice the VE-13 identifies about 20–30% of community-dwelling older adults as vulnerable and they have a 4 fold increase in the odds of death or function decline.
186 | William Lawrence, MD | AHRQ | TOO | 42 | ACP | 2^nd^ regular identification of surrogate. Is the numerator a subset of the denominator here? | Yes, but we tried to clarify the description to make that clearer (42)
187 | William Lawrence, MD | AHRQ | TOO | 42 | ACP | last measure - how do we assess that a patient had care consistent with expressed preferences? | The assumption in the ACOVE measures is that the patient's preferences, surrogate will be elucidated and documented within the patient's medical record, usually within a specified timeframe depending on site within the hospital, or why surrogate and preferences were not able to be obtained. Thus, the documentation in the patient's record of their preferences would provide the standard by which care consistency will be evaluated. Clarification text inserted in final report.
188 | William Lawrence, MD | AHRQ | TOO | 46 | ACP | documentation of specific life sustaining preferences. Not sure why the denominator is only those who don't want therapies (although, if this is what the measure says, we go with it, but might deserve comment). Also, numerator and denominator could be from different sets. | See response to Item #162
189 | William Lawrence, MD | AHRQ | TOO | 47 | ACP | DFCC measure set - you refer to ER visits for discussions of hospitalizations and ICU episodes. Also, while I could grasp your ratio of the 5^th^ percentile/95^th^ percentile for a measure of variability of the measure, I think it would be helpful to put in the raw rates here also. | Raw rates are not included in the paper from which these data were derived {#0742} or in the published article used as supporting evidence {#0142}. Accuracy data and the range for the 95% CI have been added to the text of the final report.
190 | William Lawrence, MD | AHRQ | TOO | 48 | ACP | chemotherapy in last 30 days of life. Does this include Phase I trials? Should it? Is palliative chemotherapy used this late? | This is not addressed in the available information we have on the measure. Presumably it would not capture Phase 1 trials, unless they are covered (and recorded) in Medicare administrative records.
191 | William Lawrence, MD | AHRQ | TOO | 49 | ACP | admission to hospice and others. Is there a definition of “deceased cancer patients”? Is a breast cancer survivor NED for 5 years who dies of a heart attack a deceased cancer patient? | This is not addressed in the available information we have on the measure.
192 | William Lawrence, MD | AHRQ | TOO | 51 | ACP | potential indicators - a reference to the appendix would be nice here. | Corrected-We embedded a reference to the Evidence Tables which essentially present this in tabular form.
193 | William Lawrence, MD | AHRQ | TOO | 54 | Chapter 4, 3rd paragraph | Can we say anything from the extensive amount of data that you reviewed concerning the frequency with which pain is assessed and appropriately treated? I realize that by virtue of the settings being quality measure testing settings, they might not be generalizable, but presumably they could at least be considered an upper bound of what happens in reality. | We have added this information: “Some information is available on measure for pain assessment, but we identified no measures with this type of information for appropriate pain treatment. The UHC measure of any pain assessment within 48 hours of admission to the hospital, which was met in almost 100% of patients and showed little variation among facilities, would not be useful for any of these purposes. The more rigorous UHC measure, requiring assessment with a numeric pain scale(mean 76%, range 13–100%) and the QOPI measure for pain assessment on the last oncology visit prior to death (mean 56%, range, 30–90%) show more variation and therefore more promise, but would need evaluation for responsiveness and association with outcomes. The VHA measure for regular pain assessment in the ICU shows a low level of initial performance in 1 institution (42%), responsiveness to an intervention (94%), and a relationship with improved outcomes (a decrease in pain scores >=3 from 41 to 6%).60)”
194 | William Lawrence, MD | AHRQ | TOO | 55 | Chapter 4, second paragraph | Agree with the issue of no measures in pediatric cancer. It might be worthwhile echoing this in some of the gaps sections in the prior paragraphs. | We have added this additional language.
195 | William Lawrence, MD | AHRQ | TOO | 56 | Chapter 4, 1st paragraph | Also agreed on the issue of the measures not providing guidance. My question for you is whether this is a downside of the measure. Ideally, a quality measure is linked to a leverage point that clinicians, health systems, or someone else should be able to impact upon both to change the measure but ultimately to improve outcomes. For me as a clinician, it would be much easier to implement change if I have parameters with which to act in accordance with the quality measure and presumably in accordance with quality care. If the trigger is that I should take action 3 weeks prior to the person dying, it is somewhat hard to operationalize in my practice. I agree that the ACOVE measures have a better conceptual basis here, although again it would be helpful to understand what defines a vulnerable elder (if a definition has been specified in the measure). | We do agree that this is a downside of some of these measures.
196 | William Lawrence, MD | AHRQ | TOO | 56 | Chapter 4, 3rd paragraph | The lack of information on race, gender, etc, is not particularly surprising, but does anyone at all publish rates on their measures by these categories? If so, it would be worth mentioning. | We found no published differences in rates of these indicators by race / ethnicity or gender.
197 | William Lawrence, MD | AHRQ | TOO | 25 and on | | Minor editorial comment - could you reference the appropriate appendix containing the evidence tables at the intro of the sections, simply to note that there is more detailed info on the discussed measures. That way, if people want a formal definition of numerator, denominator, or want to know how data are abstracted, they'll know where to look. | Corrected-We embedded a reference to the Evidence Tables which essentially present this in tabular form.
198 | William Lawrence, MD | AHRQ | TOO | Front Matter | | Don't forget abstract, executive summary, etc. Would also appreciate an acknowledgement of the Federal Partners - in addition to AHRQ, they include NCI, CMS, and CDC. | We have acknowledged the Partners in the Introduction.
199 | William Lawrence, MD | AHRQ | TOO | | Measures | Also, general issue on the reports of measures - at times, you put in rates for the measures (e.g. second measure on page 25), which is an issue in testing (has someone actually put the measure out in the field and tested it enough to be able to get a rate?). It might be reasonable to consistently comment on rates, or might want to put up front that if you don't comment on rates, there aren't any (or whatever the conditions are for your not including these data). Also, should they appear in the evidence tables? | We have clarified this in our Methods. This information was provided only when it was available.
200 | William Lawrence, MD | AHRQ | TOO | | Evidence Tables | could you spell out Advanced Care Planning in the title? To me, ACP is American College of Physicians | Clarified
201 | William Lawrence, MD | AHRQ | TOO | | Organization | I liked the organization of the measures/indicators by Assessment/Treatment/Follow-up - that seems a very intuitive approach to dividing the measures. | Thank you.
202 | William Lawrence, MD | AHRQ | TOO | | Defining difference between measures and indicators | In the results section, you divide things into measures and indicators, but I haven't found where you define the difference between the two. Could you make this clear in text? Similarly, you have in your abstraction sheets a working definition of a quality measure, which I didn't see in text in the intro - might be worth adding. | We added a sentence referring readers back to the Methods sections for the definitions.
203 | William Lawrence, MD | AHRQ | TOO | | Evidence Tables | Incidental note after comparing page 39 text to evidence tables - it would be helpful if you could have the order of measures in the evidence table match the order in text - much easier to find a measure in the appendix that way. | We have now corrected this.
204 | William Lawrence, MD | AHRQ | TOO | | Table 1 | Table 1. I like this table. Having just finished commenting on the draft of colorectal measures report recently, they found a lot of literature reports on one or two measures (e.g. percent of stage III colorectal cancer patients receiving adjuvant chemotherapy) in a report. In yours, it appears that most or all of the measures/indicators are individual items from much broader measure sets. Is this true? Don't necessarily need to comment on this in the report, but I found the difference quite interesting | Yes, that is true.
205 | William Lawrence, MD | AHRQ | TOO | | Evidence Tables | While it is out of chronologic order, would suggest for the evidence tables that you list denominator first, then numerator, since typically the numerator should be a subset of the denominator. This will a) save you repeating the denominator in the numerator cell in the tables, and b) help make it easier to spot when the numerator isn't a subset (happened at least once - I'll find it in my notes), which should at least raise a red flag. | Thank you, and we have reversed the order of the columns in the final tables.
206 | Castillo, DonnaRae | AHRQ | | | Title | The title is not descriptive enough. Suggest a change to “Quality Measures for Supportive Cancer Care” or something very similar as you mention in your text. | We changed the title to reflect the task order.
207 | Castillo, DonnaRae | AHRQ | | | Title page | It is unclear who the actual authors are. I am assuming the two PIs and the two directors. This needs to be clear (for reference purposes). | Done
208 | Castillo, DonnaRae | AHRQ | | | Contents | This needs to be restructured. List the chapters in order, then References, Figures, Tables, Appendixes. (The last are merely listed with their titles; no page numbers for Appendixes (note it is “Appendixes” not Appendices] as these are only online.) Note also figures and tables are not listed within chapters. | Done
209 | Castillo, DonnaRae | AHRQ | | | Contents | We normally only use the first and, if necessary, second level of headings. Otherwise it becomes too unwieldy (see reworking of Chapter 3 contents, below). | We have corrected our chapter and section headings.
210 | Castillo, DonnaRae | AHRQ | | | Contents | Remove the line “Areas of Study” from the Contents for Chapter 3. It is not in text and is superfluous. Here is Chapter 3 using 1st and 2nd level heads: | Done
| | | | | | Chapter 3: Results..................................................
| | | | | | Overview...........................................................
| | | | | | Literature Flow..................................................
| | | | | | Pain....................................................................
| | | | | | Introduction...................................................
| | | | | | Measures and Indicators................................
| | | | | | Potential Indicators and Measurement Gaps..
| | | | | | Dyspnea................................................................
| | | | | | Introduction....................................................
| | | | | | Measures and Indicators.................................
| | | | | | Potential Indicators and Measurement Gaps..
| | | | | | Depression............................................................
| | | | | | Introduction....................................................
| | | | | | Measures and Indicators.................................
| | | | | | Potential Indicators and Measurement Gaps..
| | | | | | Advance Care Planning........................................
| | | | | | Introduction....................................................
| | | | | | Measures and Indicators.................................
| | | | | | Potential Indicators and Measurement Gaps..
| | | | | | Summary...............................................................
| | | | | | You may want to only use the chapter title and 1st level since the sections are short.
211 | Castillo, DonnaRae | AHRQ | | | General Format and Style | Report proper begins on page 1 (arabic not roman). All chapters open on a right hand page | This reviewer received a different version of the report directly from AHRQ.
212 | Castillo, DonnaRae | AHRQ | | | General Format and Style | First level headings (next level down from the chapter title) are centered | Corrected
213 | Castillo, DonnaRae | AHRQ | | | General Format and Style | Appendixes, tables and figures are numbered in the order they are cited in the text. | Corrected
214 | Castillo, DonnaRae | AHRQ | | | General Format and Style | Please do not leave space between paragraphs. The indention is enough to mark the beginning of new paragraph. The extra leading wastes space. | Corrected
215 | Castillo, DonnaRae | AHRQ | | | General Format and Style | Do not use bold to emphasize a word in text; italics is sufficient and it should only be used when defining a term e.g., “An indicator was defined as a descriptive statement...”). Italics should not be used repeatedly. For example, ACOVE or Dana Farber should not be emphasized whenever they are noted as the measure source and so forth. | Corrected
216 | Castillo, DonnaRae | AHRQ | | | General Format and Style | Titles of published books listed in running text should be in italics. (See for example p. xxxi, 1^st^ full paragraph and p. xv, 2^nd^ full paragraph.) This includes the title of your evidence report/summary in the run-on sentence at the bottom of p. xv; suggest you rewrite as: The authors had recently conducted a systematic review, End-of-Life Care and Outcomes.^21^ The project's database was searched for articles coded as “cancer”—regardless of type—by our topics of interest.) | Corrected.
217 | Castillo, DonnaRae | AHRQ | | | General Format and Style | First word of a bulleted item is capitalized. Generally, periods end each bulleted item (this is mainly a Web convention for compliance and readability). | Corrected
218 | Castillo, DonnaRae | AHRQ | | | General Format and Style | If quotations are necessary they should be double, not single marks (e.g., “living wills” on p. vi). Often, however, these marks are not needed. | Corrected
219 | Castillo, DonnaRae | AHRQ | | | General Format and Style | As a courtesy to the reader, spell out any acronym when it is introduced in the report (e.g., SCEPC on p. viii, DNR and DNI on p. xv). Do not, however, spell out acronyms in every chapter or in every section within chapters. | Done
220 | Castillo, DonnaRae | AHRQ | | | General Format and Style | The following are printed solid: followup (used as a noun or adjective), contraindicated, decisionmaking | Corrected
221 | Castillo, DonnaRae | AHRQ | | | General Format and Style | When used as a reflexive pronoun, self is hyphenated (e.g., self-expression, self-reported, etc.) | Done
222 | Castillo, DonnaRae | AHRQ | | | General Format and Style | Health care is two words (e.g. “health care measurement” or “health care system”) unless used as an established title (e.g., “Agency for Healthcare Research and Quality”). | Corrected
223 | Castillo, DonnaRae | AHRQ | | | General Format and Style | There is no space on either side of the solidus mark; i.e., Summary/Conclusion and 5/95 are correct (not Summary / Conclusion or 5 / 95). | Corrected
224 | Castillo, DonnaRae | AHRQ | | | General Format and Style | Use the ™ and ^®^ symbols when required; for example, Google™ CINAHL^®^ PsychINFO^®^ HEDIS^®^ | Corrected
225 | Castillo, DonnaRae | AHRQ | | | General Format and Style | If two or more numerals are used in conjunction and at least 1 of them is 10 or more, make them all numerals (as in this sentence). Thus we would not say “In nine of 10 trials...” | Corrected
226 | Castillo, DonnaRae | AHRQ | | | General Format and Style | The word State is initial cap when referring to a U.S. State (this is U.S. govt. style). | Done
227 | Castillo, DonnaRae | AHRQ | | | General Format and Style | It is not necessary to name books or articles if you are providing reference citations (see p. xxxi for example; you already cite the reference #71.) | Corrected
228 | Castillo, DonnaRae | AHRQ | | | Chapter 1 | I suggest that either here (or alternatively at the beginning of the next chapter), you distinguish between measure and indicator as you are using them. This is not totally clear. | We discuss this in our Methods chapter.
229 | Castillo, DonnaRae | AHRQ | | | Chapter 2 | On current p. viii where you list your two key questions, I suggest you either put the a/b/c of question 1 with the main part of the question or break out the two parts of question 2 after the word “including” as “a” and “b” in order to be consistent in format with question 1. In other words, question 2 formatted like question 1 would read: 2. What gaps in knowledge about quality measurement are evident from the currently available literature, including: a. Absence of measures or b. Measures lacking evidence of their scientific soundness, whether for the population of cancer patients as a whole or for specific populations. | These were the key questions assigned to us.
230 | Castillo, DonnaRae | AHRQ | | | Chapter 1 | Table 1 is mentioned at top of current p. x as a list of organizations. I am assuming this is the Table 1, now in Chapter 3, that lists the organizations and the measures they are supplying. thus this table should be moved to Chapter 2. Table 1 and Table 2 can be placed at the end of this chapter so as not to interfere with the running text. If this current Table 1 is not the one you reference on p. x, that table needs to be supplied. | We changed the order in which we describe them in the text. We decided to leave Table 2 in the Results section rather than Methods because it reflects findings of the review.
231 | Castillo, DonnaRae | AHRQ | | | Chapter 2 | As noted above, appendixes are numbered in the order cited. As cited in the text of Chapter 2, the order should be: A. Technical Expert Panel and Peer Reviewers B. TEP Worksheet C. Literature Search Strategies (NOTE: This is one appendix, Appendix C, not Appendix C; the individual databases are not C-1, C-2 etc.). D. Contact Form E. Article Screener | Corrected
232 | Castillo, DonnaRae | AHRQ | | | Chapter 2 | At the top of p. xiv, to make more typographically consistent, I suggest you reformat as the end of the sentence just before the bulleted items as follows: | Done
| | | | | | The main search strategy included an extensive list of terms intended to identify research publications associated with all of the following:; - Each of the domains of interest (pain, dyspnea, depression, advance care planning).; - Quality assessment or improvement.; - Quality measurement.
233 | Castillo, DonnaRae | AHRQ | | | Chapter 2 | The hyperlinks on pp. xiv and xv should be removed. (okay to leave the underlining). | Corrected
234 | Castillo, DonnaRae | AHRQ | | | Chapter 3 | Headings should be consistent in wording and format. For example, in the Pain section, one of the headings is “Potential Measures & Measurement Gaps”; in the Dyspnea section, the equivalent heading reads “Potential Measures / Measurement Gaps”; and in the Advance Care section it is just “Potential Measures.” They should all read Potential Measures and Measurement Gaps | Corrected
235 | Castillo, DonnaRae | AHRQ | | | Chapter 3 | As noted above, if the reference to Table 1 is to the Table 1 mentioned in Chapter 2, it needs to be moved and the title should reflect the measure source; for example: Table 1. Sources and attributes of identified measures and indicators | We corrected the names and titles of Table 1 and 2 as suggested.
236 | Castillo, DonnaRae | AHRQ | | | Chapter 3 | Run-in headings should be bold, not italics or parenthesized, and followed by a period. Do not make the beginning of the sentence bold. For example, in the Pain section, the first paragraph under “Measures and Indicators” in Chapter 3, p. xxviii, begins with the following heading and 1st sentence:(Measure - regular assessment of pain) Quality Assessment Tools (QA Tools), proposed in 200062 includes one measure relevant to pain assessment.This is awkward and not according to our required style. It should read:Measure: Regular assessment of pain. Quality Assessment Tools (QA Tools), proposed in 2000,62 includes one measure relevant to pain assessment. All the measure or indicator names would be set up the same way. | Corrected
237 | Castillo, DonnaRae | AHRQ | | | Chapter 3 | Move the name of the second UHC measure on p. xxviii to make it a heading, for typographical consistency. For example: | Corrected
| | | | | | Measure: Routine inpatient pain assessment. (for the first measure)
| | | | | | Measure: Routine inpatient pain assessment with a numeric scale. (for the second measure)
| | | | | | This would apply also on p. xliii to the second ACOVE measure under Treatment of Depression.
238 | Castillo, DonnaRae | AHRQ | | | Chapter 3 | Under the “Treatment” section on p. xxx, the text mentions “3 measures and 1 indicator”; however the text in that section (see pp. xxx and xxxi” presents 2 measures and 2 indicators. This discrepancy must be reconciled; either the intro sentence or a run-in heading is wrong. | Corrected
239 | Castillo, DonnaRae | AHRQ | | | Chapter 3 | Under the “Followup” section of Advance Care Planning, the intro sentence mentions 14 measures in 10 categories and 7 indicators in 8 categories. The 10 general measure categories are easily seen; the indicators are not. For those measures that also that include a similar indicator, we should modify the run-in heading to include the notation. For example the measure noted as “Measure: late life hospital use” includes a similar indicator. Let's change the heading to: Measure/Indicator: Late life hospital use. (or alternatively, but less preferable, Measure and indicator: Late life hospital use.) | Corrected
240 | Castillo, DonnaRae | AHRQ | | | Chapter 3 | In addition, I count 8, not 7, indicators listed within this section as follows (page nos. in parens): 1) late life hospital use (p. xlix) 2) late life ICU use (p. l) 3) late life rate of emergency care (also p. l) 4) new chemotherapy regimen in last 30 days of life (p. li) 5) chemotherapy in last 14 days of life (also p. li) 6) admission to hospice (p. lii) 7) site of death (p. liii) The above 7 are within the “measure” paragraphs; but there is also 8) care consistency with documented care preferences (p liii) | Corrected
| | | | | | If this is correct, please change the intro paragraph to read 8 indicators in 8 categories.
241 | Castillo, DonnaRae | AHRQ | | | Chapter 4 | This should include Discussion as part of the chapter title. | Corrected
242 | Castillo, DonnaRae | AHRQ | | | References | References is the correct title of this section | Corrected
243 | Castillo, DonnaRae | AHRQ | | | Excluded Studies | Since this is one of the last reports under the “old” style guide, it is appropriate to list alphabetically the excluded studies (your current Appendix J as listed in the Contents could fill this need here.) | The excluded studies will be a separate appendix.
244 | Castillo, DonnaRae | AHRQ | | | Appendixes | As noted these should be reordered and numbered in the order of their citation in text. As of now, this is the order of their call-out in the text: A. Technical Expert Panel and Peer Reviewers B. TEP Worksheet C. Literature Search Strategies (NOTE: This is one appendix, Appendix C, not Appendixes C; the individual databases are not C-1, C-2 etc.). D. Contact Form E. Article Screener F. Evidence Tables | Corrected
245 | Castillo, DonnaRae | AHRQ | | | Appendix A: | Please make sure you have permission from the individuals to be listed to include their names in the report. | Permissions granted.
246 | Castillo, DonnaRae | AHRQ | | | Appendix B: | Title should be Appendix C: Literature Search Strategies. | Corrected
247 | Castillo, DonnaRae | AHRQ | | | Evidence Tables | Title should be Appendix F. Evidence Tables. Table titles should be where the distinctions are made. For example: | Corrected
| | | | | | Evidence Table F.1. Quality Measures and Indicators for Supportive Cancer Care: Pain.
248 | Castillo, DonnaRae | AHRQ | | | Other Appendixes | - Perhaps I overlooked them but I could not find any text reference to several appendixes (G–L) currently listed in your Contents table. These appendixes are not here.; - Is the “Cambridge Ballot” necessary?; - I have already mentioned Appendix J above which can become the List of Excluded Studies.; - What is the purpose of separating observational evidence tables currently noted as Appendix L from the others currently noted as Appendix E (which will become App F )? Can these be combined? Why are the “Observational Studies” necessary anyway if they are not discussed?; - Appendix H should be one appendix, not two, entitled Appendix H: Methodological Issues in Measurement or, if you prefer, Appendix H: Reliabiliy,Validity, and Other Measurement Issues. Include the table within the appendix.; - Delete Appendix K. Including peer review comments is unnecessary. This is prepublication information. They belong in your file, not with a published report. | This reviewer received a different version of the report / appendixes from AHRQ.