# Appendix F5. Quality Measures for Cancer Palliation: Measures That Cross All Domains

No. | Measure or Indicator Set/Reference / Year | Description of measure or indicator | Denominator | Numerator | Disease | Patient Characteristics | Setting | Data Source, Reliability, and Validity
Pain, Depression, Dyspnea, and Advance Care Planning
1 | Connor, S. R.^1^ | (Measure) Family evaluation of hospice care | Family members of hospice decedents | Percentage of respondents reporting opportunity for improvement in attention to family needs for support, attending to family needs for information, provision of desired physical comfort and emotional support; and mean overall satisfaction | Mixed hospice population | Adult/Children | Hospice | Family interview / survey
| | | | | | White | | Reliability / Validity not reported
| | | | | | African American
| | | | | | Hispanic
| | | | | | Asian

## Reference List for Appendix F5

1 Connor SR, Teno J, Spence C, Smith N. Family evaluation of hospice care: results from voluntary submission of data over website.