# Appendix A. Technical Expert Panel Members and Peer Reviewers

Table A1 Technical Expert Panel members

[underlined: Name] | [underlined: Institution]
Steve Asch, M.D., M.P.H. | VAGLHS
Marilyn Bookbinder, R.N., Ph.D. | Beth Israel Medical Center
June Dahl, Ph.D. | University of Wisconsin-Madison
Perry Fine, M.D. | University of Utah
Laura Hanson, M.D., M.P.H. | University of North Carolina at Chapel Hill
Jimmie Holland, M.D. | Memorial Sloan Kettering Cancer Center
Joan Teno, M.D., M.S. | Brown Medical School
Jean Kutner, M.D., M.S.P.H. | University of Colorado Health Sciences Center
Charles Cleeland, Ph.D. | UTMD Anderson Cancer Center
Jennifer Malin, M.D. | UCLA School of Medicine, RAND
Molla Donaldson, Dr.P.H., M.S. | National Cancer Institute (Fed Reviewer)
Patricia Ganz, M.D. | UCLA Schools of Medicine and Public Health
Rodger Winn, Ph.D. | National Quality Forum

Table A2 Peer Reviewers

[underlined: Name] | [underlined: Institution]
Adalsteinn Brown, A.B., D.Phil. | University of Toronto
Ellen Stovall | National Coalition for Cancer Survivorship (NCCS)
Eva Grunfeld, M.D., D.Phil. | Cancer Care Nova Scotia
Joanne Wolfe, M.D. | Harvard University-Pediatrics
Judi L. Person, M.P.H. | National Hospice and Palliative Care Organization (NHPCO)
Lindsey Bramwell, M.P.H., R.N., CDR, U.S.P.H.S. | CMS (Fed Reviewer)
Anna Lythgoe, R.N., M.S.N. | VHACO, Office of Quality and Performance
Phil Madvig, M.D. | Kaiser Permanente