# Appendixes

Appendix A. Technical Expert Panel Members and Peer Reviewers

Appendix B. TEP Worksheet

Appendix C. Literature Search Strategies

Appendix D. RAND SCEPC Cancer Quality Measures Project - Measure Developer Contact Form

Appendix E. Cancer Measure Review Article Screener

Appendix F1. Quality Measures and Indicators for Supportive Cancer Care: Pain

Appendix F2. Quality Measures and Indicators for Supportive Cancer Care: Dyspnea

Appendix F3. Quality Measures and Indicators for Supportive Cancer Care: Depression

Appendix F4. Quality Measures and Indicators for Supportive Cancer Care: Advanced Care Planning

Appendix F5. Quality Measures for Cancer Palliation: Measures That Cross All Domains

Appendix G. Peer Reviewer Comments

Appendix H. Excluded Studies