# Summary Tables

Table 1. Characteristics of Studies Eligible for Inclusion in the Review (N = 36)..

Table 2. Summary of Study Results..

Table 3. Type and Number of Outcomes Reported in Studies.

Table 4. Quality of Identified Studies on the Value of the Periodic Health Evaluation..

Table 5. Components Which were Included (or may have been included) in Studies on the Periodic Health Evaluation (N=36).

Table 6. Grading of the Overall Strength of Evidence on the Value of the Periodic Health Evaluation..

Table 7. Comparison of Effect Sizes in Randomized Controlled Trials..

Table 8. Number of Studies (presented in cells) Reporting Outcomes According to Study Design and Direction of Results Reported..

Table 9. Summary of Results from Best Available Evidence to Assess Each Outcome..

Table 1 Characteristics of Studies Eligible for Inclusion in the Review (N = 36)

Characteristics | | n (%)
Study design | Randomized controlled trial | 11 (31)
| Non-randomized controlled trial | 1 (3)
| Prospective cohort | 2 (5)
| Retrospective cohort | 5 (14)
| Cross-sectional | 14 (39)
| Pre-post comparison | 3 (8)
First year study conducted | 1940-1969 | 4 (11)
| 1970-1989 | 9 (25)
| 1990-2005 | 19 (53)
| Not specified | 4 (11)
Country where study conducted | United States | 25 (69)
| United Kingdom | 3 (8)
| Canada | 3 (8)
| Japan | 2 (5)
| Taiwan | 1 (3)
| Denmark | 1 (3)
| Sweden | 1 (3)
Study setting | Urban | 17 (47)
| Suburban | 8 (22)
| Rural | 5 (14)
| Unclear | 18 (50)
Delivery site for PHE | Ambulatory practice office | 16 (44)
| Academic practice | 7 (19)
| Resident/housestaff clinic | 5 (14)
| Hospital outpatient clinic | 4 (11)
| Community health center | 1 (3)
| Health checkup/physical exam clinic | 3 (8)
| Military (not otherwise specified) | 1 (3)
| Employer health clinic | 1 (3)
| Community center | 1 (3)
| Not applicable (observational study with survey design) | 8 (22)
| Not specified | 4 (11)
Physician specialty delivering PHE | Family medicine practice | 10 (28)
| Internal medicine practice | 7 (19)
| General Practice | 6 (17)
| Multispecialty | 1 (3)
| Not specified | 4 (11)
| Not applicable (observational study with survey design) | 8 (22)
Health plan under which PHE delivered | National health system (non-U.S. studies) | 10 (28)
| Medicare | 4 (11)
| Employer health plan | 4 (11)
| Staff model health maintenance organization | 2 (5)
| Other managed care plan | 2 (5)
| Veterans Affairs or other U.S. Department of Defense health plan | 1 (3)
| Not specified or mixed (surveys, or NOS) | 15
Subject of study | Patient
| Not otherwise specified | 31 (86)
| Employee or executive | 8 (22)
| Medical Providers
| Family practitioners | 8 (22)
| General internists | 5 (14)
| General practitioners | 4 (11)
| Medical trainees (fellows, residents/house staff, medical students) | 3 (8)
| Nurses or nurse practitioners | 3 (8)
| Internists | 2 (5)
| Physicians' assistants | 1 (3)
| Health providers, not otherwise specified | 1 (3)
| Obstetricians/gynecologists | 0 (0)
| Medical specialist/subspecialist physicians | 0 (0)
| Physicians, not otherwise specified | 0 (0)
| Office staff | 0 (0)

PHE = periodic health evaluation.

Percents may not add to 100. Reviewers were able to give multiple answers to many of the questions.

Table 2 Summary of Study Results

Author, year | Year Study Began | Years (months of follow up) | Study population | Intervention Group | Comparison Group | Interventions outside of the PHE | Outcome(s) Assessed | Definition of PHE in this study | Study Limitations
Randomized Controlled Trials
Patrick, 1999 ^53^ | 1993 | 48 months (2 years after intervention) | The study population consisted of 2,558 HMO enrollees in Seattle, WA. Medicare demonstration project. | The intervention group included Group Health Comparative of Puget Sound Medicare enrollees invited to receive preventive services benefits package for two years. | The comparison group consisted of Medicare enrollees receiving usual care. | | 1. Immunization - influenza | The PHE was described as a preventive service package that include - 1) health-risk assessment (telephone interview); 2) health-promotion visit (90 minute nurse visit with health risk appraisals, positive behavior reinforcement and referrals for interventions where appropriate); 3) disease-prevention visit (by nurse and physician who conducted history and physical examination and reviewed patients' health risks) and 4) follow-up classes (exercise, planning ahead). Counseling on exercise, high fiber/low fat diet and advance directives offered to all. | Internal Validity Concerns:
| | | | Uptake of PHE: 90% attended health promotion and disease prevention visits year 1; 83% attended health promotion and disease prevention visits in year 2; 78% had visits in both years,; 9% attended none in any year; 24% attended any classes. | | | 2. Health habits - improvement in: | Counseling on exercise, high fiber/low fat diet and advance directives offered to all. | 1. Reporting on blinding
| | | | | | | - Physical activity | Health promotion visit and disease prevention visits and group exercise were offered in both years. | External Validity Concerns:
| | | | | | | - Diet (fat and fiber) | | 1. Description of outcomes not detailed
| | | | | | | - Advance directives | | 2. Results potentially not generalizable beyond Medicare recipient population
| | | | | | | - Breast self-exam | | Statistical Validity Concerns:
| | | | | | | - Smoking | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | - Alcohol
| | | | | | | - Seat belt use
| | | | | | | 3. Patient attitudes - mean score health worry^‡^
| | | | | | | 4. Body mass index - at risk for obesity, 24-month F/U
| | | | | | | 5. Costs - average total cost per participant
| | | | | | | 6. Mortality
| | | | | | | - Mortality at 24 months
| | | | | | | - 48 months
Elder, 1995 ^54^ ; Mayer, 1994 ^90^ | 1992 | 48 months (2 years after intervention completion) | The study population consisted of 1,203 HMO enrollees in San Diego, CA. Medicare demonstration project. | The two-year intervention consisted of Medicare beneficiaries receiving a health risk appraisal with individual counseling and health promotion workshops. | The comparison group received usual care. | | 1. Health habits | The PHE was described as preventive services through a health risk appraisal with individual counseling, selected clinical tests and immunizations, and a series of 8 weekly group health promotion sessions (memory, mental alertness, coping with loss, choices for independent living, self-enhancement, exercise, nutrition, relaxation, self-care). | Internal Validity Concerns:
| | | | Uptake of PHE: 96% completed health risk appraisal and individual counseling; 87% attended at least one group session, 72% attended at least 4, 59% attended at least 6. | | | - Fiber servings per day | Individual counseling was continued during year 2. | 1. Reporting on differences between enrollees and non-enrollees
| | | | | | | - Fat servings per week | | 2. Reporting on blinding
| | | | | | | - Salt use | | 3. Reporting on withdrawals or crossovers
| | | | | | | - Caffeine drinks per day | | External Validity Concerns:
| | | | | | | - Stretching minutes per week | | 1. Results potentially not generalizable beyond Medicare recipient population
| | | | | | | - Consumption of cruciferous foods
| | | | | | | 2. Blood pressure
| | | | | | | - Mean systolic blood pressure at 12 months
| | | | | | | - Mean diastolic blood pressure at 12 months
| | | | | | | 3. Body mass index
| | | | | | | - Mean BMI at 24 months (end of intervention period)
| | | | | | | - Mean BMI at 48 months (end of F/U)
Morrissey, 1995 ^55^ | 1988 | 12–26 months after beginning of intervention (for cost outcomes, 3 years after beginning of intervention - 1 year after intervention completion) | The study population consisted of 1914 patients from 10 primary-care medical practices in central North Carolina. Medicare demonstration project. | The intervention group received full Medicare reimbursement to physicians for preventive care and health promotion packages, regular reminding of physicians to routinely schedule preventive care visits, a new office system in which nurse carried out many preventive procedures, and a form for charting preventive care. Duration of intervention was two years. | The comparison group received usual care. | [underlined: Intervention Group:] | 1. Pap smear | The PHE was described as a preventive care visit offered once a year including a breast exam, eye exam, pap smear, hearing test, depression test, influenza & pneumovax immunization, cholesterol test, fecal occult blood test, urinalysis and a urinary incontinence test. One hour health promotion sessions were conducted every 6 months for physical activity, nutrition, stress management/problem solving and others based on risk. | External Validity Concerns:
| | | | Uptake of the PHE: 88% received at least one clinical screening; 87% received at least one health promotion service. | | Patients: | 2. Immunization - influenza | | 1. Results potentially not generalizable beyond Medicare recipient population
| | | | | | 1. written materials | 3. Cholesterol screening
| | | | | | 2. phone call | 4. Colon cancer screening - fecal occult blood testing
| | | | | | Providers: | 4. Mammogram
| | | | | | 1. annual capitated payments for preventive care and health promotion visits | 5. Costs
| | | | | | 2. prompting to schedule preventive care visits | - 3-year post-intervention cumulative Medicare charges.
| | | | | | 3. office system change for nurse delivery of preventive services | - 3-year post-intervention cumulative Medicare reimbursement
| | | | | | 4. form for charting preventive care | 6. Hospitalization
| | | | | | | - Utilization data: hospital days per enrollee over two years of intervention and one year post-intervention
| | | | | | | - Admissions per enrollee over two years of intervention and one year post-intervention
Burton, 1995 ^56^ ; German, 1995 ^79^ ; Burton, 1997 ^80^ ; Burton, 1995 ^78^ Burton, 1995; German, 1995; Burton, 1997; | 1989 | 24 months after beginning of intervention and for some outcomes 48 months after beginning of intervention (2 years after end of intervention) | The study population consisted of 4,195 older, community-dwelling Medicare recipients in Baltimore. Medicare demonstration project. | The intervention group received coverage for an annual preventive visit and tests (Medicare vouchers for 2 yearly preventive visits and optional counseling visits). | The comparison group received no coverage for an annual preventive visit and tests. | [underlined: Intervention Group:] | 1. Pap smear | The PHE was described as a physical examination. The examination included a breast, pelvic (including Pap smear), and digital rectal exam, fecal occult blood testing, cholesterol testing, immunizations, counseling for health risks, and a complete history including vision, hearing, and dentition. | Internal Validity Concerns:
| | | | Uptake of the PHE: 63% made preventive visit year 1; 52% counseling visit year 1; 52% preventive visit year 2; 33% counseling visit year 2. | | Patients: | 2. Health habits | | 1. Reporting on blinding
| | | | | | 1. Written material | - Smoking | | External Validity Concerns:
| | | | | | | - Problem alcohol drinking | | 1. Results potentially not generalizable beyond Medicare recipient population
| | | | | | | 3. Health status - change in health status of intervention and control groups from baseline to 2 years
| | | | | | | 4. Costs
| | | | | | | - Total health care charges, Year 1.
| | | | | | | - Total health care charges, Year 2.
| | | | | | | - Mean monthly Medicare Part A charges, Year 1
| | | | | | | - Mean monthly Medicare Part A, charges Year 2
| | | | | | | - Mean monthly Medicare Part A charges Year 3 (1 year post-intervention)
| | | | | | | - Mean monthly Medicare Part A charges Year 4 (2 years post-intervention)
| | | | | | | 5. Hospitalization
| | | | | | | - Mean inpatient days for the intervention and control groups who had a hospital discharge in that year (Year 1)
| | | | | | | - Mean inpatient days Year 2
| | | | | | | - Hospital discharges per 1000 Year 1
| | | | | | | - Hospital discharges per 1000 Year 2
| | | | | | | 6. Mortality
Norman, 1992 ^60^ | 1992* | | The study population consisted of 818 patients from one general practice in Norfolk, England aged 30 to 41. | The intervention group consisted of patients who received an invitation letter with an appointment for a health check. | | [underlined: Intervention Group:] | 1. Receipt of PHE - attendance of PHE | The PHE was described as a health check that included the assessment of smoking behavior, alcohol consumption, diet and exercise levels, blood pressure and weight. | External Validity Concerns:
| | | | The intervention group also included patients who received an open invitation letter to health | | Patients: | | | 1. Description of study population characteristics not detailed
| | | | | | 1. Written material | | | Statistical Validity Concerns:
| | | | | | [underlined: Control Group:] | | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | Patients:
| | | | | | 1. Written material
Belcher, 1990 ^44^ | 1981 | 60 months | The study population consisted of 1,224 male patients who attended the Seattle Veterans Affairs Medical Center during October to December 1980. (We included 674 patients in the study who either attended a health promotion clinic or received usual care. Other groups received other interventions) | The intervention group was offered self-referral to a health promotion clinic. | The comparison group received usual care. | [underlined: Intervention Group:] | 1. Counseling | The PHE was described as a physical examination similar to USPSTF recommended activities. Included history and physical examination items (alcoholism screen, smoking assessment, blood pressure check, breast examination); laboratory testing (fecal occult blood, cholesterol, tuberculin skin test, VDRL, Pap smear and mammography); tetanus/diphtheria and influenza vaccination, and counseling on breast self-examination and alcoholism and smoking cessation. | Internal Validity Concerns:
| | | | Uptake of the PHE: 71% participated in health promotion clinic in year 1; 78% participated in health promotion clinic in year 1 or year 2; 90% attending in year 1 returned for year 2 | | Patients: | - Alcohol abuse | | 1. Reporting on blinding
| | | | | | 1. Written material | - Smoking cessation | | External Validity Concerns:
| | | | | | 2. Phone call | 2. Immunization - influenza | | 1. Description of study population not detailed
| | | | | | | 3. Colon cancer screening - fecal occult blood testing | | 2. Results potentially not generalizable beyond Veterans Affairs (male) population
Stone, 1981 ^57^ ; South-east London, 1977 ^7^ ; South-east London, 2001 ^76^ ; Stone, 1978a ^91^ ; Stone, 1978b ^92^ ; Trevelyan, 1973 ^93^ | 1967 | 60–108 months | The study population consisted of 7229 patients in South-east London aged 40 to 64 years in 1967 receiving care in primary care group practices. | The intervention group were South London patients aged 40 to 64 years in specific group practices; received 2 multiphasic screenings 2 years apart. | The comparison group consisted of South London patients aged 40 to 64 years in specific group practices; received usual care. | | 1. Disease detection | The PHE was described as multiphasic screening. Screening for ischemic heart disease, elevated blood pressure, chronic bronchitis, diabetes, thyroid imbalance, arthritis, obesity, venous varicosities, hearing and visual defects. (PFTs, ECG, blood pressure, serum cholesterol, uric acid, fecal occult blood), abdominal exam, leg exam, breast and pelvic exam, chest x-ray, height, weight and skin fold, vision and audiometry testing, skin, mouth, teeth and joint exams | Internal Validity Concerns:
| | | | Uptake of the PHE: 73% participated in first year screening; 99% of these had both physical exam and clinic tests | | | - Angina | | 1. Reporting on blinding
| | | | | | | - High diastolic blood pressure | | External Validity Concerns:
| | | | | | | - Ischemia on electrocardiogram | | 1. Study performed before USPSTF or similar contemporary preventive services guidelines in effect
| | | | | | | - Bronchitis symptoms | | Statistical Validity Concerns:
| | | | | | | 2. Health habits - percentage still smoking | | 1. Differences in control and treatment group at baseline not specifically accounted for in analysis
| | | | | | | 3. Disability - major disability (e.g., inability to dress or undress themselves) | | 2. Incomplete presentation of statistical significance
| | | | | | | 4. Hospitalization - hospitalizations/ 1000 person years at risk (1976)
| | | | | | | 5. Mortality mortality rate per 1000 person-years at risk:
| | | | | | | - All cause death
| | | | | | | - Neoplasm
| | | | | | | - Central nervous system
| | | | | | | - Cardiovascular disease
| | | | | | | - Respiratory disease
| | | | | | | - All other causes
Fletcher, 1977 ^45^ | 1974 | Outcomes (disease detection) measured directly after multiphasic screening visit. | The study population consisted of 112 patients 40 to 65 years old seen by 112 physicians. Physicians randomized to receiving results of multiphasic screening program versus reviewing prepared chart abstract versus reviewing actual chart | The intervention group consisted of patients who received multiphasic screening. | The first comparison group was the medical chart abstraction group (physicians given abstracted information about patients from chart). | | 1. Disease detection | The PHE was described as multiphasic screening that included a standard questionnaire, measurement of blood pressure, height, weight, visual acuity, tonometry, audiometry, blood leukocyte count, hematocrit and hemoglobin levels, serologic levels for syphilis, biochemistry of random blood specimen, urinalysis, ECG, and chest roentgenogram. The pHE also included clinical breast examination, pap smear and vital capacity. | Internal Validity Concerns:
| | Charts were reviewed at 12 months to assess follow-up of new problems | | Uptake of the PHE: Not mentioned, but by design, all intervention group participants would have received the multiphasic screening. | In the second comparison group, physicians reviewed the patient's actual chart. | | - Disease detection of ALL problems before and after intervention (number of new medical problems detected at F/U) | | 1. Reporting on blinding
| | | | | | | - Disease detection of important problems before and after intervention | | External Validity Concerns:
| | | | | | | | | 1. Study performed before USPSTF or similar contemporary preventive services guidelines in effect
| | | | | | | | | 2. Description of study population not detailed
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
Cutler, 1973 ^41^ ; Collen, 1973 ^47^ ; Dales, 1973 ^94^ ; Ramcharan, 1973 ^95^ ; Friedman, 1986 ^9^ ; Dales, 1979 ^96^ ; Norinder, 2002 ^97^ | 1964 | 84–192 months | The study population consisted of 10,713 randomly selected California Kaiser Health Plan members in 1964, age 35–54. | The intervention group consisted of California Kaiser Health Plan members aged 35–54 encouraged to have an annual multiphasic check-up for 11 years. | The comparison group consisted of California Kaiser Health Plan members aged 35–54 who received usual care. | [underlined: Intervention Group:] | 1. Costs | The PHE was described as an annual multiphasic health check-up (MHC) consisting of a multiphasic exam (which is a series of tests performed in the automated multi-test lab), and a follow-up evaluation of from multiphasic exam. The multiphasic exam included a standard questionnaire including history and present symptoms questions, measurement of blood pressure, visual acuity, tonometry, audiometry, urinalysis, ECG, and chest & breast x-rays,. The MHC also included anthropometry, spirometry, and a serum chemistry panel. | Internal Validity Concerns:
| | | | Uptake of the PHE: 54% of intervention group received at least 4 PHEs over 7 years, 83% received at least one PHE over 7 years | Uptake of the PHE: 13% of intervention group received at least 4 PHEs over 7 years, 53% received at least one PHE over 7 years | Patients: | - Average annual cost for physician visit per participant at 7 years (men, aged 45–54 years at baseline) | | 1. Reporting on blinding
| | | | | | 1. Written Material | - Average annual cost for physician visit per participant at 11 years (men, aged 45–54 years at baseline) | | External Validity Concerns:
| | | | | | 2. Reminder | - Average annual expense per participant in multiphasic health check-up expense at 7 years. (men, aged 45–54 years at baseline) | | 1. Study performed before USPSTF or similar contemporary preventive services guidelines in effect
| | | | | | 3. Phone calls | - Average annual expense per participant in multiphasic health check-up expense at 11 years. (men, aged 45–54 years at baseline) | | Statistical Validity Concerns:
| | | | | | | 2. Disability | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | - Disability at 7 years
| | | | | | | - Disability at 11 years among men aged 45–54
| | | | | | | 3. Mortality
| | | | | | | Deaths, rate per 1000 persons
| | | | | | | - All cause deaths
| | | | | | | - Death from potentially postponable causes^¶^
| | | | | | | - Death from colorectal cancer
| | | | | | | - Death from breast cancer (women only)
| | | | | | | - Death from cervical/uterine cancer (women only)
| | | | | | | - Death from prostate cancer (men only)
| | | | | | | - Death from hypertension-associated causes
| | | | | | | - Death from ischemic heart disease
| | | | | | | - Death from respiratory system disease.
| | | | | | | - Death from musculoskeletal disease
| | | | | | | - Death from mental, nervous, or sensory organ disease
| | | | | | | - Death from endocrine, nutritional, and metabolic disease
| | | | | | | - Death from suicide
| | | | | | | - Death from lymphohematopoetic cancer
Theobald, 1998 ^58^ | 1969 | 20 years | The study population consisted of 32, 186 patients aged 18–65. | The intervention group consisted of Stockholm residents aged 18–65 who were offered a general health examination. | The comparison group were Stockholm residents aged 18–65 who received usual care. | | 1. Mortality | The PHE was described as a general health examination that included social, psychiatric, and medical interviews and exams to determine social and medial needs. Also, blood tests, physical examinations, ECGs, exercise tests, psychological tests and eye and dental examinations. | Internal Validity Concerns:
| | | | Uptake of PHE: 2578/3064 (84%) of those offered the PHE were examined. | | | - All cause mortality | | 1. Reporting on differences between participants and non-participants
| | | | | | | - Cardiovascular disease mortality | | 2. Reporting on blinding
| | | | | | | - Cancer mortality | | 3. Description of PHE is not detailed
| | | | | | | - Accidents and intoxication mortality | | External Validity Concerns:
| | | | | | | | | 1. Description of study population characteristics not detailed
| | | | | | | | | 2. Study performed before USPSTF or similar contemporary preventive services guidelines in effect
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
OXCHECK, 1995 ^59^ ; Langham, 1996 ^81^ ] | 1989 | 36 months | The study population consisted of 11,090 patients aged 35 to 64 from 5 general practices in Bedfordshire, England. | The intervention group received a health check at baseline (year 1) and in year 4. | The comparison group received no health check at baseline but received a health check in year 4. | [underlined: Intervention Group:] | 1. Health habits | The PHE was described as a health check and consisted of medical history, lifestyle questionnaire, measurements of height, weight, blood pressure, and serum cholesterol levels, and post-visit counseling. | Internal Validity Concerns:
| | | 4,908 patients receiving PHE n year 1, year 4 (intervention group) and in year 4 (control group) comprise the study population for this analysis. | Uptake of the PHE: Of the 2205 receiving PHE in year 1, 75% received PHE in year 4 | | Patients: | - Smoking | | 1. Reporting on blinding
| | | | | | 1. Written Material | - Alcohol use | | Statistical Validity Concerns:
| | | | | | 2. Reminder | - Exercise less than once per month | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | 3. Phone call | - Use full cream milk
| | | | | | 4. Encouragement to make a visit during other healthcare visits | - Use butter or hard margarine
| | | | | | [underlined: Control Group:] | 2. Blood pressure
| | | | | | Patients: | - Systolic blood pressure at 3-year follow up
| | | | | | 1. Written Material | - Diastolic blood pressure at 3-year follow up
| | | | | | 2. Reminder | - Proportion of high risk diastolic pressure (≥100mm Hg) from 3 year F/U when compared to control
| | | | | | 3. Phone call | 3. Changes in serum cholesterol
| | | | | | 4. Encouragement to make a visit during other healthcare visits | - Mean total cholesterol at 3-year F/U
| | | | | | | - Proportion of high risk cholesterol (≥8mmol/l) at 3 year F/U
| | | | | | | 4. Body mass index
| | | | | | | - Mean BMI at 3-year F/U
| | | | | | | - Percentage of participants with BMI ≥ 30
| | | | | | | 5. Cost-effectiveness
Non-randomized Controlled Trials
Christensen, 1995 ^84^ | 1990 | | The study population consisted of 2,452 patients of 65 general practitioners. | The intervention group consisted of Denmark patients of general practitioners who received mailing that a preventive health examination was free. | The comparison group were Denmark patients of general practitioners who received mailing that a preventive health examination was 40 Danish Krone. | [underlined: Intervention Group:] | 1. Receipt of PHE - attendance at PHE | The PHE in this study was described as a preventive health examination. | External Validity Concerns:
| | | | | | Patients: | | | 1. Description of PHE is not detailed
| | | | | | 1. Written material
| | | | | | 2. Financial disincentive (charge)
| | | | | | [underlined: Control Group:]
| | | | | | Patients:
| | | | | | 1. Written material
| | | | | | 2. Financial disincentive (charge)
Prospective Cohorts
Roberts, 1969 ^62^ | 1950 | 180 months | The study population consisted of 20,648 male patients who had employee-sponsored periodic health exams. | The intervention group consisted of U.S. employed men receiving a employer-sponsored periodic health examination. | The comparison group consisted of a historical comparison of U.S. white men. | | 1. Mortality - actual/expected deaths | The PHE was described as a periodic health exam that included a health history, and a thorough physical examination supplemented by laboratory, x-ray, and ECG studies. | External Validity Concerns:
| | | | | | | | | 1. Study performed before USPSTF or similar contemporary preventive services guidelines in effect
| | | | | | | | | 2. Results potentially not generalizable beyond persons who are non-White men
Chiou, 2002 ^83^ | 1993 | 6 years | The study population consisted of a sample of 1,193 elderly people in each of the 11 districts in Kaohsiung City, Taiwan. | The intervention group consisted of Taiwanese adults aged 65 years and older reporting receiving a physical examination in past year. | The comparison group were Taiwanese adults aged 65 and older not receiving physical examination in past year | | 1. Mortality - Relative risk of mortality | The PHE was defined as an annual physical exam that included measurements of weight, height, blood pressure, pulse, visual acuity, oral health, and hearing. A PHE also included urine, fecal occult blood, fasting blood lipids, and glucose laboratory tests. | External Validity Concerns:
| | | | | | | | | 1. Results potentially not generalizable beyond elderly Taiwanese.
Retrospective Cohorts
Burton, 2002 ^29^ | 1989 | 3 years | The study population consisted of 1,773 Bank One executives who were enrolled in the Bank Medical Plan, or a preferred provider plan. | The intervention group consisted of executives that were eligible for and receiving the periodic health examination. | The comparison group consisted of executives eligible for but not participating in the periodic health examination. | | 1. Costs - average cost in medical claims paid per employee | The PHE was described as a complete history and physical examination, fasting laboratory tests including multiphasic chemistries (blood count etc), lipid profile, total cholesterol, HDL-cholesterol, calculated LDL-cholesterol, dipstick urinalysis, resting 12 lead-electrocardiogram, pulmonary function testing and vision and glaucoma screening. | Internal Validity Concerns:
| | | | | | | 2. Disability | | 1. Use of claims data not specified for research purposes
| | | | | | | - Average number of short-term disability days per employee | | External Validity Concerns:
| | | | | | | - Total short-term disability days in 3 years | | 1. Results potentially not generalizable beyond executive employees
| | | | | | | - Any short-term disability days (%)
Hama, 2001 ^77^ | 1999 | 12 months | The study population consisted of 240 employees of the Japan Maritime Self-Defense Force working on the Iwo Jima military defense base. | The patients in the intervention group received a pre-assignment medical exam 1 year before their assignment. | The patients in the comparison group didn't receive a pre-assignment medical exam 1 year before their assignment. | | 1. Disease detection | The PHE was defined as an annual health examination including analysis of height, body weight, blood pressure, BMI, chest radiography, electrocardiography, vital capacity, serum chemistry, stool samples, and urine samples. | External Validity Concerns:
| | | | | | | - Cardiac arrhythmia | | 1. Results potentially not generalizable beyond Japanese males.
| | | | | | | - Neurological problems | | Statistical Validity Concerns:
| | | | | | | Hyperlipidemia | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | - GI ulcers
| | | | | | | Hypertension
| | | | | | | - Severe obesity (BMI >28.6 kg/m^2^)
| | | | | | | - Proteinuria
| | | | | | | 2. Blood pressure
| | | | | | | - Mean systolic blood pressure
| | | | | | | - Mean diastolic blood pressure
| | | | | | | - Proportion of hypertension
| | | | | | | 3. Changes in serum cholesterol levels
| | | | | | | - Mean total cholesterol
| | | | | | | - Mean LDL cholesterol
| | | | | | | - Mean triglycerides
| | | | | | | - Mean HDL cholesterol
| | | | | | | - Proportion of hyperlipidemia
| | | | | | | 4. Body mass index
| | | | | | | - Mean BMI;
| | | | | | | - Proportion of severe obesity (BMI ≥ 28.6)
Freedman, 2000 ^16^ | 1995 | 18 months | The study population consisted of 136 community-dwelling patients aged 70 and older. | The intervention group included patients who received a periodic health examination. | The comparison group received no periodic health examination and attended clinic 3 or more times. | [underlined: Intervention Group:] | 1. Immunization | The PHE in this study included screening for smoking, alcohol, influenza vaccination, tetanus vaccination, exercise, nutrition, blood pressure, hearing, and vision. | Internal Validity Concerns:
| | | | | | Providers: | - Received influenza vaccine | | 1. Reporting on differences between enrollees and non-enrollees
| | | | | | 1. Chart-based reminders | - Received tetanus vaccine | | External Validity Concerns:
| | | | | | | | | 1.Description of study inclusion/exclusion criteria not detailed
| | | | | | | | | 2. Description of study population characteristics not detailed
| | | | | | | | | 3. Description of PHE is not detailed
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | | | 2. Incomplete presentation of statistical significance
Williams,1998 ^65^ | 1998* | 12 months | The study population consisted of 50 adult patient's medical records before and 50 after intervention in each of 60 primary care practices. | The intervention group consisted of patients who received a Health Maintenance Exam (HME) and interacted with a touch-sensitive computer system (TSCS), which provided patient-specific preventive service recommendations. | The comparison group consisted of patients who had an HME and did not use a TSCS. | [underlined: Intervention Group:] | 1. Pap smear | The PHE, called a HME in this study, was defined as an office visit specifically for a physical exam, breast examination, pap smear, and pelvic examination, or annual check-up. | Internal Validity Concerns:
| | | The study population also consisted of 507 touch-sensitive computer system users. | | | Patients: | 2. Colon cancer screening | | 1. Reporting on differences between enrollees and non-enrollees
| | | | | | 1. touch-sensitive computer system | - Flexible sigmoidoscopy | | External Validity Concerns:
| | | | | | Providers: | - Fecal occult blood test | | 2. Description of study population characteristics not detailed
| | | | | | 1. touch-sensitive computer system | 3. Mammogram | | 3. Description of PHE is not detailed
| | | | | | [underlined: Control Group:] | | | Statistical Validity Concerns:
| | | | | | Patients: | | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | 1. touch-sensitive computer system | | | 2. Incomplete presentation of statistical significance
| | | | | | Providers:
| | | | | | 1. touch-sensitive computer system
Bernacki, 1988 ^28^ | 1983 | 36 months | The study population consisted of 710 male executives of a multinational US corporation. | The intervention group consisted of corporation executives that were eligible for periodic physical exam (PPE) and receiving 3 PPEs during 3-year study period. | The comparison group consisted of corporation executives eligible for PPE and not receiving a PPE during the 3-year study period. | | 1. Costs - health care claims cost per capita in Year 3 | The PHE was described as a periodic physical examination that included a medical history, physical examination, visual acuity testing, resting electrocardiogram, multiple lab studies, audiometry, cervical cytology, chest radiograph, proctosig-moidoscopy, tonometry, pulmonary function test, maximal exercise electrocardiography, and a barium enema. | Internal Validity Concerns:
| | | | The second intervention group were corporation executives eligible for PPE and receiving 1 or 2 PPEs during 3-year study period | | | | | 1. Reporting on withdrawals
| | | | | | | | | 2. Standard/valid reporting of outcomes
| | | | | | | | | External Validity Concerns:
| | | | | | | | | 1. Description of study population characteristics not detailed
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
Grimaldi, 1965 ^61^ | 1956 | 96 months | The study population consisted of 194 employees. | The intervention group consisted of corporation middle management employees opting to participate in a periodic physical examination (PPE). | The first comparison group consisted of corporation middle management employees opting not to participate in PPE. | | 1. Costs - mean medical expense per claim | The PHE was described as a preventive health examination that included a thorough self-administered health inventory questionnaire, a physical examination, a 14 × 17 x-ray film of the chest, audiometric testing, visual acuity, tonometry, 12-lead ECG, urinalysis for albumin and sugar, hematocrit and microscopic study of the blood smear, blood sugar determination, and a protoscopic examination when indicated. | External Validity Concerns:
| | | | | The second comparison group were employees from another site not offered the PPE. | | | | 1. Study performed before USPSTF or similar contemporary preventive services guidelines in effect
| | | | | | | | | 2. Description of study population characteristics not detailed
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | | | 2. Incomplete presentation of statistical significance
Cross-sectional Studies
Lin, 2004 ^73^ | 1997 | | The study population consisted of 21,025 patients who visited the outpatient department from 1997 through 2000. (NHAMCS data) | Patients receiving an outpatient department visit including a nurse practitioner defined the Intervention group. | Patients receiving an outpatient visit not including a nurse practitioner defined the comparison group. | | 1. Counseling | The PHE was defined as a non-illness care visit to the outpatient department. | External Validity Concerns:
| | | | | | | - Diet counseling | | 1. Data from pediatric outpatient clinics included
| | | | | | | - Injury prevention counseling | | 2. Study not specifically designed to address Key Question
| | | | | | | - Physical activity counseling | | Statistical Validity Concerns:
| | | | | | | - Safe sexual practices counseling | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | - Tobacco use counseling
Flocke, 2004 ^74^ ; Eaton, 2002 ^98^ | 1994 | | The study population consisted of 2,670 adult outpatients, visiting 138 family physicians in 84 practices from October 1994 through August 1995 in Northeast Ohio. | The intervention group included patients who were seen by a health care professional for well care. | The first comparison group included patients who were seen for chronic illness. | | 1. Counseling | The PHE was defined as a well care visit with a health care professional. | Internal Validity Concerns:
| | | | | The second comparison group included patients who were seen for acute illness. The last comparison group included patients who were seen for things other than chronic illness, acute illness or well care. | | - Patient diet advice recall | | 1. Reporting on differences between enrollees and non-enrollees
| | | | | | | - Patient smoking counseling recall | | External Validity Concerns:
| | | | | | | - Physical activity patient recall | | 1. Study not specifically designed to address Key Question
| | | | | | | - Nutritional counseling—univariate analysis | | Statistical Validity Concerns:
| | | | | | | total n = 3475 | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | - Nutritional counseling—multivariate analysis
| | | | | | | total n = 3475
Finkelstein, 2002 ^67^ | 1994 | | The study population consisted of 2,232 women aged 20 and older who were residents in Ontario, Canada that completed the National Population Health Survey reporting their use of annual examinations with answers linked to their use of services in a national health insurance plan | The intervention group received an annual health examination/ preventive screening. | The comparison group received no annual health examination/preventive screening. | | 1. Pap smear | The PHE was defined as an annual or periodic health examination by a healthcare professional. | Internal Validity Concerns:
| | | | | | | 2. Cholesterol screening | | 1. Data obtained from questionnaire, results subject to recall bias
| | | | | | | 3. Mammogram | | External Validity Concerns:
| | | | | | | | | 1. Description of study population characteristics not detailed
| | | | | | | | | 2. Results potentially not generalizable beyond female population
Hahn, 1999 ^66^ | 1995 | | The study population consisted of an audit of the computerized billing data of 75,621 cross-sectional audit of outpatient billing claims for adults seen at least once by a primary care provider in 1995, classified by visit type (visits for preventive care vs. acute care). | The first intervention group received preventive services with only HMO insurance | The first comparison group did not receive preventive services with HMO insurance. | | 1. Pap smear | The PHE was defined as a physical exam or preventive services. | External Validity Concerns:
| | | | The other intervention group received preventive services with only FFS insurance. | The second comparison group did not receive preventive services with FFS insurance. | | 2. Immunization - tetanus | | Description of study population characteristics not detailed
| | | | | | | 3. Cholesterol screening | | Study did not provide information on level of insurance for the PHE and screening tests in HMO and FFS plans
| | | | | | | 4. Colon cancer screening | | Statistical Validity Concerns:
| | | | | | | - Sigmoidoscopy | | Potentially inadequate adjustment for residual confounding
| | | | | | | - Fecal occult blood testing
| | | | | | | 5. Mammogram
Tao, 2001 ^64^ | 1997 | | The study population consisted of data on women age >18 years from the 1997 National Ambulatory Medical Care and National Hospital Ambulatory Medical Care Surveys in which physicians completed forms describing reasons for ambulatory visits (including general medical visits or gynecological) and the receipt of preventive services | The intervention group received general medical or gynecologic exam as defined by either physician or patient. | The comparison group received non-general medical or gynecologic exam visits as defined by both patient and physician. | | 1. Pap smear | The PHE was defined as a general medical examination, gynecologic exam, or periodic health examination. | Internal Validity Concerns:
| | | | | | | 2. Counseling - family planning or contraceptive given | | 1. Data obtained from questionnaire, results subject to recall bias
| | | | | | | 3. Mammogram | | External Validity Concerns:
| | | | | | | | | 1. Study not specifically designed to address Key Question
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
Parchman,2001 ^69^ | 1996 | | The study population consisted of 1,409 Mexican American El Paso County, Texas residents, aged 18 to 64 years of age participating in a telephone and door-to door survey designed to assess access to and use of ambulatory health care | The intervention group reported they had received a check-up in the past year. | The comparison group reported they hadn't received a check-up in the past year. | | 1. Pap smear | The PHE was defined as a check-up or visit to a healthcare professional. | Internal Validity Concerns:
| | | | | | | 2. Cholesterol screening in past 5 years | | 1. Data obtained from questionnaire, results subject to recall bias
| | | | | | | 3. Mammogram | | External Validity Concerns:
| | | | | | | | | 1. Study not specifically designed to address Key Question
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
Nutting, 2001 ^75^ | 1991 | | The study population consisted of 1,138 patient-visits by 93 physicians in the Ambulatory Sentinel Practice Network, in 50 community-based practices. Physicians were surveyed to recall the content of nonacute care visits with women age 40–75 years seen in their practices. | The intervention group had an annual examination. | The comparison group had a routine chronic are visit. | | 1. Mammogram | The PHE was described as a routine annual examination that didn't included visits for chronic care, intercurrent illness, emergent conditions, or injuries. | Internal Validity Concerns:
| | | | | | | | | 1. Data obtained from questionnaire, results subject to recall bias
| | | | | | | | | External Validity Concerns:
| | | | | | | | | 1. Description of PHE is not detailed
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
Stange, 2000 ^42^ | 1994 | | The study population consisted of 4,049 patient-visits in the offices of 138 family physicians in North-east Ohio. | The intervention group was described by well care visits. | The comparison group was described by illness visits. | | 1. Counseling | The PHE was described as preventive services that consisted of screening, health habit counseling, and immunization services. | External Validity Concerns:
| | | | | | | - Mean % (SD) receipt of USPTF health habits counseling | | 1. Description of study inclusion/exclusion criteria not detailed
| | | | | | | - Mean % (SD) receipt of cancer-related health habits counseling | | Statistical Validity Concerns:
| | | | | | | 2. Immunization | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | - Mean % receiving USPSTF recommended vaccinations | | 2. Incomplete presentation of statistical significance
Faulkner, 1997 ^22^ | 1991 | | The study population consisted of 34,236 adults aged 18 to 64 from the Centers for Disease Control's 1991 Behavioral Risk Factor Surveillance System studied to assess the association of health insurance coverage with the receipt of preventive services. | The intervention consisted of a Behavioral Risk Factor Surveillance Survey 1991: All preventive services covered by health plan. | The first comparison group consisted of patients having most preventive services covered by a health plan. | | 1. Receipt of PHE odds of receiving check-up according to level of health insurance compared to no health insurance coverage | The PHE was defined as a period health exam where a patient has receipt of recommended services within the periodicity schedules recommended for specific age/gender groups. | Internal Validity Concerns:
| | | | | The second comparison group consisted of patients that had some preventive services covered by a health plan. | | - Men, aged 18–39 years | | 1. Reporting on differences between enrollees and non-enrollees
| | | | | | | - Men, aged 40–64 years | | External Validity Concerns:
| | | | | | | - Women, aged 18–39 years | | 1. Description of study inclusion/exclusion criteria not detailed
| | | | | | | - Women, aged 40–64 years | | 2. Description of study population characteristics not detailed
| | | | | | | | | 3. Description of PHE is not detailed
| | | | | | | | | Statistical Validity Concerns:
| | | | | | | | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | | | 2. Incomplete presentation of statistical significance
Kottke, 1997 ^31^ | 1994 | | The study consisted of 6,830 randomly selected patients from 44 primary-care clinics who completed a mail survey to ascertain their receipt of preventive services in the context of “check-up physical examinations” versus other types of visits | The intervention group consisted of patients who had a visit (reason for visit as declared by patient) for a health risk appraisal. | The first comparison group included patients with visits (reason for visit as declared by patient) for urgent problems. | [underlined: Intervention Group:] | 1. Pap smear | The PHE was defined as a physical examination or check up that consisted of a breast exam, blood pressure measurement, pap smear, smoking cessation counseling, influenza & pneumovax immunization, cholesterol screening, and mammogram. | Internal Validity Concerns:
| | | | | The second comparison group included patients with visits (reason for visit as declared by patient) for continuing condition. | Providers: | 2. Counseling - smoking cessation | | 1. Reporting on differences between enrollees and non-enrollees
| | | | | The third comparison group included patients with visits (reason for visit as declared by patient) for a follow-up. | 1. continues quality improvement initiative | 3. Immunization | | External Validity Concerns:
| | | | | The fourth comparison group included patients with visits (reason for visit as declared by patient) other than for follow-up, continuing education, urgent problems, or health risk appraisal. | | - Rate** influenza vaccine offered by providers | | 1. Description of study population characteristics not detailed
| | | | | | | - Rate** pneumococcal vaccine offered by providers | | 2. Description of PHE is not detailed
| | | | | | | 4. Cholesterol screening** | | Statistical Validity Concerns:
| | | | | | | 5. Mammogram | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | | | | 2. Incomplete presentation of statistical significance
Sox, 1997 ^70^ | 1992 | | The study population consisted of 2,775 patients of family physicians and general internists in Vermont, age 42 years and older, with no life-threatening illness, and recently visited a physician completing a questionnaire and agreeing to review of medical records to assess their receipt of a “periodic health examination” and their receipt of recommended clinical preventive services | The intervention group received a periodic health examination. | The comparison group received cancer-specific, age-appropriate and sex-appropriate exams during usual care. | | 1. Pap smear | The PHE is this study was described as a routine physical examination that wasn't for a particular illness, but for a general check-up. | Internal Validity Concerns:
| | | | | | | 2. Counseling | | 1. Reporting on differences between enrollees and non-enrollees
| | | | | | | - dietary | | External Validity Concerns:
| | | | | | | 3. Colon cancer screening | | 1. Description of study inclusion/exclusion criteria not detailed
| | | | | | | - Mean proportion of persons in each practice receiving sigmoidoscopy | | 2. Description of study population characteristics not detailed
| | | | | | | - Mean proportion of persons in each practice receiving fecal occult blood testing | | 3. Description of PHE is not detailed
| | | | | | | 4. Mammogram | | Statistical Validity Concerns:
| | | | | | | | | 1. Concern regarding unit of analysis employed in presentation of results
| | | | | | | | | 2. Incomplete presentation of statistical significance
Slesinger, 1976 ^63^ | 1973 | | The study population consisted of 989 employed individuals who had health insurance responding to household survey regarding their receipt of clinical preventive services in the past year | The intervention group consisted of employees who chose a prepaid group insurance plan. | The comparison group consisted of a random sampling of employees who chose the traditional Blue Cross/Blue Shield plan. | [underlined: Intervention Group:] | 1. Pap smear | The PHE was described as a general physical check-up or Physical examination. | External Validity Concerns:
| | | | | | Patients: | 2. Receipt of PHE - receipt of general check-up in the past year | | 1. Study performed before USPSTF or similar contemporary preventive services guidelines in effect
| | | | | | 1. Comprehensive benefit package on a pre-payment basis | | | Statistical Validity Concerns:
| | | | | | [underlined: Control Group:] | | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | Patients:
| | | | | | 1. Did not offer prepaid comprehensive benefits package (no reimbursement for MD office visits or physical exams)
Nakanishi, 1996 ^82^ | 1992 | | The study population consisted of 227,581 inpatient and outpatient claims of residents aged 40 and over in 9 cities in Japan. | The intervention group consisted of Japanese adults aged 40 years and older in the National Health Insurance program. | | | 1. Costs | The PHE was described as a health examination that included (1) health check-ups as basic health examination (interview, body measurement, physical tests, blood pressure measurement, urinalysis and blood test) with special examinations when indicated, and screenings for stomach cancer (stomach radiography), uterus cancer (visual examination, cytodiagnosis and internal examination as cervical cancer screening and cytodiagnosis as uterine body screening), lung cancer (chest radiography and phlegm cellular test), breast cancer (visual examination and palpation), and colon cancer (occult blood test, starting in 1992) (for uterus cancer screening and breast cancer screening, women aged 30 or more are eligible); (2) issuance of a health notebook (recording health examinations, providing the eligibility of patients to receive medical care and maintaining medical care records); (3) health education (health classes using brochures, posters, cable broadcasting, etc.); (4) individual health counseling; (5) rehabilitation programs; and (6) home-visit guidance (nursing techniques, treatment methods, training for activities fordaily living at home, etc.). | Internal Validity Concerns:
| | | | | | | - Inpatient cost per insured person (yen) correlated with rate of use of health check-ups | | 1. Reporting on differences between enrollees and non-enrollees
| | | | | | | - High inpatient cost (600,000 yen or more) correlated with rate of use of health check-ups | | External Validity Concerns:
| | | | | | | - Outpatient cost per insured person correlated with rate of use of health check-ups | | 1. Results potentially not generalizable beyond Japanese population
| | | | | | | 2. Hospitalization
| | | | | | | - Hospital admission rate per 1000 insured persons correlation with rate of use of health checkups
| | | | | | | - Length of stay of 180 days or more per 1000 insured persons correlated with rate of use of health checkups
Somkin, 2004 ^68^ | 1999 | | The study population consisted of, 463 subjects aged 40 to 74 residing in Alameda County, California respondents to a telephone survey assessing their access to and satisfaction with preventive services | The intervention group included persons reporting they received a check-up in the last 12 months. | The comparison group included persons reporting they had not received a check-up in the last 12 months. | | 1. Pap smear | The PHE was defined as a check-up in the last 12 months. | External Validity Concerns:
| | | | | | | 2. Mammogram | | 1. Study not specifically designed to address Key Question
Pre-post Studies
Schneider, 2003 ^71^ | 1999 | 2 months | The study population consisted of 319 adult patients in an ambulatory family practice residency clinic in which physicians participated in a quality improvement program to enhance the delivery of the “health maintenance examination” and clinical preventive services | Patients received written material, and a reminder phone call. | | [underlined: Intervention Group:] | 1. Pap smear | The PHE was defined as a health maintenance examination. | External Validity Concerns:
| | | | Providers received education on prevention measures. | | Patients: | 2. Counseling | | 1. Study not specifically designed to address Key Question
| | | | | | 1. Patient-held medical records | - Exercise counseling | | Statistical Validity Concerns:
| | | | | | Providers: | - Diet counseling | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | 1. Chart-based reminders | - Alcohol counseling
| | | | | | 2. Educational sessions on preventive measures | - Substance abuse counseling
| | | | | | [underlined: Control Group:] | - Tobacco cessation counseling
| | | | | | Patients: | 3. Cholesterol screening
| | | | | | 1. Patient-held medical records | 4. Colon cancer screening
| | | | | | Providers: | - Percentage receiving fecal occult test.
| | | | | | 1. Chart-based reminders | - Percentage receiving sigmoidoscopy
| | | | | | 2. Educational sessions on preventive measures | 5. Mammogram
| | | | | | | 6. Receipt of PHE
Geiger, 1993 ^72^ | 1990 | 5 months | The study population consisted of 23 family practice residents and faculty physicians who provided for 3,300 patients, using a practice-based teaching model to increase resident compliance with USPSTF guidelines | The intervention consisted of two sequential phases. In phase one, physicians were educated about providing preventive services in accordance with USPSTF guidelines in the context of a “health check.” In phase two, physicians were monitored for their delivery of a recommended preventive services during scheduled health checks. | | [underlined: Intervention Group:] | 1. Pap smear | The PHE was described as preventive services (health check; physical examination) that assessed blood pressure, breast exam, pap smear, height, weight, visual acuity, hearing, substance abuse activity, diet activity, injury prevention activity, oral health, and physical activity use. In addition, Influenza, pneumovax, & tetanus immunizations, cholesterol screening, mammography, urinalysis, and thyroid function. | Internal Validity Concerns:
| | | | | | Patients: | 2. Counseling | | 1. Standard/valid reporting of outcomes
| | | | | | 1. Written Material | - Substance abuse counseling | | Statistical Validity Concerns:
| | | | | | [underlined: Control Group:] | - Diet counseling | | 1. Potentially inadequate adjustment for residual confounding
| | | | | | Patients: | - Oral health counseling (dental care)
| | | | | | 1. Written Material | - Physical activity counseling
| | | | | | | 3. Cholesterol screening
| | | | | | | 4. Mammogram

‡ Larger values indicate worse health.

¶ Colon/rectum, breast, cervix/uterine, prostate, and kidney cancer, hypertension, hypertensive cardiovascular disease, hemorrhagic cerebrovascular disease.

* Date published; unspecified

** Clinic weighted rate across 44 primary care clinics.

Table 3 Type and Number of Outcomes Reported in Studies

Type of outcomes and number reported in studies | n(%) studies
Delivery of Clinical Preventive Services
1 outcome | 7(19) ^16,^ ^53,^ ^56,^ ^63,^ ^73^ – ^75^
2 outcomes | 2(6) ^42,^ ^68^
3 or more outcomes | 11(31) ^31,^ ^44,^ ^55,^ ^64^ – ^67,^ ^69^ – ^72^
Proximal Clinical Outcomes
1 outcome | 1(3) ^45^
2 outcomes | 2(6) ^56,^ ^57^
3 or more outcomes | 3(8) ^53,^ ^54,^ ^59,^ ^77^
Distal Clinical and Economic
1 outcome | 5(14) ^28,^ ^58,^ ^61,^ ^62,^ ^83^
2 outcomes | 4(11) ^29,^ ^53,^ ^55,^ ^82^
3 or more outcomes | 3(8) ^41,^ ^56,^ ^57^
Interventions to improve receipt of PHE
1 outcome | 5(14) ^22,^ ^60,^ ^63,^ ^71,^ ^84^
All Outcomes (regardless of type)
1 outcome | 13(36) ^45,^ ^58,^ ^60,^ ^62,^ ^83,^ ^84^ ^16,^ ^22,^ ^28,^ ^61,^ ^73^ – ^75^
2 outcomes | 5(14) ^29,^ ^42,^ ^63,^ ^68,^ ^82^
3 or more outcomes | 18(50) ^44,^ ^53^ – ^57^ ^31,^ ^41,^ ^59,^ ^64^ – ^67,^ ^69^ – ^72,^ ^77^

Table 4 Quality of Identified Studies on the Value of the Periodic Health Evaluation

Author, year | External validity* | Internal validity^†^ | Statistical Analysis^‡^ | Total score^§^
Lin, 2004 | low | high | high | high
Somkin, 2004 | high | medium | high | high
Flocke, 2004; Eaton, 2002 | medium | high | high | high
Schneider, 2003 | medium | medium | medium | medium
Finkelstein, 2002 | low | medium | high | medium
Hahn, 1999 | medium | low | low | low
Chiou, 2002 | low | low | high | medium
Burton, 2002 | high | low | low | low
Tao, 2001 | low | low | low | low
Parchman, 2001 | low | medium | low | low
Nutting, 2001 | low | low | medium | low
Hama, 2001 | medium | high | medium | high
Patrick, 1999 | medium | medium | low | low
Stange, 2000 | high | high | medium | high
Freedman, 2000 | high | high | medium | high
Williams, 1998 | high | low | high | medium
Faulkner, 1997 | low | high | medium | medium
Kottke, 1997 | medium | low | high | medium
Sox, 1997 | low | medium | medium | medium
Elder, 1995; Mayer, 1994 | high | medium | high | high
Christensen, 1995 | high | medium | high | high
Morrissey, 1995 | high | high | high | high
Burton, 1995; German, 1995; Burton, 1997; Burton, 1995 | high | high | medium | high
Morrissey, 1995 | medium | high | medium | high
Norman, 1992 | medium | high | low | medium
Belcher, 1990 | medium | medium | medium | low
Bernacki, 1988 | low | low | low | low
Stone, 1981; Stone, 1978; South-east London, 1977; Trevelyan, 1973; South-east London, 2001 | high | medium | low | medium
Fletcher, 1977 | high | low | medium | medium
Slesinger, 1976 | low | low | low | low
Cutler, 1973; Collen, 1973; Dales, 1973; Ramcharan, 1973; Friedman, 1986; Dales, 1979; Norinder, 2002 | high | medium | low | low
Robert, 1969 | low | low | low | low
Grimaldi, 1965 | low | low | low | low
Theobald, 1998 | medium | low | medium | low
OXCHECK, 1995a; OXCHECK, 1995b | medium | medium | low | medium
Nakanishi, 1996 | medium | high | medium | high

* External validity includes quality of reporting on study inclusion/exclusion criteria, characteristics of study population, description of periodic health evaluation (PHE) or interventions to change the delivery of the PHE, and description of outcomes. See text under “Article summary quality” for more detail regarding assessment of quality.

† Internal validity includes assessment of randomization scheme (for trials), appropriateness of control group (for trials), assessment of those who enrolled versus those who did not enroll, assessment of withdrawals, blinding of intervention assignment and outcome assessment (for trials), and adequacy of outcome measurement. See text under “Article summary quality” for more detail regarding assessment of quality.

‡ Statistical analysis quality includes reporting on sample size calculations, presentation of statistical significance, and appropriateness of statistical methods. See text under “Article summary quality” for more detail regarding assessment of quality.

§ Scores of high, medium, or low indicate that the article scored in the highest, middle, or lowest tertile of scores.

Table 5 Components Which were Included (or may have been included) in Studies on the Periodic Health Evaluation (N=36)

Component of PHE | n(%)
History and Risk Assessment
Tobacco smoking | 14(39)
Alcohol/ substance abuse | 13(36)
Dietary risk factors | 12(33)
Physical Activity | 10(27)
Injury prevention | 6(17)
Safe sexual practices | 6(17)
Sun exposure | 4(11)
Oral health | 4(11)
Medications/ Poly-pharmacy | 4(11)
Calcium intake | 2(6)
Folic acid intake | 2(6)
Physical Examination
Blood pressure assessment | 18(50)
Examination (not otherwise specified) | 14(39)
Breast examination | 12(33)
Weight | 12(33)
Height | 10(28)
Gynecological examination | 10(28)
Cardiovascular examination | 5(14)
Pulmonary examination | 5(14)
Eye* examination | 5(14)
Pulse | 4(11)
Rectal examination | 4(11)
Prostate examination | 4(11)
Abdominal examination | 4(11)
Neurological examination | 3(8)
Foot examination | 2(6)
Other^†^ | 13(36)

* fundoscopic

† vision testing, tonometry, audiometry

Table 6 Grading of the Overall Strength of Evidence on the Value of the Periodic Health Evaluation

Outcome | Pap smear | Counseling | Immunizations | Choles-terol | Colon cancer | Mammogram | Disease detection | Health habits | Patient attitudes | Health Status | Blood Pressure | Serum Cholesterol | Body Mass Index | Costs | Disability | Hospitalization | Mortality | Receipt of PHE
Number of studies§ | 2 (2) | 7 (1) | 3 (3) | 5(1) | 2 (2) | 2 (1) | 2 (2) | 5 (5) | 1 (1) | 2 (2) | 2 (2) | 2 (1) | 3 (3) | 4(4) ‡ | 2 (2) | 3 (3) | 5 (5) | 2 (1)
Strength of study design* | 4 | 3 | 4 | 3 | 4 | 3 | 4 | 4 | 4 | 4 | 4 | 3 | 4 | 4 | 4 | 4 | 4 | 3
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -0.5 | -1 | -1 | -1 | -1 | -1 | -1 | -1 | -1 | -1 | -0.5 | -1 | -1 | -1 | -1 | -0.5 | -1 | -0.5
Did the studies have important inconsistency? (-1) | 0 | -0.5 | -1 | 0 | 0 | -0.5 | -1 | -1 | 0 | -0.5 | -0.5 | -0.5 | -1 | -1 | -1 | -0.5 | -1 | 0
Were data imprecise or sparse? (-1) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | -1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome?^†^ | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, medium, low, very low) | 3.5 High | 1.5 Low | 2 Med | 2 Med | 4 High | 1.5 Low | 2 Med | 2 Med | 2 Med | 2.5 Medium | 3 High | 1.5 Low | 2 Med | 2 Med | 2 Med | 3 High | 2 Med | 2.5 Med

* Were study designs randomized trials (high quality), non-randomized controlled trials (medium quality), or observational studies (low quality)?

† Evidence was deemed “strong” if significant relative risk or odds ratio >2 (or Cohen's d ≥0.8) based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio >5 based on direct evidence with no major threats to validity (+2).

PHE = periodic health evaluation

§ Parentheses contain number of randomized controlled trials considered among the best available evidence.

‡ One study evaluating cost-effectiveness as cost per percent coronary risk reduction not included ^81^ due to inability to assess direction of results.

Table 7 Comparison of Effect Sizes in Randomized Controlled Trials

| Effect size (95% CI) | | | Not able to calculate ES
| Outcomes in studies with positive effect of PHE | Outcomes in studies with negative effect of PHE | Confidence interval crosses 0
Outcomes
Receipt of Pap smear | 1.71 (1.69, 1.73) ^55^
| 0.07 (0.07, 0.07) ^80^
Preventive counseling | 1.09 (1.08,1.11) ^44^ ^c^
| 1.19 (1.17, 1.21) ^44^ ^b^
Immunizations | 0.35 (0.33, 0.36) ^55^ ^a^ | -0.22 (-0.24, -0.20) ^44^ ^a^
| 0.10 (0.10, 0.10) ^53^ ^a^
Cholesterol screening | 0.02 (0.00, 0.04) ^55^
Colon cancer screening (fecal occult blood testing) | 1.19 (1.17, 1.21) ^55^
| 1.07 (1.05, 1.08) ^44^
Mammography | 0.14 (0.12, 0.16) ^55^
Disease detection | 0.03 (0.02, 0.03) ^76^ ^f^ | -0.01 (-0.01, -0.01) ^76^ ^d^ | -0.01 (-0.01, 0.00) ^76^ ^e^
| 0.96 (0.84, 1.08) ^45^ ^a^ | -0.03 (-0.03, -0.03) ^76^ ^g^
| 0.53 (0.41, 0.64) ^45^ ^b^
Health habits | 0.28 (0.14, 0.42) ^54^ ^a^ | -0.040 (-0.043, -0.037) ^53^ ^h^ | 0.000 (-0.14, 0.14) ^54^ ^b^
| 0.120 (0.117, 0.123) ^53^ ^b^ | -0.014 (-0.016, -0.012) ^76^ ^c^ | 0.01 (-0.13, 0.15) ^54^ ^c^
| 0.040 (0.037, 0.043) ^53^ ^c^ | -.02 (-.03, -.02) ^78^ ^b^ | 0.02 (-0.12, 0.16) ^54^ ^d^
| 0.345 (0.342, 0.348) ^53^ ^d^ | | 0.05 (-0.09, 0.19) ^54^ ^e^
| 0.080 (0.077, 0.083) ^53^ ^e^ | | 0.01 (-0.13, 0.15) ^54^ ^f^
| 0.020 (0.017, 0.023) ^53^ ^f^
| 0.020 (0.017, 0.023 ) ^53^ ^g^
| 0.100 (0.098, 0.102) ^59^ ^a^
| 0.032 (0.030, 0.034) ^59^ ^b^
| 0.088 (0.086, 0.090) ^59^ ^c^
| 0.244 (0.242, 0.246) ^59^ ^d^
| 0.250 (0.248, 0.252) ^59^ ^e^
| 0.13 (0.11,0.14) ^78^ ^a^
Patient attitudes | | | | ^53^
Health Status | | | | ^56^
Blood Pressure | 0.12 (0.02,0.21) ^54^ ^g^ | | 0.03 (-0.06, 0.13) ^54^ ^h^
| 0.11(0.04, 0.18) ^59^ ^f^
| 0.13 (0.06, 0.19) ^59^ ^g^
| 0.022 (0.019, 0.024) ^59^ ^h^
Changes in serum cholesterol levels | 0.22 (0.16, 0.29) ^59^ ^k^
| 0.09 (0.09, 0.10) ^59^ ^l^
Body Mass Index | 0.087 (0.022, 0.153) ^59^ ^i^ | -0.020 (-0.023,-0.017) ^53^ ^i^ | -0.031 (-0.170, 0.108) ^54^ ^i^
| 0.032 (0.030, 0.034) ^59^ ^j^ | | -0.036 (-0.174, 0.103) ^54^ ^j^
Reduction in health care costs | | | 0.06 (-0.03, 0.15) ^55^ ^d^ | ^47,^ ^53,^ ^56^
| | | 0.05(-0.04, 0.14) ^55^ ^e^
Reduction in disability | 0.060 (0.054, 0.066) ^96^ ^a^ | -0.014 (-0.016, -0.012) ^76^
Reduction in hospitalizations | 0.01 (0.00, 0.01) ^76^ ^a^ | | 0.02 (-0.07, 0.11) ^55^ ^b^ | ^56^ ^b,c,d,e^
| | | -0.04 (-0.13, 0.05) ^55^ ^c^
Reduction in all-cause mortality | 0.06 (0.05, 0.06) ^56^ ^a^ | -0.03 (-0.04, -0.03) ^53^ ^a^ | Rate ratio: 1.03 (0.94,1.14) ^58^
| 0.004 (0.004, 0.005) ^9^ ^a^ | -0.002 (-0.003, -0.0003) ^76^ ^b^
Receipt of PHE (Question 4) | 0.69 (0.68,0.70) ^60^

ES = effect size; CI = confidence interval

Citation( ^55^ ) a: influenza vaccination, b: hospital days per enrollee, c: Admissions per enrollee, d: 3-year post-intervention cumulative Medicare charges; e: 3-year post-intervention cumulative Medicare reimbursement

Citation( ^45^ ) a: disease detection of ALL problems before and after intervention, b: disease detection of important problems before and after intervention;

Citation( ^53^ ) a: Influenza vaccination, b: Physical activity, c: Diet (fat and fiber), d: Advance directives, e: Breast self-exam, f: Smoking, g: Alcohol, h: Seat belt use; I: at risk for obesity, 24-month F/U

Citation( ^44^ ) a: influenza vaccination, b: alcohol abuse, c: smoking cessation

Citation( ^76^ ) a: Hospitalizations, b: Mortality rate per 1000 person-years at risk: all cause death, c: percentage still smoking, d: angina, e: high diastolic blood pressure, f: ischemia on electrocardiogram, g: bronchitis symptoms;

Citation( ^56^ ) a: Death; b: Mean inpatient days for the intervention and control groups who had a hospital discharge in that year (Year 1), c: Mean inpatient days Year 2, d: Hospital discharges per 1000 Year 1, e: Hospital discharges per 1000 Year 2;

Citation( ^53^ ) a: Mortality at 48 months;

Citation( ^9^ ) a: Deaths, rate per 1000 persons 16 years;

Citation( ^96^ ) a: Disability at 11 years

Citation( ^54^ ) a: fiber servings per day, b: fat servings per week, c: salt use, d: caffeine drinks per day, e: stretching minutes per week, f: consumption of cruciferous foods; g: mean systolic blood pressure at 12 months; h: mean diastolic blood pressure at 12 months; i: mean BMI at 24 months (end of intervention period); j: mean BMI at 48 months (end of F/U)

Citation( ^59^ ) a: smoking, b: alcohol use, c: exercise less than once per month, d: use full cream milk, e: use butter or hard margarine; f: systolic blood pressure at 3-year follow up; g: diastolic blood pressure at 3-year follow up; h: proportion of high risk diastolic pressure (≥100mm Hg) from 3 year F/U when compared to control; i: mean BMI at 3-year F/U; j: percentage of participants with BMI ≥ 30; k: mean total cholesterol at 3-year F/U; l: proportion of high risk cholesterol (≥8mmol/l) at 3 year F/U

Citation( ^78^ ) a: smoking, b: problem alcohol drinking

Table 8 Number of Studies (presented in cells) Reporting Outcomes According to Study Design and Direction of Results Reported

| Number of Studies According to Study Design and Direction‡ of Results | | | | | | | | | | | | | | | Totals
| Experimental | | | | | | Observational
| RCT* (N^†^= 11) | | | Non-RCT* (N^†^= 1) | | | Cohort* (N^†^= 7) | | | Cross-Sectional* (N^†^= 14) | | | Pre-Post* (N^†^= 3) | | | Experimental | | | Observational
Examined Outcome | +PHE | øPHE | -PHE | +PHE | øPHE | -PHE | +PHE | øPHE | -PHE | +PHE | øPHE | -PHE | +PHE | øPHE | -PHE | +PHE | øPHE | -PHE | +PHE | øPHE | -PHE
[underlined: Delivery of Clinical Preventive Services]
Physical Examination
Pap Smear | 2 | | | | | | | 1 | | 7 | 1 | | 1 | 1 | | 2 | | | 8 | 3
Preventive Counseling
Counseling | 1 | | | | | | | | | 5 | | 1 | 1 | 1 | | 1 | | | 6 | 1 | 1
Preventive Immunizations
Immunizations | 2 | | 1 | | | | 1 | | | 3 | | | 2 | | | 2 | | 1 | 6
Laboratory, Radiological Testing
Cholesterol Screening | 1 | | | | | | | | | 4 | | | | 2 | | 1 | | | 4 | 2
Colon Cancer Screening | 2 | | | | | | | 1 | | 2 | | | 1 | | | 2 | | | 3 | 1
Mammography | 1 | | | | | | | 1 | | 7 | | 1 | | 2 | | 1 | | | 7 | 3 | 1
[underlined: Proximal Clinical Outcomes]
Disease Detection | 1 | 1 | | | | | 1 | | | | | | | | | 1 | 1 | | 1
Health Habits | 1 | 3 | 1 | | | | | | | | | | | | | 1 | 3 | 1
Patient Attitudes | 1 | | | | | | | | | | | | | | | 1
Health Status | 1 | 1 | | | | | | | | | | | | | | 1 | 1
Blood Pressure | 1 | 1 | | | | | | 1 | | | | | | | | 1 | 1 | | | 1
Serum Cholesterol | 1 | | | | | | | 1 | | | | | | | | 1 | | | | 1
Body Mass Index | 1 | 1 | 1 | | | | | 1 | | | | | | | | 1 | 1 | 1 | | 1
[underlined: Distal Clinical and Economic Outcomes]
Costs^£^ | 1 | 2 | 1 | | | | 2 | | 1 | 1 | | | | | | 1 | 2 | 1 | 3 | | 1
Disability | 1 | | 1 | | | | 1 | | | | | | | | | 1 | | 1 | 1
Hospitalization | 1 | 2 | | | | | | | | 1 | | | | | | 1 | 2 | | 1
Mortality | 2 | 2 | 1 | | | | 2 | | | | | | | | | 2 | 2 | 1 | 2
[underlined: Interventions to improve receipt of PHE] | 1 | | | 1 | | | | | | 1 | 1 | | 2 | | | 2 | | | 2 | 1

* Study design definitions: RCT=randomized controlled trial (study of two groups randomly assigned to intervention (versus control)); non-RCT=non-randomized controlled trial (study of two groups randomly assigned to intervention (versus control)—intervention assignment not random); Cohort (study with prospective or retrospective longitudinal observation of study population (no intervention assignment)); Cross-sectional (study population observed at one point in time (no intervention assignment, no prospective or retrospective observation); Pre-Post=Pre-post observational design (one study group in which baseline measurements are taken (pre-intervention phase). These measurements are repeated on the same study group following the implementation of an intervention (post-intervention phase).

† N represents total number for entire review.

‡ Direction of results: +PHE = Articles reporting the PHE improves delivery (or is associated with improved delivery) of clinical preventive services, proximal clinical outcomes, or distal and economic outcomes; -PHE = Articles reporting the PHE worsens delivery (or is associated with worse delivery) of clinical preventive services, proximal clinical outcomes, or distal and economic outcomes; ø PHE = Articles reporting mixed results (positive, negative, or neutral) with regard to the association of receipt of the PHE with clinical outcomes.

£ One RCT examining cost-effectiveness is not included because of the inability to assess direction of results. ^81^

Table 9 Summary of Results from Best Available Evidence to Assess Each Outcome

Outcome | Type* of Evidence Assessing Considered (number of studies) | Strength and Consistency of Evidence | Range of Magnitude and Direction of Effects of PHE on Outcome**
Delivery of Clinical Preventive Services
Gynecological examination/ Pap smear | RCTs (2) | High | Small to Large Positive
Counseling | RCTs (1) | Low | Mixed
| Observational (6)
Immunizations | RCTs (3) | Medium | Mixed
Cholesterol Screening | RCTs (1) | Medium | Small to Large Positive
| Observational (4)
Colon Cancer Screening (Fecal Occult Blood Testing) | RCTs (2) | High | Large Positive
Mammography | RCTs (1) | Low | Mixed
| Observational (1)
Proximal Clinical Outcomes
Disease Detection | RCTs (2) | Medium | Mixed
Health Habits | RCTs (5) | Medium | Mixed
Patient Attitudes (Worry) | RCTs (1) | Medium | Positive†
Health Status | RCTs (2) | Medium | Mixed†
Blood Pressure | RCTs (2) | High | Mixed
Serum Cholesterol | RCTs (1) | Low | Mixed
| Observational (1)
Body Mass Index | RCTs (3) | Medium | Mixed
Distal Clinical and Economic Outcomes
Costs | RCTs (4) | Medium | Mixed
Disability | RCTs (2) | Medium | Mixed
Hospitalization | RCTs (3) | High | Mixed
Mortality | RCTs (5) | Medium | Mixed
Improvement in Receipt of PHE | RCTs (1) | Medium | Medium to Large Positive
| Non-RCTs (1)

* RCT=Randomized controlled trial; Observational=Studies with observational design; non-RCT=non-randomized controlled trials

** Magnitude and direction of effect of receipt of PHE on outcome, based on standardized effect sizes calculated using Cohen's d. We considered effect sizes ranging from 0 to 0.25 to represent “small” effects, ranging from 0.25 to 0.8 to represent “medium” sized effects, and effect sizes greater than 0.8 to represent “large” effects. Effect sizes can be thought of as the average percentile standing of the average treated (or experimental) participant relative to the average untreated (or control) participant. An ES of 0.0 indicates that the mean of the treated group is at the 50th percentile of the untreated group. An ES of 0.25 indicates that the mean of the treated group is at the 58th percentile of the untreated group. An ES of 0.8 indicates that the mean of the treated group is at the 79th percentile of the untreated group.

† Standardized effect size could not be calculated for the study or studies assessing this outcome.