# References and Included Studies

1 Han PK. Historical changes in the objectives of the periodic health examination. Ann Intern Med. 1997;127(10):910-7. [pmid: 9382370].
2 Charap MH. The periodic health examination: genesis of a myth. Ann Intern Med. 1981;95(6):733-5. [pmid: 7030166].
3 Davis AB. Life insurance and the physical examination: a chapter in the rise of American medical technology. Bull Hist Med. 1981;55(3):392-406. [pmid: 7037084].
4 Leeder S. Commentary: Learning in Lambeth-- the South-East London Screening Study revisited. Int J Epidemiol. 2001;30(5):944-5. [pmid: 11689499].
5 Siegel GS. An American dilemma--the periodic health examination. Arch Environ Health. 1966;13(3):292-5. [pmid: 5922231].
6 Collen MF, Garfield SR, Richart RH, et al. Cost analyses of alternative health examination modes. Arch Intern Med. 1977;137(1):73-9. [pmid: 831655].
7 The South-East London Screening Study Group. A controlled trial of multiphasic screening in middle-age: results of the South-East London Screening Study. The South-East London Screening Study Group. Int J Epidemiol. 1977;6(4):357-63. [pmid: 608798].
8 Agency for Healthcare Research and Quality RMD. February 2005. About USPSTF. U.S. Preventive Services Task Force. Available at: http://www.ahrq.gov/clinic/uspstfab.htm. accessed 2005.
9 Friedman GD, Collen MF, Fireman BH. Multiphasic Health Checkup Evaluation: a 16-year follow-up. J Chronic Dis. 1986;39(6):453-63. [pmid: 3711252].
10 Frame PS, Carlson SJ. A critical review of periodic health screening using specific screening criteria. 3. Selected diseases of the genitourinary system. J Fam Pract. 1975;2(3):189-94. [pmid: 1097580].
11 Canadian Task Force on Preventive Care History and Methodology. Available at: http://www.ctfphc.org. accessed 2005.
12 Frame PS, Carlson SJ. A critical review of periodic health screening using specific screening criteria. Parts 1–3. J Fam Pract. 1975;2(1):29-194. [pmid: 1123583].
13 Medical Practice Committee American College of Physicians. Periodic health examination: a guide for designing individualized preventive health care in the asymptomatic patients. Ann Intern Med. 1981;95(6):729-32. [pmid: 7305155].
14 Canadian Task Force on the Periodic Health Examination. The periodic health examination. Canadian Medical Association Journal
15 Smith HE, Herbert CP. Preventive practice among primary care physicians in British Columbia: relation to recommendations of the Canadian Task Force on the Periodic Health Examination. CMAJ. 1993;149(12):1795-800. [pmid: 8261349]. [pmcid: 1485726].
16 Freedman A, Pimlott N, Naglie G. Preventive care for the elderly. Do family physicians comply with recommendations of the Canadian Task Force on Preventive Health Care?. Can Fam Physician. 2000;46(1):350-7. [pmid: 10690491]. [pmcid: 1987685].
17 Aromaa A, Koponen P, Tafforeau J, et al. Evaluation of Health Interview Surveys and Health Examination Surveys in the European Union. Eur J Public Health. 2003;13(3 Suppl):67-72. [pmid: 14533752].
18 Singapore Ministry of Health. 2003. Clinical Practice Guidelines. Available at: [underlined: http://www.moh.gov.sg/corp/publications/list.do?id=pub_guide_clinics] . accessed 2005 Oct.
19 Romm FJ. Patients' expectations of periodic health examinations. J Fam Pract. 1984;19(2):191-5. [pmid: 6747560].
20 Romm FJ. Periodic health examination: effect of costs on patient expectations. South Med J 1985; 78(11): 1330–2, 1340.
21 Hudon E, Beaulieu MD, Roberge D. Integration of the recommendations of the Canadian Task Force on Preventive Health Care: obstacles perceived by a group of family physicians. Fam Pract. 2004;21(1):11-7. [pmid: 14760037].
22 Faulkner LA, Schauffler HH. The effect of health insurance coverage on the appropriate use of recommended clinical preventive services. Am J Prev Med. 1997;13(6):453-8. [pmid: 9415792].
23 Salinsky E. Clinical preventive services: when is the juice worth the squeeze? NHPF Issue Brief 2005; (806): 1–30.
24 CMS. 2003. The Medicare Prescription Drug Improvement and Modernization Act of 2003. Available at: http://www.medicare.gov/Publications/Pubs/pdf/11054.pdf. accessed 2005.
25 U.S. Department of Health and Human Services. 2003. Prevention Makes Common ‘Cents’. Available at: http://aspe.hhs.gov/health/prevention/. accessed 2005.
26 Pronk NP, Goodman MJ, O'Connor PJ, et al. Relationship between modifiable health risks and short-term health care charges. JAMA. 1999;282(23):2235-9. [pmid: 10605975].
27 Sturm R. The effects of obesity, smoking, and drinking on medical problems and costs. Health Aff (Millwood). 2002;21(2):245-53. [pmid: 11900166].
28 Bernacki EJ, Tsai SP, Malone RD. Participation in a periodic physical examination program and group health care utilization and costs. J Occup Med. 1988;30(12):949-52. [pmid: 3230446].
29 Burton WN, Chen CY, Conti DJ, et al. The value of the periodic executive health examination: experience at Bank One and summary of the literature. J Occup Environ Med. 2002;44(8):737-44. [pmid: 12185794].
30 Hayward RS, Steinberg EP, Ford DE, et al. Preventive care guidelines: 1991. American College of Physicians. Canadian Task Force on the Periodic Health Examination. United States Preventive Services Task Force. Ann Intern Med. 1991;114(9):758-83. [pmid: 2012359].
31 Kottke TE, Solberg LI, Brekke ML, et al. Delivery rates for preventive services in 44 midwestern clinics. Mayo Clin Proc. 1997;72(6):515-23. [pmid: 9179135].
32 Oboler SK, Prochazka AV, Gonzales R, et al. Public expectations and attitudes for annual physical examinations and testing. Ann Intern Med. 2002;136(9):652-9. [pmid: 11992300].
33 Ren A, Okubo T, Takahashi K. Comprehensive periodic health examination: impact on health care utilisation and costs in a working population in Japan. J Epidemiol Community Health. 1994;48(5):476-81. [pmid: 7964358]. [pmcid: 1060011].
34 Sciamanna CN, Novak SP, Houston TK, et al. Visit satisfaction and tailored health behavior communications in primary care. Am J Prev Med. 2004;26(5):426-30. [pmid: 15165659].
35 Gordon PR, Senf J, Campos-Outcalt D. Is the annual complete physical examination necessary?. Arch Intern Med. 1999;159(9):909-10. [pmid: 10326933].
36 Frame PS. The complete annual physical examination refuses to die. J Fam Pract. 1995;40(6):543-5. [pmid: 7775907].
37 Oboler SK, LaForce FM. The periodic physical examination in asymptomatic adults. Ann Intern Med. 1989;110(3):214-26. [pmid: 2643379].
38 Preisser JS, Cohen SJ, Wofford JL, et al. Physician and patient predictors of health maintenance visits. Arch Fam Med. 1998;7(4):346-51. [pmid: 9682688].
39 Solanki G, Schauffler HH. Cost-sharing and the utilization of clinical preventive services. Am J Prev Med. 1999;17(2):127-33. [pmid: 10490055].
40 Olsen DM, Kane RL, Proctor PH. A controlled trial of multiphasic screening. N Engl J Med. 1976;294(17):925-30. [pmid: 1256483].
41 Cutler JL, Ramcharan S, Feldman R, et al. Multiphasic checkup evaluation study. 1. Methods and population. Prev Med. 1973;2(2):197-206. [pmid: 4723635].
42 Stange KC, Flocke SA, Goodwin MA, et al. Direct observation of rates of preventive service delivery in community family practice. Prev Med. 2000;31(2 Pt 1):167-76. [pmid: 10938218].
43 van Walraven C, Goel V, Austin P. Why are investigations not recommended by practice guidelines ordered at the periodic health examination?. J Eval Clin Pract. 2000;6(2):215-24. [pmid: 10970015].
44 Belcher DW. Implementing preventive services. Success and failure in an outpatient trial. Arch Intern Med. 1990;150(12):2533-41. [pmid: 2244769].
45 Fletcher SW, Sourkes M, Rabzel M, et al. Multiphasic screening. Case-finding tool in a Teaching Hospital Medical Clinic. JAMA. 1977;237(9):887-91. [pmid: 576328].
46 Knox EG. Multiphasic screening. Lancet. 1974;2(7894):1434-6. [pmid: 4140342].
47 Collen MF, Dales LG, Friedman GD, et al. Multiphasic checkup evaluation study. 4. Preliminary cost benefit analysis for middle-aged men. Prev Med. 1973;2(2):236-46. [pmid: 4723639].
48 Frijling B, Hulscher ME, van Leest LA, et al. Multifaceted support to improve preventive cardiovascular care: a nationwide, controlled trial in general practice. Br J Gen Pract. 2003;53(497):934-41. [pmid: 14960217]. [pmcid: 1314746].
49 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295]. [pmcid: 428525].
50 Jacob Cohen. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale, N.J.: L. Erlbaum Associates; 1988.
51 Rosenthal R. Parametric Measures of Effect Size. New York: Russell Sage Foundation Publications; 1994.
52 Lee A. Becker. 2006. Effect Size Measures for Two Independent Groups. Available at: [underlined: http://web.uccs.edu/lbecker/Psy590/es.htm#II.%20independent] . accessed 2006 Feb 16.
53 Patrick DL, Grembowski D, Durham M, et al. Cost and outcomes of Medicare reimbursement for HMO preventive services. Health Care Financ Rev. 1999;20(4):25-43. [pmid: 11482123].
54 Elder JP, Williams SJ, Drew JA, et al. Longitudinal effects of preventive services on health behaviors among an elderly cohort. Am J Prev Med. 1995;11(6):354-9. [pmid: 8775655].
55 Morrissey JP, Harris RP, Kincade-Norburn J, et al. Medicare reimbursement for preventive care. Changes in performance of services, quality of life, and health care costs. Med Care. 1995;33(4):315-31. [pmid: 7731275].
56 Burton LC, Steinwachs DM, German PS, et al. Preventive services for the elderly: would coverage affect utilization and costs under Medicare?. Am J Public Health. 1995;85(3):387-91. [pmid: 7892924]. [pmcid: 1614868].
57 Stone DH, D'Souza MF. Multiphasic screening in middle age: results and implications of a controlled trial in British general practice. Isr J Med Sci. 1981;17(23):215-21. [pmid: 7228648].
58 Theobald H, Bygren L, Carstensen J, et al. Effects of an assessment of needs for medical and social services on long-term mortality: a randomized controlled study. Int J Epidemiol. 1998;27(2):194-8. [pmid: 9602398].
59 Imperial Cancer Research Fund OXCHECK Study Group. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study. BMJ (Clinical research ed). 1995;310:1099-104.
60 Norman P, Conner M. Health checks in general practice: the patient's response. Fam Pract. 1992;9(4):481-7. [pmid: 1490543].
61 Grimaldi JV. The worth of occupational health programs: a new evaluation of periodic physical examinations. J Gnathol. 1965;56(1):365-74.
62 Roberts NJ, Ipsen J, Elsom KO, et al. Mortality among males in periodic-health-examination programs. N Engl J Med. 1969;281(1):20-4. [pmid: 5785733].
63 Slesinger DP, Tessler RC, Mechanic D. The effects of social characteristics on the utilization of preventive medical services in contrasting health care programs. Med Care. 1976;14(5):392-404. [pmid: 1271880].
64 Tao G, Zhang P, Li Q. Services provided to nonpregnant women during general medical and gynecologic examinations in the United States. Am J Prev Med. 2001;21(4):291-7. [pmid: 11701300].
65 Williams RB, Boles M, Johnson RE. A patient-initiated system for preventive health care. A randomized trial in community-based primary care practices. Arch Fam Med. 1998;7(4):338-45. [pmid: 9682687].
66 Hahn DL. The delivery of clinical preventive services: acute care intervention. J Fam Pract. 1999;48(10):785-9. [pmid: 12224676].
67 Finkelstein MM. Preventive screening. What factors influence testing?. Can Fam Physician. 2002;481:494-501.
68 Somkin CP, McPhee SJ, Nguyen T, et al. The effect of access and satisfaction on regular mammogram and Papanicolaou test screening in a multiethnic population. Med Care. 2004;42(9):914-26. [pmid: 15319618]. [pmcid: 1618783].
69 Parchman M, Byrd T. Access to and use of ambulatory health care by a vulnerable Mexican American population on the U.S.-Mexico border. J Health Care Poor Underserved. 2001;12(4):404-14. [pmid: 11688192].
70 Sox CH, Dietrich AJ, Tosteson TD, et al. Periodic health examinations and the provision of cancer prevention services. Arch Fam Med. 1997;6(3):223-30. [pmid: 9161346].
71 Schneider GW, DeHaven M, Snell LM. Fostering a culture of prevention in a residency program through a continuous quality improvement project. Am J Med Qual. 2003;18(2):82-9. [pmid: 12710557].
72 Geiger WJ, Neuberger MJ, Bell GC. Implementing the US preventive services guidelines in a family practice residency. Fam Med. 1993;25(7):447-51. [pmid: 8375602].
73 Lin SX, Gebbie KM, Fullilove RE, et al. Do nurse practitioners make a difference in provision of health counseling in hospital outpatient departments?. J Am Acad Nurse Pract. 2004;16(10):462-6. [pmid: 15543924].
74 Flocke SA, Stange KC. Direct observation and patient recall of health behavior advice. Prev Med. 2004;38(3):343-9. [pmid: 14766118].
75 Nutting PA, Baier M, Werner JJ, et al. Competing demands in the office visit: what influences mammography recommendations?. J Am Board Fam Pract. 2001;14(5):352-61. [pmid: 11572540].
76 South-East London Screening Study Group. A controlled trial of multiphasic screening in middle-age: results of the South-East London Screening Study. Int J Epidemiol. 2001;30(5):935-40. [pmid: 11689496].
77 Hama Y, Masumori K, Tagami H, et al. Preassignment examination for personnel on Iwo Jima. Mil Med. 2001;166(8):721-4. [pmid: 11515325].
78 Burton LC, Paglia MJ, German PS, et al. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. The Medicare Preventive Services Research Team. Prev Med. 1995;24(5):492-7. [pmid: 8524724].
79 German PS, Burton LC, Shapiro S, et al. Extended coverage for preventive services for the elderly: response and results in a demonstration population. Am J Public Health. 1995;85(3):379-86. [pmid: 7892923]. [pmcid: 1614862].
80 Burton LC, German PS, Shapiro S. A preventive services demonstration. Health status, health behaviors, and cost outcomes 2 years after intervention. The Johns Hopkins Medicare Preventive Services Demonstration Team. Med Care. 1997;35(11):1149-57. [pmid: 9366893].
81 Langham S, Thorogood M, Normand C, et al. Costs and cost effectiveness of health checks conducted by nurses in primary care: the Oxcheck study. BMJ. 1996;312(7041):1265-8. [pmid: 8634616]. [pmcid: 2351075].
82 Nakanishi N, Tatara K, Fujiwara H. Do preventive health services reduce eventual demand for medical care?. Soc Sci Med. 1996;43(6):999-1005. [pmid: 8888469].
83 Chiou CJ, Chang HY. Do the elderly benefit from annual physical examination? An example from Kaohsiung City, Taiwan. Prev Med. 2002;35(3):264-70. [pmid: 12202069].
84 Christensen B. Payment and attendance at general practice preventive health examinations. Fam Med. 1995;27(8):531-4. [pmid: 8522084].
85 Halterman S, Camero C, Maillet P. The consumer-driven approach: can it pick up where managed care left off?. Benefits Q. 2003;19(2):13-26. [pmid: 12827841].
86 Samuel TW, Raleigh SG, Hower JM, et al. The next stage in the health care economy: aligning the interests of patients, providers, and third-party payers through consumer-driven health care plans. Am J Surg. 2003;186(2):117-24. [pmid: 12885601].
87 Donahue KE, Ashkin E, Pathman DE. Length of patient-physician relationship and patients' satisfaction and preventive service use in the rural south: a cross-sectional telephone study. BMC Fam Pract. 2005;6(1):40. [pmid: 16202146]. [pmcid: 1262705].
88 Piette JD, Heisler M, Krein S, et al. The role of patient-physician trust in moderating medication nonadherence due to cost pressures. Arch Intern Med. 2005;165(15):1749-55. [pmid: 16087823].
89 Thom DH, Kravitz RL, Bell RA, et al. Patient trust in the physician: relationship to patient requests. Fam Pract. 2002;19(5):476-83. [pmid: 12356698].
90 Mayer JA, Jermanovich A, Wright BL, et al. Changes in health behaviors of older adults: the San Diego Medicare Preventive Health Project. Prev Med. 1994;23(2):127-33. [pmid: 8047517].
91 Stone DH, Shannon DJ. Screening for impaired visual acuity in middle age in general practice. Br Med J. 1978a;2(6141):859-61. [pmid: 709095]. [pmcid: 1607952].
92 Stone DH, Crisp AH. The effect of multiphasic screening on aspects of psychiatric status in middle age: results of a controlled trial in general practice. Int J Epidemiol. 1978b;7(4):331-4. [pmid: 744670].
93 Trevelyan H. Study of evaluate the effects of multiphasic screening within general practice in Britain: design and method. Prev Med. 1973;2(2):278-94. [pmid: 4723641].
94 Dales LG, Friedman GD, Ramcharan S, et al. Multiphasic checkup evaluation study. 3. Outpatient clinic utilization, hospitalization, and mortality experience after seven years. Prev Med. 1973;2(2):221-35. [pmid: 4723638].
95 Ramcharan S, Cutler JL, Feldman R, et al. Multiphasic checkup evaluation study. 2. Disability and chronic disease after seven years of multiphasic health checkups. Prev Med. 1973;2(2):207-20. [pmid: 4723637].
96 Dales LG, Friedman GD, Collen MF. Evaluating periodic multiphasic health checkups: a controlled trial. J Chronic Dis. 1979;32(5):385-404. [pmid: 109452].
97 Norinder A, Persson U, Nilsson P, et al. Costs for screening, intervention and hospital treatment generated by the Malmo Preventive Project: a large-scale community screening programme. J Intern Med. 2002;251(1):44-52. [pmid: 11851864].
98 Eaton CB, Goodwin MA, Stange KC. Direct observation of nutrition counseling in community family practice. Am J Prev Med. 2002;23(3):174-9. [pmid: 12350449].