# Acknowledgments

The Evidence-based Practice Center thanks Karen Robinson for her assistance in developing the electronic search strategies, Steven Bressler for his assistance with literature searching and database management, Gabriel Lai for his assistance with data entry and cleaning, Christine Napolitano for her assistance with budget matters and the final preparation of the report, and Brenda Zacharko for her assistance with final preparations of the report.