# Results

## Results of Literature Search and Abstract Review Process

A summary of the results of the search and review process is provided in Figure 2.

In addition to the 7003 citations retrieved by the search methods, we retrieved 64 citations through hand searching. Using the duplicate removal feature of SRS 3.0, and reviewer observation, we identified 544 duplicates, leaving 6523 for title review. Of these, we reviewed 2021 at the abstract level. We included 819 articles in the full article inclusion/exclusion portion of the review. Of these, 54 articles were promoted for full data abstraction and quality assessment. These 54 articles represented 36 studies that reported multiple outcomes and/or multiple follow ups. Full data abstraction was completed only on the 36 studies integrating data from all 54 articles.

Because many articles had more than one reason to be excluded the abstract reviewers did not need to agree on the main reason for exclusion applied at the abstract level. The two most frequent reasons for exclusion were that the article did not include any useful information for this review (762 abstracts), and no original data was presented (either a review or an opinion piece) (523 abstracts). The remaining reasons for exclusion were: study included only subjects less than 18 years old (75 abstracts), and not an English language study (4 abstracts). Articles could be excluded for more than one reason at this level.

## Results of Article Inclusion/Exclusion Process

From the abstract review process, 819 citations were identified for the article inclusion/exclusion phase. At this level 762 articles (93%) were excluded, and 3 were not retrievable. The most frequent reasons for exclusion were that the article did not include any original data (390 articles), the article did not apply to any of the Key Questions (372 articles), the exposure in the study was not a PHE (310 articles), and the article focused on specific preventive service delivery (215 articles). Of the 54 articles (36 studies) included in this report, Key Question 1 was addressed by all studies, Key Questions 2 was addressed by 36 studies, and Key Question 4 was addressed by 5 studies. Articles could be excluded for more than one reason at this level. A listing of the included articles and the excluded articles with the reasons for exclusion is included in this report (Appendix E ^a^).

a Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/phetp.htm

## General Study Characteristics

We identified a total of 36 studies containing information applicable to the Key Questions. A description of study characteristics is listed in Table 1. The most common study design was cross-sectional (14 studies), followed by RCTs (11) and cohort studies (7). Overall, the literature was characterized by complexity and heterogeneity in several dimensions. Studies were conducted over a period of several decades (19 from 1990 and later, 9 between 1970 and 1989, 4 before 1970, 4 articles did not indicate when the study was conducted) (Table 1). Practice settings for the studies were also diverse, with 16 studies taking place in ambulatory practice offices, seven in academic practice settings and four in hospital outpatient clinics. Studies described family medicine physicians, internal medicine physicians and general practice physicians as delivering the PHE. Studies reflected a range of health plans as well, with 10 studies in non-U.S. national health plans, four in Medicare settings, four in employer health plans and two in staff-model HMOs. While 25 studies were performed in the U.S., we also identified relevant studies from the U.K., Canada, Taiwan, Japan, Denmark and Sweden

In addition to study setting and population, heterogeneity was evident in how the PHE was delivered. Some studies reported on the effects of receiving PHEs over a period of time, but most studies reported on receiving the PHE at one point in time. While all studies included some sort of comparison to the PHE, some studies compared the PHE to usual care (which was defined heterogeneously or no system for the organized delivery of preventive services), and some observational studies compared exposure to a PHE to lack of exposure to a PHE (Table 2). The definition of the PHE also varied substantially across studies (see Key Question 1). Receipt of the PHE in intervention groups offered the PHE ranged from 54% to 100% across studies.

Studies described a wide range of outcomes including clinical preventive service delivery, health behaviors, hospitalization, and mortality. Most studies reported on multiple outcomes: 13 studies reported on one outcome; 5 studies reported on two; and 18 studies reported on three or more. (Table 3) Eleven articles reported on delivery of at least three delivery of clinical preventive services outcomes, three reported on at least three proximal clinical outcomes, and three reported on at least three distal clinical or economic outcomes.

### Randomized Controlled Trials

The 11 RCTs studying the value of the PHE spanned a variety of populations and settings including: Medicare demonstration projects, Veterans Administration Medical Centers, Kaiser Health Plan, South London, Denmark and Sweden. Four trials were performed in 1990 or later, three were performed in the 1980s and four were performed before 1980 (1964, 1967, 1969 and 1974.) Every outcome measured in the report had results from at least one randomized controlled trial. (Table 2)

Medicare Demonstration Projects. Four RCTs examined the effect of the PHE in Medicare populations through demonstration projects sponsored by the Health Care Financing Administration. The goal of these projects was to determine whether Medicare payment for preventive services delivered to seniors results in better health and decreased health care utilization. In one Medicare demonstration study in 2558 patients, performed in 1993 at Group Health Cooperative of Puget Sound HMO in Seattle, the PHE was delivered in the context of a “preventive service package” in which patients received clinical preventive services including a health risk assessment, a health promotion visit (including health risk appraisals, positive behavior reinforcement, referrals for interventions where appropriate), disease prevention visit (visit with nurses and physicians who conducted history and physical examinations and reviewed patients' health risks), and follow up educational classes (group exercise classes, “planning” ahead classes with advanced directives and long-term care insurance.) ^53^ Counseling on exercise, high fiber/low fat diet and advance directives was also offered to all intervention group participants. The health promotion and disease prevention visits and the exercise classes were conducted annually for two years. The comparison group received clinical preventive services as customarily offered in their physicians practices. Immunization, health habits, patient attitudes, body mass index (BMI), costs and mortality were measured outcomes; some outcomes were measured at completion of the two-year intervention while others were also assessed two years after intervention completion (4 years from baseline). Fifty-one percent of eligible enrollees participated in study. Of the treatment group, approximately 90% had health-promotion and disease-prevention visits in the first intervention year, and approximately 83% had visits in year two. Seventy-eight percent had all four visits in years one and two, and 9% had no visits. However, only 24% of the treatment group attended any offered classes. The main limitation to this study is generalizability to non-elderly non-Medicare populations. Other limitations include suboptimal reporting on blinding, potentially inadequate adjustment for residual confounding, and poor description of study outcomes.

In a second Medicare demonstration project beginning in 1993, 1203 subjects who were Medicare beneficiaries enrolled in a health maintenance organization in San Diego were randomly assigned to receive either a PHE comprised of selected clinical tests and immunizations, a health risk appraisal with individual counseling, and a series of health promotion sessions or usual care. The health risk appraisal and health promotion workshops were offered for one year. In the second year of the intervention, individual counseling was continued. Outcomes assessed included health habits, BMI and blood pressure. Behaviors were assessed from patients' self reports; blood pressure was measured. ^54^ Ninety-six percent of the intervention group completed the health risk appraisal and individual counseling, 87% attended at least one group session, and 59% attended at least six group sessions. Limitations in this study include suboptimal reporting on differences between study enrollees and non-enrollees, blinding and participant withdrawals. In addition, the results may not be generalizable outside the Medicare population.

A third study reporting on a Medicare demonstration project described results for 1914 participants in 10 primary care practices in central North Carolina, with chart abstraction on 455 patients. ^55^ Physicians of patients randomized to the intervention group received annual capitated payments for preventive care and health promotion packages, prompting to routinely schedule preventive care visits, office system changes for nurse delivery of preventive care and a form for charting preventive care. Patients were randomized within physician practices, and intervention group patients received the “preventive service package” at no cost. The “preventive service package” included annual history and physical, Pap smear, breast exam, eye exam, hearing test, depression test, influenza and pneumovax immunizations, cholesterol tests, fecal occult blood testing, urinalysis and a urinary incontinence test. Each clinical screening service had recommended intervals for delivery, and nurses were responsible for delivery of most of the preventive care services. The “preventive service package” (history and physical and recommended tests) was offered once a year for two years. One hour health promotion sessions were offered twice a year for two years and included physical activity, nutrition and stress management classes with others offered based on risk. Practices received monthly prompting to schedule prevention appointments, and nurses received training to conduct the prevention/health promotion services offered. Special chart forms were used for services delivered as part of the intervention. The comparison group received clinical preventive services as customarily offered in their physicians practices. Study outcomes assessed included Pap smear, immunization, cholesterol screening, fecal occult blood screening, mammogram, costs and hospitalizations. Outcomes were assessed through chart review on a sample of practices, participant interview and Medicare claims records. Outcomes assessments based on interviews and chart review occurred between 12 and 26 months after the beginning of the intervention; cost outcomes were assessed 1 year after completing the intervention (3 years after beginning of intervention.) The authors report 45% of eligible patients were recruited to participate. Of the 954 participants randomized to the intervention group, 88% received at least one clinical screening and 87% received at least one health promotion service. The primary limitation of this study is that the results may not be generalizable beyond the Medicare population.

The fourth Medicare demonstration project was conducted in Baltimore in 1989 and randomized 4195 participants to receive a physical examination, history and evaluation, laboratory procedures and immunizations, and counseling for health risks or else usual care. ^56^ Intervention participants received a voucher for a preventive exam from their physician once a year for two years. The history and physical exam included vision, hearing, dentition, breast exam, pelvic exam with Pap smear and digital rectal exam. Fecal occult blood tests and total serum cholesterol tests were performed. Vouchers for counseling visits were issued if physicians requested them; counseling could include smoking, exercise, diet, alcohol use/abuse, emotional distress, injury prevention/ falls, medication use/adverse reactions, sleep problems, functional status and urinary incontinence. Outcomes measured included Pap smear, health habits (smoking, problem drinking), health status, costs, hospitalizations and mortality. Some outcomes were measured at the end of the two-year intervention, and some were measured two years later. Outcomes were assessed by a combination of self-report and Medicare claims data. Sixty-three percent of the intervention group had a preventive clinical visit; 52% had a counseling visit. In year two, 32% made a preventive visit and 33% made a counseling visit. The study's limitations included suboptimal reporting of blinding and that the results may not be generalizable beyond the Medicare population.

Veteran Affairs Medical Center. One randomized controlled trial, beginning in 1981, took place in the Seattle Veterans Affairs Medical Center. ^44^ In this study, 1224 male patients were randomized to receive the PHE in the context of a “health promotion clinic” versus other supplementary services versus usual care. We include the 647 patients offered the “health promotion clinic” or usual care in this review (the other patients (n=577) received other supplementary services to encourage preventive service compliance not pertinent to this report). In the “health promotion clinic,” nurse practitioners, with backup consultation by general internists, delivered screening, counseling and referral protocols tailored to participants' age, gender and other risk factors. These were similar to the 1989 USPSTF recommended activities and included history and physical examination items (alcoholism screen, smoking assessment, blood pressure check, breast examination); laboratory testing (fecal occult blood, cholesterol, tuberculin skin test, VDRL, Pap smear and mammography); tetanus/diphtheria and influenza vaccination, and counseling on breast self-examination and alcoholism and smoking cessation. Results of screening were given to the patient and to their usual medical care provider. The “health promotion clinic” was offered for five years. Outcomes were assessed by chart review five years after trial completion, compared to baseline, and included alcohol or smoking screening, influenza immunization and fecal occult blood testing. Seventy-one percent of those in the intervention group participated in the health promotion clinic during year one, and 78% of participants came to the health promotion clinic in either year one or year two. In year two, 90% of those attending in year one returned for the second annual screening. Limitations of this study included lack of detail provided on the study population or the content of the PHE and limited generalizability. Although this study was designed to assess this outcome directly, its limitations included suboptimal description of the study population, no reporting on any blinding, and its potentially limited generalizability to men receiving care in the VA setting.

South London, U.K. One study, performed in 1967, was a large randomized controlled trial of nearly 7,000 community dwelling persons in South London who attended one of two group general practices. This study was designed to assess the value of introducing a general practice based screening service (compared to usual care) for persons age 40–64 and followed patients for nine years for the incidence of co-morbid illnesses, hospitalization or mortality. ^57^ The general practice based multiphasic screening service was described as a visit in which patients completed a “symptoms questionnaire” and occupational history followed by a physical examination performed by nurses (primarily, supervised by a physician) and several screening tests. The goal was to screen for ischemic heart disease, elevated blood pressure, chronic bronchitis, diabetes, thyroid imbalance, arthritis, obesity, varicose veins and hearing and visual defects. Specific physical exam components included height, weight, blood pressure, skinfold, skin, mouth, joints, abdomen, legs, breast and pelvic exams; screening tests included pulmonary function tests, vision, audiometry, chest X-ray, ECG, blood count, blood urea, blood glucose, serum cholesterol, protein-bound iodine, uric acid and fecal occult blood testing. Two years after the first multiphasic screening, participants with initially abnormal screening results were invited to have a second screening. Outcomes included disease detection, health habits, disability, hospitalization and mortality up to nine years. Health habits and disability were self-reported. Seventy-three percent of eligible individuals participated in the first health screening of which 99% had both clinic tests and a physical examination. Limitations of this study include suboptimal reporting on blinding, suboptimal adjustment of confounders and incomplete presentation of statistical significance. In addition, this study was performed before the USPSTF or similar contemporary preventive services guidelines were in effect which may limit inferences that can be drawn.

Small Canadian RCT. The goal of this trial, performed in Canada in 1974, was to determine if a multiphasic screening program helps physicians identify new medical problems. One hundred twelve physicians in an academic teaching setting were randomized to a) have their patients undergo a multiphasic screening program, b) have their patients receive usual care followed by formal medical records abstraction, or c) have their patients receive usual care followed by an informal chart review by the physicians themselves. Patients ages 40 to 65 years being seen at least twice in the past year were eligible for the study, and one patient per physician was studied. The patients in the multiphasic screening program arm received their multiphasic exam after the regular physician visit. One to two weeks after the visit, physicians were given additional information about their patients according to the randomized study groups: multiphasic screening results, results from chart abstraction or being able to review their patients chart for 15 minutes. Disease detection of all new problems and all “important” problems were outcomes measured before and after the intervention. In the multiphasic screening program, patients were administered a “standard health questionnaire” followed by a physical examination and several screening tests. ^45^ The exam and screening tests included blood pressure, height, weight, visual acuity, tonometry, audiometry, blood leukocyte count, hematocrit, syphilis serology, 16-channel automated biochemistry profiles, urinalysis, ECG, chest X-ray, vital capacity, breast exam and Pap smear. Limitations of this study include suboptimal reporting on blinding and on the study population characteristics as well as potentially incomplete adjustment for residual confounding. In addition, this study was performed before the USPSTF or similar contemporary preventive services guidelines were in effect which may limit inferences that can be drawn.

Kaiser Multiphasic Health Checkup Study. A large trial randomized 10,713 Kaiser Health Plan members ages 35–54 years in 1964 to either being encouraged to undergo an annual multiphasic health checkup or receiving usual care. ^41^ The study group resided in San Francisco, Oakland or Berkley and had to have at least two years continuous membership in the health plan. The intervention group received an initial letter and then regular phone calls over the eleven year study period urging them schedule a multiphasic health checkup appointment annually. The multiphasic health checkup consisted of a series of laboratory and radiologic tests, self-administered history, and follow up physical exam by an internist. Testing included ECG, sphygmomanometery, anthropometry, chest and breast X-rays, visual acuity, tonometry, audiometry, spirometry, urine test and serum chemistry panel. After the evaluation, the patient's regular internist received a report of the results. Outcomes assessed included costs, self-reported disability and mortality. Mortality outcomes were followed up to 16 years. Fifty-four percent of the intervention group received four or more multiphasic check-ups over the first seven years compared to 13% of the control group. Eighty-three percent of the intervention group at had least one examination over seven years compared to53% of the control group. The limitations of this study include suboptimal reporting on any blinding as potential inadequate adjustment for confounders. As in other studies conducted before contemporary clinical preventive services guidelines were developed, this study may not have the same potential for improving health outcomes as later trials.

Stockholm, Sweden. This large RCT was conducted in Stockholm in 1969 to investigate the long-term effects of one “general health screening” on mortality. ^58^ In this study of over 32,000 residents ages 18 to 65 years, 2,578 underwent the general health screening. The “general health screening” included social, psychiatric and medical interviews, blood tests, physical examinations, ECGs, exercise tests, psychological tests and eye and dental examinations. Each participant was screened over the course of one day by social workers, psychiatrists and physicians. Mortality over 20 years was assessed by the national death registry. Eighty-four percent of individuals offered the health screening were examined. Limitations of this study include suboptimal reporting on blinding, differences between participants and non-participants, description of study population characteristics and detailed description of the PHE. In addition, there was potentially inadequate consideration of confounders. Finally, the PHE was performed in before USPSTF guidelines were available.

OXCHECK. This RCT was conducted in five urban and suburban general practices in Bedfordshire, England in 1989, and studied the effectiveness of health checks delivered by nurses in primary care in reducing risk factors for cardiovascular disease and cancer. ^59^ Over 11,000 individuals aged 35 to 64 years who returned a health questionnaire were randomly allocated to health checks during one of four years. This report focuses on participants who received a health check in year one of the study (n=2205) and year four (n=1660) compared to participants who received their first health check in year four (n=1916). The health check consisted of a 45 to 60 minute visit with medical history, lifestyle questionnaire, structured dietary assessment, height, weight, blood pressure, and serum cholesterol. Post visit counseling was also given. Nurses were formally trained to conduct health checks per a standard protocol. Outcomes included health habits, blood pressure, cholesterol level, BMI, and cost effectiveness. Of the 2205 participants in the intervention group (receiving PHE in year 1 and year 4), 75% received the health check at year 4. Limitations in this study include reporting on blinding and potentially inadequate adjustment for confounders.

U.K. System-level Intervention. This RCT examined an intervention on the uptake of the PHE. This study, published in 1992, randomized patients of a general practice in the Norfolk, England to receive either an invitation for a scheduled health check or an open invitation for a health check. ^60^ The health check consisted of a history and physical examination performed by a nurse, followed by the generation of a personalized letter summarizing results and providing personalized advice regarding health changes. Eight hundred eighteen patients ages 30 to 41 years were randomized. The outcome was attendance at the PHE. Limitations of this study include lack of reporting of detailed study population characteristics and potentially inadequate adjustment for confounding.

### Benefits and Limitations of RCTs Assessing the PHE

RCTs provide the only study design capable of minimizing bias due to unmeasured confounding. However, it is difficult to follow long-term outcomes in RCTs, especially with the delay expected between the effects of health interventions mediated through the PHE (at times only one PHE was received in these studies) and durable effects many years later. During this time period, participants in RCTs may have many other interactions with the health care system which could limit the ability to detect meaningful differences in health outcomes. Randomized trials of the PHE also are expensive, and although the study design maximizes internal validity, results from one study population may not be broadly generalizable to others. Moreover, only one third of RCTs evaluating the PHE were performed in 1990 or later when the USPSTF guidelines were in effect. Earlier studies would not be expected to have the same effects on health outcomes as later trials if they did not incorporate contemporary preventive service guidelines.

### Benefits and Limitations of Observational Studies Assessing the PHE

Observational studies on the PHE have inherent limitations that lessen inferences that can be drawn from their results. First, persons undergoing a PHE or volunteering for a PHE are likely healthier than those who do not. This selection bias can confound measurements of health outcomes, and possibly also preventive service delivery if physicians are less likely to recommend services to ill patients. Observational studies collecting information from self-report are subject to recall bias, and studies collecting information on preventive services from chart review are subject to the bias that clinicians may be more likely to record counseling services during a PHE. While some studies attempt to adjust for these issues, residual confounding usually remains a concern.

Despite their limitations, evidence from observational studies on the value of the PHE is included in this report (Table 2). Over 80% of studies conducted since 1990 have an observational design, likely due to the fact that randomized trials of the PHE are by nature large and very expensive. Thus, in order to consider the body of recent evidence on the PHE and to incorporate diverse populations (e.g., women, ethnic minorities), observational studies are included, while fully acknowledging their limitations.

Seven cohort studies, fourteen cross-sectional studies and three studies with pre/post comparison design assessed the value of the PHE. Nineteen of the studies took place in 1990 or later, two between 1980 and 1989 and three before 1980. The study populations were quite diverse ranging from middle management employees, to elderly residents in Taiwan, to primary care clinic patients in settings across the U.S. Just as in the RCTs, the observational studies reported on a wide range of outcomes of the PHE.

### Article Quality

The quality of reporting on studies varied, with only one study receiving quality scores in the highest tertile for external validity, internal validity, and quality of statistical analysis. ^55^ (Table 4) The majority of studies received varied ratings for external validity and internal validity, while five studies received scores in the lowest tertile for external validity, internal validity, and quality of statistical analysis (Table 4). ^28,^ ^61^ – ^64^ Total quality scores for experimental trials were generally high (median score of 68 (range 56 to 87) out of 100 total possible points). Total quality scores for observational studies were also generally high, but with more variability in range (median score of 63 (range 37 to 77) out of 100 total possible points). Total quality scores are included in the evidence tables Appendix G).

## Key Question 1: What Definitions are Used for the Adult PHE in Studies of its Value?

Summary of findings. Definitions of the PHE were heterogeneous. While central elements used to define the PHE included the clinical history and risk assessment of patients and a physical examination, the specific composition of these central elements varied among studies. The most frequently cited types of history and risk assessment performed were assessment of dietary, alcohol/substance abuse, and tobacco smoking risks; the least frequently cited types of risk assessment included assessment of calcium and folic acid intake. In many cases, the physical examination was referred to with no specific clarification of what components were included. When specified, the most frequently cited components of the examination were assessment of blood pressure, weight and height, breast examination, gynecological examination, and rectal examination; the least frequently cited components included neurological and foot examinations.

Findings. A description of components studies reported as being part of the PHE is listed in Table 5. The most frequently reported components involving history and risk assessment were: assessment of tobacco smoking (14 studies); alcohol and substance use (13 studies); dietary risk factors (12 studies); and physical activity (10 studies). Fewer studies included assessments of injury risk/injury prevention (6 studies), calcium intake (2 studies) or folic acid intake (2 studies). The most frequently reported components involving the physical examination were: blood pressure (18 studies), breast examination (12 studies), weight (12 studies), height (10 studies), and gynecological examination (10 studies). Fourteen studies described the delivery of the PHE in general terms (e.g., as a “well visit” or a “health maintenance visit”) without further reporting what specific components were included in the PHE itself. Fewer studies reported on assessments of pulse (4 studies) rectal, prostate, abdominal or neurological examinations (4 studies for each), neurological examination (3 studies) or foot examination (2 studies). Complete definitions of the PHE varied tremendously (Table 2).

## Key Question 2: What is the Evidence that a PHE, Delivered at Different Patient Ages or Different Frequencies, is Associated with Benefits Compared to Care Without a PHE?

Studies addressing Key Question 2 included studies reporting on the association of receipt of the PHE with: a) the delivery/receipt of seven clinical preventive services (gynecological examination/Pap smear, counseling, immunizations, cholesterol screening, colon cancer screening, and mammography); b) seven proximal clinical outcomes (disease detection, patient health habits, patient attitudes, health status, blood pressure, serum cholesterol, and BMI); c) three distal clinical outcomes (disability, hospitalization, and mortality); and d) economic outcomes (costs and cost-effectiveness).

### Delivery of Clinical Preventive Services

Gynecological Examination/Pap Smear

Summary of findings. Thirteen studies (including two RCTs and eleven observational studies) evaluated the association of receiving the PHE with delivery/receipt of the gynecological examination/Pap smear. The best available evidence to assess this outcome was comprised of two large RCTs, performed in the late 1980's, and it was deemed to be of “high” grade based on standard criteria. In these studies, the PHE had small to large positive effects on the receipt of the gynecological examination/Pap smear (see below for details). While these RCTs were specifically designed to assess the effect of the PHE on this outcome, they focused on Medicare recipients, and thus may be limited in their generalizability to other populations. Observational studies of the association of receipt of the PHE with receipt of the gynecological examination/Pap smear revealed both positive and mixed results. Observational studies had a variety of limitations, including potential confounding of results not accounted for and use of data subject to recall bias.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from two large RCTs, received an overall grade of “high.” In grading the evidence, these studies were found to have few serious limitations in quality, no important inconsistency with regard to the direction of effects, adequate data, and a low probability of reporting bias (Table 6). These two studies evaluated the effect of the PHE on the delivery/receipt of the gynecological examination/Pap smear among community dwelling Medicare recipients who received reimbursement for the PHE compared to Medicare recipients receiving usual care. While these studies were limited in their generalizability to other ambulatory populations, they were specifically designed to evaluate the effect of the PHE on delivery/receipt of clinical preventive services and therefore directly addressed Key Question 2 (Tables 2, 6 and 7).

Randomized controlled trials. Two randomized controlled trials performed in 1988 and 1989 studied Medicare recipients (over 5000 patient combined total). ^55,^ ^56^ Follow up of patients ranged from twelve to 26 months. In one study, funded as a Medicare demonstration project, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including annual history and physical on at least an annual basis, delivered by both a nurse and a physician. The comparison group received clinical preventive services as customarily offered in their physicians' practices. ^55^ In the other study, also funded as a Medicare demonstration project in which participants in the intervention group received vouchers for free preventive visits to be delivered by participants' primary care physicians, the PHE was described as consisting of a history and physical examination followed by the provision of USPSTF recommended clinical preventive services. The comparison group received no coverage for annual preventive visits or tests. ^56^ The PHE had a small positive effect (Cohen's d (95% confidence interval (CI)): 0.07 (0.07,0.07)) to a large positive effect (Cohen's d (95% CI):1.71 (1.69,1.73)) on delivery/receipt of the gynecological examination/Pap smear (Table 7, Evidence Table 1a). Limitations of these studies include their potential limited generalizability to non-Medicare populations (Table 2).

Observational studies. Observational studies evaluating the association of receipt of the PHE with delivery/receipt of the gynecological examination/Pap smear included one retrospective cohort study, eight cross-sectional studies, and two observational studies with pre-post design performed from 1976 to 2004. Study populations for these studies included patients seen in community practices who interacted (or did not interact) with a touch-sensitive computer system placed in primary care practices to promote the delivery of preventive services, ^65^ a cross-sectional audit of outpatient billing claims for adults seen at least once by a primary care provider classified by visit type (visits for preventive care vs. acute care), ^66^ female residents in Ontario, Canada who completed the National Population Health Survey reporting their use of annual examinations with answers linked to their use of services in a national health insurance plan, ^67^ respondents to a California telephone survey who were contacted to assess their access to preventive services and satisfaction with preventive services, ^68^ data from the National Ambulatory Medical Care and National Hospital Ambulatory Medical Care Surveys in which physicians completed forms describing reasons for ambulatory visits (including general medical visits or gynecological) and the receipt of preventive services, ^64^ Mexican-American participants in a telephone and door-to-door survey designed to assess access to and use of ambulatory health care, ^69^ patients randomly selected from 44 ambulatory outpatient clinics who completed a survey to ascertain their receipt of preventive services in the context of “checkup physical examinations” versus other types of visits, ^31^ patients from randomly selected community practices agreeing to complete a questionnaire and medical record review to assess their receipt of a “periodic health examination” and their receipt of recommended clinical preventive services, ^70^ employed health insurance enrollees responding to a questionnaire regarding the receipt of clinical preventive services in the past year, ^63^ patients in an ambulatory family practice residency clinic in which physicians participated in a quality improvement program to enhance the delivery of the “health maintenance examination” and clinical preventive services, ^71^ and family practice residents and faculty physicians using a practice-based teaching model to increase resident compliance with USPSTF guidelines. ^72^ Eight of these observational studies reported a positive association between receipt of the PHE and delivery/receipt of the gynecological examination/Pap smear, while three of these studies reported mixed results (Table 8, Evidence Tables 1b–d). Several limitations were noted among these observational studies including inability to completely control for potential confounding in several of the studies, lack of detail in studies' descriptions of the PHE, and the potential for recall bias in studies based on participant interviews/questionnaire responses (Table 2).

Preventive Counseling

Summary of findings. Thirteen studies (including one RCT and eight observational studies) evaluated the association of receiving the PHE with delivery/receipt of preventive counseling. A variety of types of counseling were examined within studies, including counseling regarding diet (6 studies), regarding physical activity (9 studies), smoking cessation (9 studies), alcohol/substance abuse (8 studies), injury prevention (3 studies), safe sexual practices (3 studies), calcium intake (one study), oral health (one study), sun exposure (one study), and general counseling (not otherwise specified) (one study). Four studies reported on other types of counseling. The delivery of all types of preventive counseling among studies was treated as a single outcome. The best available evidence to assess this outcome emanated from one RCT and six cross-sectional observational studies performed from1981 to 2004, and it was deemed to be of “low” grade based on standard criteria. Most studies reported a positive association of receiving a PHE with the delivery/receipt of preventive counseling with a strongly positive effect rendered by the PHE on delivery/receipt of smoking cessation counseling and alcohol abuse counseling in the RCT. Five observational studies reporting moderate to large positive associations of receipt of the PHE with receipt of counseling, while one observational study reported a negative association. The RCT was noted to have poor description of the study population and the PHE itself as well as its potentially limited generalizability to persons receiving care in the Veterans Affairs setting. However, this study did directly address Key Question 2. The seven cross-sectional studies were noted to have several limitations, including not directly addressing Key question 2, inability to completely control for potential confounding in several of the studies, lack of detail in studies' descriptions of the PHE, and the potential for recall bias in studies based on participant interviews/questionnaire responses.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from one RCT and six cross-sectional observational studies received an overall grade of “low.” In grading the evidence, these studies were found to have serious limitations in quality, moderate inconsistency in the direction of results (one observational study reporting a negative association with remaining studies reporting positive associations) but adequate data and low probability of reporting bias (Table 6). Although the RCT was designed to assess this outcome directly, its limitations included poor description of the study population and the PHE itself as well as its potentially limited generalizability to persons receiving care in the VA setting. ^44^ The seven cross-sectional studies were noted to have several limitations, including not being designed to specifically assess this outcome, inability to completely control for potential confounding in several of the studies, lack of detail in studies' descriptions of the PHE, and the potential for recall bias in studies based on participant interviews/questionnaire responses (Tables 2, 6 and 7).

Randomized controlled trial. In this study, patients attending a VA medical center were randomized to receive the PHE in the context of a “health promotion clinic” versus usual care. ^44^ The study measured the delivery of both alcohol abuse counseling and smoking cessation counseling. ^44^ The study began in 1981 with follow up for five years. Limitations of this study included lack of detail provided on the study population or the content of the PHE and limited generalizability. Delivery/receipt of alcohol abuse and smoking counseling were improved by randomization to the health promotion clinic in this study (Cohen's d (95% (CI)): 1.18 (1.17,1.21) and 1.09 (1.08,1.11), respectively) (Tables 2 and 7, Evidence Table 2a).

Observational studies. Observational studies evaluating the delivery/receipt of preventive counseling included six cross-sectional studies and two observational studies with pre-post design performed from 1993 to 2004. Study populations included reports from ambulatory patients across the U.S., ^73^ data from the National Ambulatory Medical Care and National Hospital Ambulatory Medical Care Surveys in which physicians completed forms describing reasons for ambulatory visits (including general medical visits or gynecological) and the receipt of preventive services, ^64^ outpatients seen in family practices in Ohio, ^42,^ ^74^ patients randomly selected from 44 ambulatory outpatient clinics who completed a survey to ascertain their receipt of preventive services in the context of “checkup physical examinations” versus other types of visits, ^31^ patients from randomly selected community practices agreeing to complete a questionnaire and medical record review to assess their receipt of a “periodic health examination” and their receipt of recommended clinical preventive services, ^70^ patients in an ambulatory family practice residency clinic in which physicians participated in a quality improvement program to enhance the delivery of the “health maintenance examination” and clinical preventive services, ^71^ and family practice residents and faculty physicians using a practice-based teaching model to increase resident compliance with USPSTF guidelines. ^72^ Six of these observational studies reported positive associations of receipt of the PHE with receipt of counseling, while one study reported a negative association and one reported mixed results (Table 8, Evidence Tables 2b–c). Several limitations were noted among these observational studies including inability to completely control for potential confounding in several of the studies, lack of detail in studies' descriptions of the PHE, studies not specifically designed to examine Key Question 2, and the potential for recall bias in studies based on participant interviews/questionnaire responses (Table 2).

Preventive Immunizations

Summary of findings. Nine studies (including three randomized controlled trials and six observational studies) evaluated the association of receiving the PHE with delivery/receipt of preventive immunizations. The association of receiving the PHE with delivery of a variety of immunizations was examined within studies, including the delivery of influenza (7 studies), tetanus (6 studies) and pneumonia (4 studies) vaccinations. Two studies reported on the delivery of other immunizations. The delivery of all types of preventive immunization among studies was treated as a single outcome. The best available evidence assessing this outcome, emanating from three RCTs performed from 1981 to 1999, and it was deemed to be of “medium” grade based on standard criteria. Results in these three RCTs were mixed with two studies reporting small to medium sized positive effects (two studies) and one study reporting a small negative effect of the PHE on delivery/receipt of preventive immunization. While these RCTs were specifically designed to assess the effect of the PHE on this outcome, they focused on Medicare recipients and patients of a Veterans Affairs medical center and thus may be limited in their generalizability to other populations. Six observational studies reported the PHE improved the delivery/receipt of preventive immunizations. Several limitations were noted among these observational studies including inability to completely control for potential confounding in several of the studies, lack of detail in studies' descriptions of the PHE or study populations, and studies not specifically designed to assess this outcome.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from three RCTs, received an overall grade of “medium.” In grading the evidence, these studies were felt to have some serious limitations in quality, and important inconsistency in the direction of results (Table 6). These three studies evaluated the effect of the PHE on the delivery/receipt of preventive immunizations among Medicare enrollees and patients of a Veterans Affairs medical center compared to similar patients receiving usual care. While these studies were limited in their generalizability to other ambulatory populations, they were specifically designed to evaluate the effect of the PHE on delivery/receipt of clinical preventive services and therefore directly addressed Key Question 2 (Tables 2, 6 and 7).

Randomized controlled trials. Three randomized controlled trials performed from 1981 to 1999 studied Medicare recipients and patients attending a VA medical center (over 5000 patients combined total). ^44,^ ^53,^ ^55^ Follow up of patients ranged from twelve months to five years. In one study, a Medicare demonstration project performed in 1993, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including a health risk assessment, a health promotion visit (including health risk appraisals, positive behavior reinforcement and referrals for interventions where appropriate), disease prevention visit (visit with nurses and physicians who conducted history and physical examinations and reviewed patients' health risks), and follow up educational classes. The comparison group received clinical preventive services as customarily offered in their physicians practices. ^53^ In the second study, also a Medicare demonstration project, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including annual history and physical on at least an annual basis, delivered by both a nurse and a physician. The comparison group received clinical preventive services as customarily offered in their physicians practices. ^55^ In the third study, patients attending a VA medical center were randomized to receive the PHE in the context of a “health promotion clinic” versus usual care. ^44^ The PHE improved delivery of preventive immunizations improved statistically significantly in two studies with effect sizes ranging from small to medium positive effects (Cohen's d (95% CI): 0.10 (0.10,0.10) and 0.35 (0.33,0.36), respectively).^53 55^ The PHE worsened delivery of preventive immunizations worsened in the group of VA patients attending a health promotion clinic, with a small magnitude of negative effect (Cohen's d (95% CI): -0.22(-0.20,-0.24)) ^44^ (Table 7, Evidence Table 3a). These studies have potentially limited generalizability to non-Medicare or VA populations (Table 2).

Observational studies. Observational studies evaluating the association of receipt of the PHE with delivery/receipt of preventive immunizations included one retrospective cohort study, three cross-sectional studies, and two observational studies with pre-post design performed from 1993 to 2003. Study populations included community-dwelling patients aged 70 and older, ^16^ a cross-sectional audit of outpatient billing claims for adults seen at least once by a primary care provider classified by visit type (visits for preventive care vs. acute care), ^66^ outpatients seen in family practices in Ohio, ^42^ patients randomly selected from 44 ambulatory outpatient clinics who completed a survey to ascertain their receipt of preventive services in the context of “checkup physical examinations” versus other types of visits, ^31^ patients in an ambulatory family practice residency clinic in which physicians participated in a quality improvement program to enhance the delivery of the “health maintenance examination” and clinical preventive services, ^71^ and family practice residents and faculty physicians using a practice-based teaching model to increase resident compliance with USPSTF guidelines. ^72^ All six of these observational studies reported a positive association between receipt of the PHE and the delivery of immunizations (Table 8, Evidence Tables 3b–c). Several limitations were noted among these observational studies including inability to completely control for potential confounding in several of the studies, lack of detail in studies' descriptions of the PHE or study populations, and studies not specifically designed to examine Key Question 2 (Table 2).

Cholesterol Screening

Summary of findings. Seven studies (including one RCT and six observational studies) evaluated the association of receiving the PHE with delivery/receipt of cholesterol screening. The best available evidence to assess this outcome was comprised of one RCT and four cross-sectional observational studies, performed from 1995 to 2003, and it was deemed to be of “medium” grade based on standard criteria. These studies demonstrated receiving the PHE was positively associated with receipt of cholesterol screening (small to large positive effect sizes). While the RCT was specifically designed to assess this outcome, it was limited to Medicare recipients and thus may be limited in its generalizability to other populations. The four cross-sectional observational studies had a variety of limitations, including the potential for recall bias in studies based on participant interviews/questionnaire responses, inability to completely control for potential confounding in several of the studies, and lack of detail in studies' descriptions of the PHE or study populations.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from one RCT and four cross-sectional observational studies, received an overall grade of “medium.” In grading the evidence, these studies were felt to have some serious limitations in quality, but they were consistent in the direction of findings, had adequate data to assess the outcome, and they had low probability of reporting bias (Table 6). The RCT evaluated the effect of the PHE on the delivery/receipt of the cholesterol screening among community dwelling Medicare recipients who received reimbursement for the PHE compared to Medicare recipients receiving usual care. While this study was limited in its generalizability to other ambulatory populations, it was specifically designed to evaluate the effect of the PHE on delivery/receipt of clinical preventive services and therefore directly addressed Key Question 2. The four cross-sectional studies were noted to have several limitations, including inability to completely control for potential confounding in several of the studies, lack of detail in studies' descriptions of the PHE and study populations, and the potential for recall bias in studies based on participant interviews/questionnaire responses (Tables 2, 6 and 7).

Randomized controlled trials. The RCT studied 455 Medicare recipients for 24 months beginning in 1995. ^55^ This study was a Medicare demonstration project in which the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including annual history and physical on at least an annual basis, delivered by both a nurse and a physician. The comparison group received clinical preventive services as customarily offered in their physicians practices. ^55^ Delivery/receipt of cholesterol screening was improved by randomization to the preventive care package in this study (Cohen's d (95% (CI)): 0.02 (0.00,0.04). This study was potentially limited in its lack of generalizability to non-Medicare populations (Tables 2 and 7, Evidence Table 4a).

Observational studies. Observational studies evaluating the delivery/receipt of cholesterol screening included four cross-sectional studies and two observational studies with pre-post designs performed from 1993–2003. Study populations included evaluated a variety of study subjects including female residents in Ontario, Canada who completed the National Population Health Survey reporting their use of annual examinations with answers linked to their use of services in a national health insurance plan, ^67^ a cross-sectional audit of outpatient billing claims for adults seen at least once by a primary care provider classified by visit type (visits for preventive care vs. acute care), ^66^ Mexican-American participants in a telephone and door-to-door survey designed to assess access to and use of ambulatory health care, ^69^ patients randomly selected from 44 ambulatory outpatient clinics who completed a survey to ascertain their receipt of preventive services in the context of “checkup physical examinations” versus other types of visits, ^31^ patients in an ambulatory family practice residency clinic in which physicians participated in a quality improvement program to enhance the delivery of the “health maintenance examination” and clinical preventive services, ^71^ and family practice residents and faculty physicians using a practice-based teaching model to increase resident compliance with USPSTF guidelines. ^72^ In four cross-sectional studies, receipt of the PHE was positively associated with the delivery/receipt of cholesterol screening while both pre-post studies reported neutral results (Table 8, Evidence Tables 4b–c). Several limitations were noted among these observational studies including inability to completely control for potential confounding in several of the studies, lack of detail in studies' descriptions of the PHE or study populations, and the potential for recall bias in studies based on participant interviews/questionnaire responses (Table 2).

Colon Cancer Screening

Summary of findings. Six studies (including two randomized controlled trials and four observational studies) assessed the association of receipt of the PHE with delivery/receipt of colon cancer screening. Both the delivery of fecal occult blood testing (6 studies) and sigmoidoscopy (4 studies) were studied. The delivery of all types of colon cancer screening among studies was treated as a single outcome. The best available evidence to assess this outcome was comprised of two randomized controlled trials, performed from 1988 to 1995, and it was deemed to be of “high” quality based on standard criteria. These studies reported large positive effects of the PHE on the delivery/receipt of fecal occult blood testing. While these studies were specifically designed to assess this outcome, one was noted to have poor description of the study population and the PHE itself. Both studies were limited by their focus on Medicare populations and patients receiving care in the Veterans Affairs setting.

Findings

Strength and limitations of the evidence. Six studies assessed the effect of the PHE on delivery/receipt of colon cancer screening. The best available evidence assessing this outcome, emanating from two RCTs, received an overall grade of “high.” In grading the evidence, one study was felt to have serious limitations in quality. However, these studies did not have important inconsistency in terms of the direction of the results, had sufficient data to ascertain results, and both studies demonstrated a strong association between the intervention and the outcome (Table 6). These two studies evaluated the effect of the PHE on the receipt of colon cancer screening among Medicare enrollees and patients of a Veterans Affairs medical center compared to similar patients receiving usual care. While these studies were limited in their generalizability to other ambulatory populations, they were specifically designed to evaluate the effect of the PHE on receipt of clinical preventive services and therefore directly addressed Key Question 2. These studies only evaluated the delivery of fecal occult blood testing in the setting of the PHE (Tables 2, 6 and 7).

Randomized controlled trials. Two randomized controlled trials performed from 1988 to 1995 studied Medicare recipients and patients attending a VA medical center (over 1000 patient combined total). ^44,^ ^55^ Follow up of patients ranged from 24 months to five years. In one study, a Medicare demonstration project, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including annual history and physical on at least an annual basis, delivered by both a nurse and a physician. The comparison group received clinical preventive services as customarily offered in their physicians practices. ^55^ In the second study, patients attending a VA medical center were randomized to receive the PHE in the context of a “health promotion clinic” versus usual care. ^44^ In both studies, receipt of the PHE improved delivery/receipt of fecal occult blood testing with large positive effect sizes (Cohen's d (95% CI): 1.19(1.17,1.21) and 1.07 (1.05,1.08), respectively). ^44,^ ^55^ (Table 7, Evidence Table 5a). Limitations of these studies included their potential limited generalizability to non-Medicare or VA populations (Table 2).

Observational studies. Observational studies evaluating the delivery/receipt of colon cancer screening included one retrospective cohort study, two cross-sectional studies, and one observational study with pre-post design performed from 1997–2003. Study populations included patients seen in community practices who interacted (or did not interact) with a touch-sensitive computer system placed in primary care practices to promote the delivery of preventive services, ^65^ a cross-sectional audit of outpatient billing claims for adults seen at least once by a primary care provider classified by visit type (visits for preventive care vs. acute care), ^66^ patients from randomly selected community practices agreeing to complete a questionnaire and medical record review to assess their receipt of a “periodic health examination” and their receipt of recommended clinical preventive services, ^70^ and patients in an ambulatory family practice residency clinic in which physicians participated in a quality improvement program to enhance the delivery of the “health maintenance examination” and clinical preventive services. ^71^ Both cross sectional studies reported receipt of the PHE was positively associated with delivery/receipt of both sigmoidoscopy and fecal occult blood testing, as did the pre-post study. The retrospective cohort study reported mixed results (Table 8, Evidence Tables 5b–d). Several limitations were noted among these observational studies including poor description of the study populations, inability to completely control for potential confounding in several of the studies, studies not specifically designed to answer Key Question 2 (Table 2).

Mammography

Summary of findings. Twelve studies (including one RCT and eleven observational studies) assessed the association of receipt of the PHE with delivery/receipt of mammography. The best available evidence to assess this outcome was comprised of one RCT and one retrospective cohort study. These studies were performed in 1988 and 1998, were deemed to be of “low” grade based on standard criteria. The PHE had a small positive effect on the receipt of mammography in the RCT study, while it had mixed effects in the observational study. While the RCT was limited in its generalizability to non-Medicare populations, it was specifically designed to assess the effect of the PHE on this outcome. In contrast, the retrospective cohort study was not specifically designed to assess this outcome, did not employ a detailed description of the PHE, and was potentially limited by inadequate adjustment for residual confounding.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from one RCT and one RCT analyzed as a retrospective cohort study, received an overall grade of “low.” In grading the evidence, these studies were felt to have some serious limitations in quality and important inconsistency in the direction of results. However the data were not deemed to be sparse, and the studies did not appear to have high probability of reporting bias (Table 6). The RCT evaluated the effect of the PHE on the receipt of mammography among community dwelling Medicare recipients who received reimbursement for the PHE compared to Medicare recipients receiving usual care. While this study was limited in its generalizability to other ambulatory populations, it was specifically designed to evaluate the effect of the PHE on receipt of clinical preventive services and therefore directly addressed Key Question 2. The other RCT studied the effectiveness of a computerized touch screen system employed in primary care practices to improve rates of preventive screening. While the study compared patients seen in primary care practices randomized to employ the touch screen system versus patients seen in practices not employing the touch screen system, they performed a retrospective chart review to assess whether patients in the intervention and control groups had received a “health maintenance examination” during the past year. Thus, for the purposes of our analyses, this study was analyzed as a retrospective cohort study (of persons exposed versus not exposed to the health maintenance examination) without regard to the study's randomized intervention. While this was a study of adult patients of all ages being seen in representative primary care practices, it was not designed to directly address Key Question 2 (Tables 2, 6 and 7).

Randomized controlled trials. The RCT studied 455 Medicare recipients for 24 months beginning in 1988. ^55^ This study was a Medicare demonstration project in which the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including annual history and physical on at least an annual basis, delivered by both a nurse and a physician. The comparison group received clinical preventive services as customarily offered in their physicians practices. ^55^ In this study, receipt of the PHE improved delivery/receipt of mammography with a small positive effect size (Cohen's d (95% CI): 0.14(0.12,0.16) (Tables 2 and 7, Evidence Table 6 a). ^55^ Inferences from this study are potentially limited to non-Medicare populations.

Observational studies. Observational studies evaluating the delivery/receipt of mammography included one RCT analyzed as a retrospective cohort study, eight cross-sectional studies, and two observational study with pre-post design performed from 1988–1998. Study populations included patients seen in community practices who interacted (or did not interact) with a touch-sensitive computer system placed in primary care practices to promote the delivery of preventive services, ^65^ respondents to a California telephone survey who were contacted to assess their access to preventive services and satisfaction with preventive services, ^68^ data from the National Ambulatory Medical Care and National Hospital Ambulatory Medical Care Surveys in which physicians completed forms describing reasons for ambulatory visits (including general medical visits or gynecological) and the receipt of preventive services, ^64^ female residents in Ontario, Canada who completed the National Population Health Survey reporting their use of annual examinations with answers linked to their use of services in a national health insurance plan, ^67^ a cross-sectional audit of outpatient billing claims for adults seen at least once by a primary care provider classified by visit type (visits for preventive care vs. acute care), ^66^ Mexican-American participants in a telephone and door-to-door survey designed to assess access to and use of ambulatory health care, ^69^ patients randomly selected from 44 ambulatory outpatient clinics who completed a survey to ascertain their receipt of preventive services in the context of “checkup physical examinations” versus other types of visits, ^31^ 93 physicians in an ambulatory practice network surveyed to recall the content of non-acute care visits with women age 40–75 years seen in their practices, ^75^ patients from randomly selected community practices agreeing to complete a questionnaire and medical record review to assess their receipt of a “periodic health examination” and their receipt of recommended clinical preventive services, ^70^ patients in an ambulatory family practice residency clinic in which physicians participated in a quality improvement program to enhance the delivery of the “health maintenance examination” and clinical preventive services, ^71^ and family practice residents and faculty physicians using a practice-based teaching model to increase resident compliance with USPSTF guidelines. ^72^ The RCT analyzed as a retrospective cohort study, performed in 1998, reported mixed associations of the PHE with receipt of mammography. Seven cross-sectional studies reported a positive association of receipt the PHE with receipt of mammography, while one reported a negative association. Both pre-post studies reported no statistically significant effect of the PHE on improving mammography rate (Table 8, Evidence Tables 6b–d). Several limitations were noted among these observational studies including poor description of the study populations, inability to completely control for potential confounding in several of the studies, studies not specifically designed to answer Key Question 2, and the potential for recall bias in studies based on participant interviews/questionnaire responses (Table 2).

### Proximal Clinical Outcomes

Disease Detection

Summary of findings. Three studies (including two RCTs and one observational study) assessed the association of receipt of the PHE with disease detection. The best available evidence to assess this outcome was comprised of two large RCTs, performed in 1967 and 1974, and it was deemed to be of “medium” quality based on standard criteria. The detection of all illnesses was treated as a single outcome. These studies reported the PHE had mixed effects on disease detection (increased disease detection in some cases, decreased detection in some cases, and no effect in some cases). While these studies were specifically designed to assess this outcome, they were both performed before the availability of USPSTF or similar contemporary clinical guidelines were in effect, thus inferences from these studies may be limited by dated approaches to the PHE.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from two large RCTs, received an overall grade of “medium.” In grading the evidence, these studies were felt to have at least one serious limitation in quality and inconsistency in the direction of their results. However, they were not found to have sparse data or a high probability of reporting bias (Table 6). One study was performed community dwelling persons in South London, and one study was performed in Canadian patients age 40 to 65 years being seen in an academic teaching setting. Both of these studies were performed before USPSTF or similar contemporary preventive services guidelines were in effect. Thus, while they were specifically designed to evaluate the effect of the PHE on the detection of disease (and therefore directly addressed Key Question 2), inferences drawn from these studies could be limited by dated approaches to the PHE (Tables 2, 6 and 7).

Randomized controlled trials. One study, performed in 1967, was a large randomized controlled trial of nearly 7,000 community dwelling persons in South London who attended one of two group general practices. This study was designed to assess the value of introducing a general practice based screening service (compared to usual care) for persons age 40–64 and followed patients for nine years for the incidence of co-morbid illnesses, hospitalization or mortality. ^57,^ ^76^ The general practice based screening service was described as a visit in which patients completed a “symptoms questionnaire” and occupational history followed by a physical examination performed by nurses (primarily, supervised by a physician) and several screening tests. In this study, the PHE was associated with increased detection of ischemia on an electrocardiogram (small positive effect-- (Cohen's d (95% CI): 0.03(0.02,0.03)), with decreased detection of angina and bronchitis symptoms (small negative effects--(Cohen's d (95% CI): -0.01(-0.01,-0.01) and -0.03 (-0.03,-0.03), respectively), and with no effect on the detection of increased diastolic blood pressure (Table 7, Evidence Table 7a). The second study, performed in 1974, identified Canadian patients age 40 to 65 years being seen by 112 physicians in an academic teaching setting and randomized patients (via physician) to a multiphasic screening program versus usual care. In the multiphasic screening program, patients were administered a “standard health questionnaire” followed by a physical examination and several screening tests. Patients were followed for twelve months for the development of co-morbid illnesses (referred to as “medical problems”). ^45^ In this study, the PHE was associated with increased detection of “all medical problems” and “important medical problems” (defined as medical problems in which the physician caring for the patients would be likely to investigate further and provide advice regarding the condition and any necessary treatment) with medium to large effect sizes (Cohen's d (95% CI): 0.96(0.84,1.08) and 0.53 (0.41,0.64), respectively) (Table 7, Evidence Table 7a). Inferences from these studies are limited by their performance before USPSTF or similar contemporary guidelines were in place as well as potentially incomplete accounting for potential confounding of outcomes (Table 2).

Observational studies. The one observational study on the association of receipt of the PHE with disease detection was a retrospective cohort study of 240 employees of the Japan Maritime Self-Defense Force working on the Iwo Jima military defense base in December 1999. The study reported lower rates of hyperlipidemia and severe obesity among personnel receiving a pre-assignment medical examination (described as a medical examination followed by screening testing) one year prior to the study when compared to those not receiving a pre-assignment medical examination (Table 8, Evidence Table 7b). Limitations of this study included potential inability to completely control for potential confounding and the study's potentially limited generalizability beyond Japanese military populations (Table 2). ^77^

Health Habits

Summary of findings. Five RCTs evaluated the effect of the PHE on patient health habits. The best available evidence to assess this outcome was comprised of five RCTs, performed from 1967 to 1989, and it was deemed to be of “medium” grade based on standard criteria. Changes in all health habits were treated as a single outcome. These studies demonstrated the PHE had mixed effects on patient health habits (improved health habits in some cases, worsened health habits in some cases, and no effect in some cases). While these studies were specifically designed to assess this outcome, one was performed before the availability of USPSTF or similar contemporary clinical guidelines were in effect, thus inferences from these studies may be limited by dated approaches to the PHE. Other studies were limited by their focus on Medicare enrollees or focus on participant living in the U.K. only. Health habits were assessed via self-report in all studies, thus results are potentially subject to recall bias.

Findings

Strength and limitations of the evidence. Five RCTs comprised the best evidence to assess this outcome, which received an overall grade of “medium.” When grading the evidence, these studies were felt to have at least one serious limitation in quality as well as important inconsistency in the direction of their results. However, they were not felt to have sparse data or high probability of reporting biased results (Table 6). Three studies funded as Medicare demonstration projects evaluated the effect of the PHE on patient behaviors among community dwelling Medicare recipients and members of a health maintenance organization who received reimbursement for the PHE, one study was a large randomized controlled trial of nearly 7,000 persons dwelling in South London who attended one of two group general practices, and one study was a study of patients seen in urban and suburban general practices in Bedfordshire, U.K. While the most notable limitations of these studies included their potentially limited generalizability to non-Medicare populations and persons living outside the U.K., as well as one study performed before USPSTF or similar contemporary guidelines, they were specifically designed to evaluate the effect of the PHE on health behaviors and therefore directly addressed Key Question 2. All behaviors were assessed via self-report in these studies, and could therefore have been subject to recall bias (Tables 2, 6 and 7).

Randomized controlled trials. In one study, performed in 1989 and funded as a Medicare demonstration project, participants in the intervention group received vouchers for free preventive visits to be delivered by participants' primary care physicians, in which the PHE was described as consisting of a history and physical examination followed by the provision of USPSTF recommended clinical preventive services. The comparison group received no coverage for annual preventive visits or tests. In this study, the PHE had mixed effects on patient behaviors. Behaviors were assessed via patient self-report at baseline and follow up. Patients receiving the PHE were statistically significantly more likely to decrease smoking when compared to those receiving usual care (small positive effect— (Cohen's d (95% CI): 0.13(0.11, 0.14)) but were less likely to improve problem drinking when compared to those receiving usual care (small negative effect— (Cohen's d (95% CI): -0.02(-0.03, -0.02)). ^56,^ ^78^ In a second study, a Medicare demonstration project published in 1993, subjects who were Medicare beneficiaries enrolled in a health maintenance organization were randomly assigned to receive a PHE in the setting of receiving selected clinical tests and immunizations, a health risk appraisal with individual counseling, and a series of health promotion sessions compared to usual care. Behaviors were assessed from patients' self reports. In this study, patients receiving the PHE demonstrated improvement in the number of fiber servings per day (small to medium positive effect— (Cohen's d (95% CI): 0.28(0.14, 0.42)), but there was no observed effect of the PHE on patients' fat servings per week, salt use, caffeine drinks per day, stretching minutes per weeks, or consumption of cruciferous foods. ^54^ In the third study, a Medicare demonstration project performed in 1993, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including a health risk assessment, a health promotion visit (including health risk appraisals, positive behavior reinforcement and referrals for interventions where appropriate), disease prevention visit (visit with nurses and physicians who conducted history and physical examinations and reviewed patients' health risks), and follow up educational classes. The comparison group received clinical preventive services as customarily offered in their physicians practices. Behaviors were assessed via patients' self reports. In this study, receipt of the PHE was associated with improvement in physical activity (small positive effect--(Cohen's d (95% CI): 0.12(0.12, 0.12)), improvement in fat and fiber dietary intake (small positive effect—(Cohen's d (95% CI): 0.04 (0.04, 0.04)), use of advanced directives (medium positive effect—(Cohen's d (95% CI): 0.34 (0.34, 0.34)), breast self-examination (small positive effect—(Cohen's d (95% CI): 0.08 (0.08, 0.08)), smoking (small positive effect—(Cohen's d (95% CI): 0.02 (0.02, 0.02)), and alcohol use (small positive effect—(Cohen's d (95% CI): 0.02 (0.02, 0.02)). This same study demonstrated the PHE was associated with a worsening in rates of seatbelt use (small negative effect—(Cohen's d (95% CI): -0.04 (-0.04, -0.04)). ^53^ The fourth study, performed in 1967, was a large randomized controlled trial of nearly 7,000 community dwelling persons in South London who attended one of two group general practices. This study was designed to assess the value of introducing a general practice based screening service (compared to usual care) for persons age 40–64 and followed patients for nine years for the incidence of co-morbid illnesses, hospitalization or mortality. The general practice based screening service was described as a visit in which patients completed a “symptoms questionnaire” and occupational history followed by a physical examination performed by nurses (primarily, supervised by a physician) and several screening tests. Behaviors were assessed via patients' self reports. In this study, receipt of the PHE was associated with worsening rates of smoking (small negative effect—(Cohen's d (95% CI): -0.014 (-0.012, -0.016)). ^76^ In the fifth study, performed in 1989 in five urban and suburban general practices in the UK, participants were randomly assigned to receive a “health check” (consisting of a comprehensive history and physical examination followed by several screening studies and post-visit health counseling) versus usual care. Behaviors were assessed via patient self-report. Patients were followed for two years after their initial intervention. In this study, the PHE was associated with improvements in smoking (small positive effect—(Cohen's d (95% CI): 0.10 (0.10, 0.10)), alcohol use (small positive effect—(Cohen's d (95% CI): 0.03 (0.03, 0.03)), exercise (small positive effect—(Cohen's d (95% CI): 0.09 (0.09, 0.09)), use of full cream (small positive effect—(Cohen's d (95% CI): 0.24 (0.24, 0.24)), and use of butter or hard margarine (small positive effect—(Cohen's d (95% CI): 0.25 (0.25, 0.25)) (Table 7, Evidence Table 8). ^59^ Limitations of these studies included inability to completely control for potential confounding and the study's potentially limited generalizability beyond Medicare populations and persons living in the UK. One study was performed before USPSTF or similar contemporary guidelines were in place as well as incomplete accounting for potential confounding of outcomes(Table 2). ^76^

Patient Attitudes

Summary of findings. One RCT assessed the effect of the PHE on patient attitudes. This single study, performed in 1993, was deemed to comprise “medium” grade evidence, based on standard criteria. This study reported an improvement in patient worry with receipt of the PHE. While this study was specifically designed to assess the effect of the PHE on this outcome, inferences may be limited beyond non-Medicare populations.

Findings

Strength and limitations of the evidence. This one RCT comprised the best available evidence to assess this outcome, which received an overall grade of “medium.” In assessing the evidence, the study was felt to have at least one serious limitation. Data on this outcome was also considered sparse (Table 6). The RCT was funded as Medicare demonstration projects evaluating the effect of the PHE on patient attitudes among Medicare recipients enrolled in a health maintenance organization who received reimbursement for the PHE (versus usual care). The most notable limitation of the RCT included potentially limited generalizability to non-Medicare populations. However, this study was specifically designed to evaluate the effect of the PHE on health behaviors and therefore directly addressed Key Question 2 (Tables 2, 6 and 7).

Randomized Controlled Trial. In this study, a Medicare demonstration project performed in 1993, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including a health risk assessment, a health promotion visit (including health risk appraisals, positive behavior reinforcement and referrals for interventions where appropriate), disease prevention visit (visit with nurses and physicians who conducted history and physical examinations and reviewed patients' health risks), and follow up educational classes. The comparison group received clinical preventive services as customarily offered in their physicians practices. ^53^ Health worry was measured as part of the administration of the Quality of Well Being Scale. This study reported smaller increases in health worry at 24 months follow up (13% increase in baseline worry score) among persons receiving the PHE compared to persons receiving usual care (23% increase in baseline worry score at follow up) (Tables 2 and 7, Evidence Table 9). Inferences from this study are potentially limited to non-Medicare populations.

Health Status

Summary of findings. Two RCTs assessed the effect of receipt of the PHE on health status. The best available evidence to assess this outcome was comprised of these two studies, funded as Medicare demonstration projects and performed in 1989 and 1993, and it was deemed to be of “high” quality based on standard criteria. These studies reported the PHE had mixed effects on health status (both measured using the Quality of Well Being Scale, one study demonstrating health status declined less among persons receiving the PHE versus persons not receiving the PHE, one study demonstrating no effect). In the study demonstrating changes positive effect of the PHE at 2 years follow up, follow up of study participants to 4 years revealed the effect of the PHE two years after the study ended was not persistent (no differences between those receiving the PHE and those who did not receive the PHE). While these studies were designed to specifically assess this outcome, they were performed among Medicare recipients, and thus may be limited in generalizability beyond this select population. In addition one study was felt not to have accounted for potential confounding.

Findings

Strength and limitations of the evidence. The best available evidence was comprised of two RCTs, performed in 1989 and 1993. This evidence received a grade of “medium,” as one study ^53^ was felt to have major limitations in quality. In addition, there was some inconsistency in the direction of results, however, there was not felt to be a high probability of reporting bias and data was felt to be adequate (Table 6). While these studies were designed to specifically assess this outcome, they were performed among Medicare recipients, and thus may be limited in generalizability beyond this select population. In addition one study was felt not to have accounted for potential confounding (Tables 2, 6 and 7). ^53^

Randomized controlled trials. One RCT of a Medicare demonstration project provided a “preventive services package” for four years to the intervention group. ^53^ The “preventive services package” consisted of an annual health-risk assessment, health-promotion visit, disease-prevention visit and follow up classes. Health status was measured using the Quality of Well Being Scale. The study reported no differences in health status similar between intervention and control at 2 years follow up (-0.01 point change for persons receiving the PHE versus a 0.00 change for persons receiving usual care; effect sizes could not be calculated).The second study, funded as a Medicare demonstration project in which participants in the intervention group received vouchers for free preventive visits to be delivered by participants' primary care physicians, the PHE was described as consisting of a history and physical examination followed by the provision of USPSTF recommended clinical preventive services. The comparison group received no coverage for annual preventive visits or tests. The study reported a small difference in the decline in health status as measured by the Quality of Well Being Scale between persons receiving the PHE (-0.0631 points over 2 years follow up) versus persons not receiving the PHE (-0.0832 points decline over 2 years follow up) (Table 7, Evidence Table 10). ^79^ However, investigators followed participants for 2 years after the study ended, to assess the persistence of the effect of the PHE. Investigators reported no differences in declines in health status between those receiving the PHE and those not receiving the PHE between 2 and 4 years after the study began. ^80^ These studies were limited by their focus on Medicare enrollees. In addition, one study did not account for potential residual confounding (Table 2). ^53^

Blood Pressure

Summary of findings. Three studies (two RCTs and one observational study) assessed the association of receipt of the PHE with changes in blood pressure. The best available evidence, comprised of two RCTs performed from 1989 to 1992, were deemed to be of “high” grade based on standard criteria. These studies reported the PHE had mixed effects on blood pressure (consistent small improvements in blood pressure outcomes demonstrated in one study and mixed results in one study). While these studies were specifically designed to assess this outcome, their results may be limited in generalizability beyond Medicare beneficiaries and patients seen in general practices in the U.K. Results from one study may also be affected by inadequate adjustment for potential confounders.

Findings

Strength and limitations of the evidence. Two RCTs comprised the best evidence to assess this outcome, which received an overall grade of “high.” When grading the evidence, the studies were found to have minor limitations in quality and some inconsistency. However, they were not felt to have sparse data or high probability of reporting bias (Table 6). One study was a study of patients seen in urban and suburban general practices in Bedfordshire, U.K. and one study was funded as a Medicare demonstration project to study community-dwelling Medicare recipients who were health maintenance organization enrollees. While these studies were designed to assess this outcome, they were potentially limited by their focus on patients receiving care in the UK and Medicare enrollees (Tables 2, 6 and 7).

Randomized Controlled Trials. In one study, a Medicare demonstration project performed in 1992, subjects who were Medicare beneficiaries enrolled in a health maintenance organization were randomly assigned to receive a PHE in the setting of receiving selected clinical tests and immunizations, a health risk appraisal with individual counseling, and a series of health promotion sessions compared to usual care. In this study, patients receiving the PHE demonstrated improvement in mean systolic blood pressure at 12 months follow up (small positive effect--Cohen's d (95% CI): 0.12(0.02, 0.21)), but there was no observed effect of the PHE on mean diastolic blood pressure at 12 months follow up (Cohen's d (95% CI): 0.03(-0.06, 0.13)). ^54^ In the second study, performed in 1989 in five urban and suburban general practices in the UK, participants were randomly assigned to receive a “health check” (consisting of a comprehensive history and physical examination followed by several screening studies and post-visit health counseling) versus usual care. Patients were followed for two years after their initial intervention. In this study, the PHE was associated with improvements in systolic blood pressure at follow up (small positive effect—(Cohen's d (95% CI): 0.11 (0.04, 0.18)), improvements in diastolic blood pressure at follow up (small positive effect—(Cohen's d (95% CI): 0.13 (0.06, 0.19)), and improvement in the proportion of persons with diastolic blood pressure ≥100mmHg (small positive effect—(Cohen's d (95% CI): 0.022 (0.019, 0.24)) (Tables 2 and 7, Evidence Table 11a). ^59^

Observational Studies. The one observational study on the association of receipt of the PHE with blood pressure was a retrospective cohort study of 240 employees of the Japan Maritime Self-Defense Force working on the Iwo Jima military defense base in December 1999. The study reported lower rates of hypertension among personnel receiving a pre-assignment medical examination (described as a medical examination followed by screening testing) one year prior to the study when compared to those not receiving a pre-assignment medical examination, but no statistically significant difference in absolute levels of blood pressure among all participants (Table 8, Evidence Table 11b). Limitations of this study included potential inability to completely control for confounding and the study's potentially limited generalizability beyond Japanese military populations (Table 2). ^77^

Serum Cholesterol

Summary of findings. Two studies (one RCT and one observational study) evaluated the association of receipt of the PHE with changes in serum cholesterol. The best available evidence comprised of one RCT performed in 1989 and one retrospective cohort study performed in 1999 was deemed to be of “low” grade based on standard criteria. The RCT reported the PHE improved serum cholesterol, while the observational study reported mixed results. While these studies were specifically designed to assess this outcome, their results may be limited in generalizability beyond patients seen in general practices in the U.K and Japanese military recruits. Results from one study may also be affected by inadequate adjustment for potential confounders.

Findings

Strength and limitations of the evidence. One RCT and one observational study comprised the best available evidence to assess this outcome, which received and overall grade of “low.” When grading the evidence, at least one of the studies was felt to have some serious limitations in quality. In addition, there was felt to be some inconsistency in the direction of results reported among the studies (Table 6). The studies were not felt to have sparse data or high probability of reporting bias, however. The RCT evaluated the effect of the PHE on cholesterol among patients seen in general practices in the U.K., while the retrospective cohort study identified differences in cholesterol among Iwo Jima military defense employees. The most notable limitations of these studies included their potential lack of generalizability beyond the populations studied (patients in the UK and Japanese military) as well as the potential inability to completely control for confounding in the observational study (Tables 2, 6 and 7).

Randomized controlled trial. In this study, performed in 1989 in five urban and suburban general practices in the UK, participants were randomly assigned to receive a “health check” (consisting of a comprehensive history and physical examination followed by several screening studies and post-visit health counseling) versus usual care. The PHE was associated with improvements in mean total cholesterol (small positive effect—(Cohen's d (95% CI): 0.22 (0.16, 0.19)) and the proportion of person with serum cholesterol ≥8mmol/L (small positive effect—(Cohen's d (95% CI): 0.09 (0.09, 0.10)) (Table 2 and 7, Evidence Table 12a). ^59^

Observational study. The one observational study on the association of receipt of the PHE with serum cholesterol was a retrospective cohort study of 240 employees of the Japan Maritime Self-Defense Force working on the Iwo Jima military defense base in December 1999. The study reported statistically significantly lower rates of hyperlipidemia among personnel receiving a pre-assignment medical examination (described as a medical examination followed by screening testing) one year prior to the study when compared to those not receiving a pre-assignment medical examination, statistically significantly greater absolute levels of total cholesterol among persons receiving the pre-assignment medical examination, and no difference in LDL cholesterol, triglycerides, or HDL among all participants (Table 8, Evidence Table 12b). Limitations of this study included potential inability to completely control for confounding and the study's potentially limited generalizability beyond Japanese military populations (Table 2). ^77^

Body Mass Index

Summary of findings. Four studies (including three randomized controlled trials and one observational study) assessed the association of receipt of the PHE with BMI. The best available evidence to assess this outcome was comprised of three RCTs, performed from 1989 to 1993, and it was deemed to be of “medium” quality based on standard criteria. These studies reported the PHE had mixed effects on BMI (small improvements in BMI for persons receiving the PHE compared to usual care in one study, less improvement in BMI for persons receiving the PHE compared to usual care in one study, and no effect in one study). While these studies were specifically designed to assess this outcome, two were performed among community-dwelling Medicare recipients, and one was performed among persons seen in a general practice in the U.K. Thus inferences may be limited to these select populations.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from three large RCTs, received an overall grade of “medium.” In grading the evidence, these studies were felt to have at least one serious limitation in quality and inconsistency in the direction of results. However, they were not felt to have sparse data or to have high probability of reporting bias (Table 6). Two studies, funded as Medicare demonstration projects, studied community dwelling Medicare recipients (in one study, participants were also health maintenance organization enrollees). The other study was performed among patients seen in general practices in the U.K. Thus, while they were specifically designed to assess this outcome, inferences could be limited to these populations. Two of the studies were felt to have potentially inadequate adjustment for residual confounding as well (Tables 2, 6 and 7).

Randomized controlled trials. Three randomized controlled trials performed from 1989 to 1993 studied Medicare recipients and patients attending one of 5 general practices in the UK (over 5000 patients combined total). ^53,^ ^54,^ ^59^ Follow up of patients ranged from two to three years. In one study, a Medicare demonstration project performed in 1993, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including a health risk assessment, a health promotion visit (including health risk appraisals, positive behavior reinforcement and referrals for interventions where appropriate), disease prevention visit (visit with nurses and physicians who conducted history and physical examinations and reviewed patients' health risks), and follow up educational classes. The comparison group received clinical preventive services as customarily offered in their physicians practices. ^53^ Limitations of this study include potential lack of generalizability of results beyond Medicare populations as well as potentially inadequate adjustment for residual confounding. This study reported persons receiving usual care had greater improvements in BMI when compared to their counterparts receiving the PHE (small negative effect--(Cohen's d (95% CI): -0.020 (-0.023, -0.017)) (Table 7, Evidence Table 13a). In the second study, a Medicare demonstration project published in 1993, subjects who were Medicare beneficiaries enrolled in a health maintenance organization were randomly assigned to receive a PHE in the setting of receiving selected clinical tests and immunizations, a health risk appraisal with individual counseling, and a series of health promotion sessions compared to usual care. In this study, the PHE had no effect on BMI at either 24 or 48 months of follow up. ^54^ Limitations of this study include potential lack of generalizability of results beyond Medicare health maintenance organization enrollees. In the third study, performed in 1989 in five urban and suburban general practices in the UK, participants were randomly assigned to receive a “health check” (consisting of a comprehensive history and physical examination followed by several screening studies and post-visit health counseling) versus usual care. Patients were followed for two years after their initial intervention. In this study, the PHE was associated with improvements in mean BMI at follow up (small positive effect—(Cohen's d (95% CI): 0.087 (0.022, 0.153)) as well as the proportion of persons with BMI≥30 at follow up (small positive effect—(Cohen's d (95% CI): 0.032 (0.030, 0.034)). ^59^ Limitations of this study include potential lack of generalizability of results beyond U.K. populations as well as potentially inadequate adjustment for residual confounding (Table 2).

Observational study. The one observational study on the association of receipt of the PHE with disease detection was a retrospective cohort study of 240 employees of the Japan Maritime Self-Defense Force working on the Iwo Jima military defense base in December 1999. The study reported no differences in mean BMI between groups but a significantly lower proportion of persons with BMI≥28.6 among personnel receiving a pre-assignment medical examination (described as a medical examination followed by screening testing) one year prior to the study when compared to those not receiving a pre-assignment medical examination (Table 8, Evidence Table 13b). Limitations of this study included potential inability to completely control for potential confounding and the study's potentially limited generalizability beyond Japanese military populations (Table 2). ^77^

### Distal Clinical and Economic Outcomes

Seven studies reported on mortality as a clinical outcome of delivery of the PHE, and nine studies reported on health care costs as an economic outcome of delivery of the PHE. Hospitalizations and disability may be considered both clinical and economic outcomes. Four studies reported on hospitalizations and three studies reported on disability as outcomes of delivery of the PHE (Table 8).

Costs

Summary of findings. Nine studies (including 5 RCTs and 4 observational studies) evaluated the association of receiving the PHE with health care costs. Cost outcomes assessed were varied and included annual physician visit costs, annual multiphasic health clinic costs, total health care charges, total Medicare charges, Medicare reimbursement, Medicare Part A charges, health care claims per capita, medical expenses per claim, inpatient cost per capita, outpatient cost per capita, and cost-effectiveness. All cost outcomes were considered as a single outcome. The best available evidence to assess this outcome was comprised of four large RCTs, one performed in the 1970's and three performed in the 1990s, and it was deemed to be “medium” grade, based on standard criteria. In these studies, the PHE had mixed effects on health care costs (decreased costs in one study, increased costs in one study, no change in costs in two studies). While the RCTs were specifically designed to assess the effect of the PHE on this outcome, three of the RCTs were focused on Medicare recipients, and thus may be limited in their generalizability to other populations. The fourth RCT was performed before USPSTF or similar contemporary preventive service guidelines were in effect. A fifth RCT (assessing cost-effectiveness) was not incorporated when grading the evidence due to inability to assess direction of results.[6883] Observational studies of the association of receipt of the PHE with health care costs revealed both positive and negative results. Observational studies had a variety of limitations, including not reporting on differences between participants and non-participants, use of claims data not created for research purposes, results not generalizable beyond particular populations studied and potential for confounding.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from four large RCTs, received an overall grade of “medium.” In grading the evidence, these studies were found to have serious limitations in quality, important inconsistency with regard to direction of effects, adequate data and a low probability of reporting bias (Table 6). Three studies evaluated the effect of the PHE on health care costs among community dwelling Medicare recipients who received reimbursement for the PHE compared to Medicare recipients receiving usual care. The fourth RCT was conducted in the Kaiser health care system in adults ages 35–54 years in the 1970s before contemporary clinical preventive guidelines were in effect. While the Medicare studies were limited in their generalizability to non-Medicare populations, and three of the studies did not report on blinding, they were specifically designed to evaluate the effect of the PHE on costs and therefore directly addressed Key Question 2 (Tables 2, 6 and 7).

Randomized controlled trials. Three randomized trials performed in 1988, 1989 and 1993 studied Medicare recipients (over 8000 patients combined total) as part of Medicare demonstration projects to determine if Medicare payment for preventive services resulted in better health and less acute care utilization. ^53,^ ^55,^ ^56^ Two Medicare studies had two-year interventions with either twelve or 24 month follow up of patients. In one study, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including a history and physical at least annually. The comparison group received clinical preventive services as customarily offered in their physicians' practices. ^55^ In this study the PHE showed no effect on cumulative Medicare charges or Medicare reimbursements for the 2-year intervention and one year following (Cohen's d (95% CI)):0.06 (-0.03, 0.15) and 0.05(-0.04, 0.14)). A second Medicare demonstration study provided vouchers for participants in the intervention group for free preventive visits to be delivered by participants' primary care physicians. ^56^ In this study both total health care charges and monthly Medicare part A charges were lower for the intervention group (effect sizes could not be calculated) (Table 7, Evidence Table 14a). A third RCT of a Medicare demonstration project provided a “preventive services package” for four years to the intervention group. ^53^ The “preventive services package” consisted of an annual health-risk assessment, health-promotion visit, disease-prevention visit and follow up classes. The study reported the intervention group had a non-statistically significant increase in costs during year 2 and year 4 of the intervention than the control group; the change in costs from baseline to follow up appeared similar between intervention and control (effect sizes could not be calculated) (Table 7, Evidence Table 14a). The fourth RCT randomized Kaiser Health Plan members ages 35–54 years in 1964 to either being encouraged to undergo an annual multiphasic health checkup or receiving usual care. ^41^ The multiphasic health checkup consisted of a series of laboratory and radiologic tests, self-administered history, and follow up physical exam by an internist. At both seven and eleven years of follow up, the intervention group had a small increase in cost for physician visits and for multiphasic health exam expenses compared to the control group (effect sizes could not be calculated) (Table 7, Evidence Table 14a). A fifth RCT conducted in England in 1989 evaluated the effectiveness of health checks delivered by nurses in primary care in reducing risk factors for cardiovascular disease and cancer and provides the only cost-effectiveness outcome in this report. ^81^ The health check consisted of medical history, physical exam, serum cholesterol and post-visit counseling. For participants who received a health check at both baseline and year 4 (intervention group) compared to participants who only received a health check at year 4 (control group), the cost per patient of a 1% reduction in coronary risk using Dundee risk scores was 1.46 British pounds. The cost effectiveness for men was 1.63 pounds and for women was 1.22 pounds. This study was not included in grading the strength and consistency of the evidence because of the inability to assess direction of the results. Limitations of these RCTs include limited generalizability to non-Medicare populations, ^53,^ ^55,^ ^56^ issues with blinding, ^41,^ ^53,^ ^56^ suboptimal adjustment for potential cofounders, ^41^ and one trial conducted before contemporary preventive service guidelines were in effect (Table 2). ^41^ Differences in costs could be attributed to differences in comorbid disease profiles or health habits between study groups in these studies as well, which was not well documented in most studies. Costs of the PHE were variably incorporated into findings regarding outcomes, limiting inferences from these studies.

Observational Studies. Observational studies evaluating the association between the receipt of the PHE and health care costs included three retrospective cohort studies and one cross-sectional study performed in 1956 to 1989 (Table 8, Evidence Tables 14b–c). Study populations for these studies included corporation executives or middle management exposed (or not exposed) to a PHE, ^28,^ ^29,^ ^61^ and a sample of Japanese adults in Osaka area 40 years and older covered by National Health Insurance who received (or did not receive) a PHE. ^82^ Three of these studies reported an association between receipt of the PHE and lower health care costs (positive outcome), ^61,^ ^82^ while one study showed association between receipt of the PHE and higher health care costs (negative outcome). ^28^ Limitations of these studies included lack of generalizability to non-management employees, ^28,^ ^29,^ ^61^ or non-Japanese populations, ^82^ suboptimal reporting of study population characteristics, ^28,^ ^61^ and comparison between participants and non-participants, ^82^ suboptimal adjustment for potential confounders, ^28,^ ^61^ and one study performed before contemporary preventive service guidelines in effect. ^61^ (Table 2) Selection bias must be considered for the employer studies where employees opted to have a physical exam or not to have a physical exam. ^28,^ ^29,^ ^61^

Disability

Summary of findings. Three studies (including two RCTs and one observational study) evaluated the association of receiving the PHE with reduction in disability. Disability outcomes assessed included self-reported limitations in usual activities, self-reported “major disability” such as problems with dressing, and short-term disability days measured from employer records. All disability outcomes were considered as a single outcome. The best available evidence to assess this outcome was comprised of two large RCTs performed in the late 1960s and 1970s, and it was deemed to be “medium” grade based on standard criteria. In these studies, the PHE had from small negative to small positive effects on reducing disability. While these RCTs were specifically designed to assess the effect of the PHE on this outcome, they were performed before the availability of the USPSTF or other contemporary preventive service guidelines and may be limited. The observational study was limited in external generalizability and raised concerns of selection bias.

Findings

Strength and limitations of the evidence. The best available evidence assessing this outcome, emanating from two large RCTs, received an overall grade of “medium.” In grading the evidence, these studies were judged to have at least one serious limitation in quality and inconsistency in the direction of their results. However, they were not found to have sparse data or a high probability of reporting bias (Table 6). One study was performed in community dwelling persons in South London, and the other was performed in Kaiser Health plan enrollees ages 35–54 years. Both studies were performed before USPSTF or other similar clinical guidelines were available. Thus, while they were specifically designed to evaluate the effect of the PHE on disability and other outcomes, inferences drawn from these studies could be limited by dated approaches to the PHE. In addition, both studies had suboptimal reporting on blinding and suboptimal adjustment for potential confounding (Tables 2, 6 and 7).

Randomized Controlled Trials. One study, performed in 1967, was a large randomized controlled trial of nearly 7,000 community dwelling persons in South London who attended one of two group general practices. This study was designed to assess the value of introducing a general practice based screening service (compared to usual care) for persons ages 40–64 and followed patients for nine years for the incidence of illness, hospitalization, disability or death. ^76^ The general practice based screening service was described as a visit in which patients completed a “symptoms” questionnaire and occupational history followed by a physical examination performed by nurses (primarily, supervised by a physician) and several screening tests. In this study, the intervention group receiving the PHE reported increased major disability (e.g., inability to dress themselves) compared to the control group (small negative effect—(Cohen's d (95%CI) -0.014(-0.016, -0.012)) (Table 7, Evidence Table 15a). The second study, performed in 1964, randomized Kaiser Health Plan members ages 35–54 years to either being encouraged to undergo an annual multiphasic health checkup or receiving usual care. ^41^ The multiphasic health checkup consisted of a series of laboratory and radiologic tests, self-administered history, and follow up physical exam by an internist. At eleven years of follow up, the intervention group had an improvement in self-reported limitations in usual activities compared to the control group (small positive effect—Cohen's d (95%CI) 0.06(0.05–0.07) (Table 7, Evidence Table 15a). Inferences from these studies are limited by their performance before contemporary preventive service guidelines were in place, suboptimal reporting on blinding and suboptimal adjustment for potential confounding (Table 2).

Observational Studies. The one observational study on the association of receipt of the PHE with disability was a retrospective cohort study of 1773 executive employees at a bank in 1989. ^29^ Executives volunteering to receive an executive PHE were compared to those who chose not to receive a PHE. The study reported lower rates of mean short-term disability days per employee, total short-term disability days in three years and proportion of employees with short-term disability days for those receiving the PHE compared to those who did not receive the PHE (Evidence table 15b). Limitations of this study included selection bias due to employees choosing whether or not to have a physical exam and limited generalizability to non-management, non-employed populations (Tables 2, 8).

Hospitalization

Summary of findings. Four studies (including three RCTs and one observational study) evaluated the association of receiving the PHE with reduction in hospitalizations. Hospitalization outcomes included hospital days per person (and per 1000) and hospital admissions per person (and per 1000). All hospital outcomes were considered as a single outcome. The best available evidence to assess this outcome was comprised of three large RCTs performed in 1967, 1988 and 1989, and it was deemed to be “high” grade. In these studies, the PHE had from small positive to mixed results on reduction in hospitalizations. While these RCTs were specifically designed to assess the effect of the PHE on this outcome, two studies were performed in Medicare recipients and may have limited generalizability outside of this population. The third study, performed in community dwelling persons in South London, was conducted before USPSTF clinical guidelines were developed.

Findings

Strength and limitations of the evidence. The best available evidence for this outcome, derived from three large RCTs, received an overall grade of “high.” In grading the evidence, the studies were judged to have minor limitations in quality, minor inconsistencies, no problems with imprecise or sparse data and not a high probability of reporting bias (Table 6). Two of the studies evaluated the effect of the PHE on hospitalizations among community dwelling Medicare recipients who received reimbursement for the PHE compared to Medicare recipients receiving usual care. Both of these have limited generalizability to non-Medicare populations. The study performed in South London is limited because it was conducted before contemporary preventive service guidelines were in effect. Two of the RCTs were limited also by suboptimal reporting of blinding (Tables 2, 6 and 7).

Randomized controlled trials. Two randomized trials performed in 1988 and 1989 studied Medicare recipients (over 6000 patients combined total) as part of Medicare demonstration projects to determine if Medicare payment for preventive services resulted in better health and less acute care utilization. ^55,^ ^56^ The Medicare studies had two-year interventions, one with twelve and one with 24 month follow up of patients. In one study, the PHE was delivered in the context of a “preventive care package” in which patients received clinical preventive services including a history and physical at least annually. The comparison group received clinical preventive services as customarily offered in their physicians' practices. ^55^ In this study the PHE showed no effect on hospital days for the 2-year intervention and one year following (Cohen's d (95% CI)):0.06 (-0.03, 0.15) and 0.05(-0.04, 0.14)). A second Medicare demonstration study provided vouchers for participants in the intervention group for free preventive visits to be delivered by participants' primary care physicians. ^56^ In this study, the PHE had mixed effects on hospitalizations. The intervention group receiving the vouchers for preventive visits had slightly higher mean inpatient days but lower hospital discharges per 1000 than the control group (effect sizes could not be calculated) (Table 7, Evidence Table 16a). The third study, performed in 1967, was a large randomized controlled trial of nearly 7,000 community dwelling persons in South London who attended one of two group general practices. This study was designed to assess the value of introducing a general practice based screening service (compared to usual care) for persons ages 40–64 and followed patients for nine years for the incidence of illness, hospitalization, disability or death. ^76^ The general practice based screening service was described as a visit in which patients completed a “symptoms” questionnaire and occupational history followed by a physical examination performed by nurses (primarily, supervised by a physician) and several screening tests. In this study, the intervention group receiving the PHE had fewer hospitalizations per 1000 person-years at risk compared to the control group (small positive effect—(Cohen's d (95%CI) 0.01 (0.00, 0.01)) (Tables 2 and 7, Evidence Table 16a). Inferences from these studies are limited by lack of generalizability to non-Medicare populations, ^55,^ ^56^ performance before contemporary preventive service guidelines were in place, ^76^ suboptimal reporting on blinding ^56,^ ^76^ and suboptimal adjustment for potential confounding (Table 2). ^76^

Observational studies. One observational study reported on the association between receipt of the PHE and hospitalizations. This cross-sectional study, performed in 1992, examined health care utilization for Japanese adults ages 40 years and older covered by the National Health Insurance Program and living in nine cities in the northern part of Osaka Prefecture. Health check-up rates were negatively correlated with both hospital admission rate per 1000 persons and a negative correlation with length of hospital stay of 180 days or more (Table 8, Evidence Table 16b). Limitations of this study include lack of generalizability outside Japan and suboptimal description of study population characteristics (Table 2). In addition, the analysis uses population-level variables (i.e., health check-up rates and hospitalization rates for the whole population) thus limiting ability to draw conclusions about any individuals.

Mortality

Summary of findings. Seven studies (including five RCTs and two observational studies) evaluated the association of receiving the PHE with mortality. The best available evidence to assess this outcome was comprised of five large RCTs performed from the 1960s to early 1990s, and it was deemed to be “medium” grade based on standard criteria. In these studies, the PHE had mixed effects on mortality. While these studies were designed to evaluate the effect of the PHE on this outcome, two were limited to the Medicare population and may not be generalizable to other groups. Three RCTs were performed in the 1960s before contemporary preventive services guidelines were developed. Observational studies limitations included generalizability to other populations, selection bias, and taking place before USPSTF guidelines were in effect.

Findings

Strength and limitations of the evidence. Five large RCTs comprised the best evidence to assess this outcome, which received an overall grade of “medium.” When grading the evidence, these studies were judged to have at least one serious limitation in quality and important inconsistency, but not imprecise data or a high probability of reporting bias (Table 6). Two studies funded as Medicare demonstration projects evaluated the effect of the PHE on mortality among community dwelling Medicare recipients, one study was a trial of nearly 7,000 persons dwelling in London who attended one of two group general practices, one study was a trial of over 10,000 Kaiser Health Plan enrollees, and one study was a trial of over 32,000 Stockholm residents. While these studies were designed to evaluate the effect of the PHE on mortality, they were limited in their generalizability to non-Medicare populations and persons living outside the U.K. or Stockholm. In addition, inferences for the three studies performed in the 1960s may be limited by dated approaches to the PHE. Other limitations of these studies include suboptimal blinding. The long follow up time of some of the studies (up to 20 years) may make it difficult to ascertain a durable effect of a PHE or series of PHEs given many years earlier (Tables 2, 6 and 7).

Randomized controlled trials. Two randomized trials performed in 1989 and 1993 studied Medicare recipients (over 6500 patients combined total) as part of Medicare demonstration projects to determine if Medicare payment for preventive services resulted in better health and less acute care utilization. ^53,^ ^56^ One Medicare demonstration study provided vouchers for participants in the intervention group for free preventive visits over two years to be delivered by participants' primary care physicians. ^56^ This study showed a reduction in overall mortality at the end of the two-year intervention period for those receiving the vouchers compared to usual care (small positive effect—(Cohen's d (95%CI) 0.06 (0.05, 0.06)) (Table 7, Evidence Table 17a). A second RCT of a Medicare demonstration project provided a “preventive services package” for four years to the intervention group. ^53^ The “preventive services package” consisted of an annual health-risk assessment, health-promotion visit, disease-prevention visit and follow up classes. The study reported the intervention group had an increase in mortality compared to controls (small negative effect—(Cohen's d -0.03 (-0.04, -0.03)) (Table 7, Evidence Table 17a). The third RCT randomized Kaiser Health Plan members ages 35–54 years in 1964 to either being encouraged to undergo an annual multiphasic health checkup or receiving usual care. ^41^ The multiphasic health checkup consisted of a series of laboratory and radiological tests, self-administered history, and follow up physical exam by an internist. At seven, eleven and 16 years of follow up, the intervention group receiving the PHE had a small decrease in mortality compared to the control group (small positive effect—Cohen's d (16 years) 0.0004 (0.0004, 0.0005) (Table 7, Evidence Table 17a). The fourth study, performed in 1967, was a large randomized controlled trial of nearly 7,000 community dwelling persons in South London who attended one of two group general practices. This study was designed to assess the value of introducing a general practice based screening service (compared to usual care) for persons ages 40–64 and followed patients for nine years for the incidence of illness, hospitalization, disability or death. ^76^ The general practice based screening service was described as a visit in which patients completed a “symptoms” questionnaire and occupational history followed by a physical examination performed by nurses (primarily, supervised by a physician) and several screening tests. In this study, the intervention group receiving the PHE had an increase in mortality per 1000 persons at risk compared to the control group (small negative effect—(Cohen's d (95%CI) -0.002 (0.000, 0.003)). The fifth RCT was conducted in Stockholm in 1969 to investigate the long-term effects of one “general health screening” on mortality. ^58^ In this large study of over 32,000 residents, 2,578 underwent the general health screening. The “general health screening” included social, psychiatric and medical interviews, blood tests, physical examinations, ECGs, exercise tests, psychological tests and eye and dental examinations. At 20 years of follow up, the relative risk of death was not significantly different in the intervention group receiving the PHE than the usual care control group (Relative Risk (95%CI) 1.03 (0.94, 1.14) (Table 7, Evidence Table 17a).

Limitations of these RCTs include limited generalizability to non-Medicare, ^53,^ ^55^ non-U.K., ^76^ and non-Stockholm ^58^ populations. Issues with blinding, ^41,^ ^53,^ ^56,^ ^58^ and suboptimal adjustment for potential confounders, ^58^ ^41,^ ^53,^ ^76^ also contributed to the limitations. Three trials were conducted before contemporary preventive service guidelines were in effect and may be limited to dated approaches to the PHE. ^41,^ ^58,^ ^76^ The long follow up time of some of the studies (up to 20 years) may make it difficult to ascertain a durable effect of a PHE or series of PHEs given many years earlier (Table 2). ^41,^ ^58,^ ^76^

Observational studies. Two observational studies reported on the association of the PHE with mortality, one concurrent cohort study and one concurrent cohort study with a historical control. The first study compared over 20,000 employed men from 1950–1964, mostly in middle management positions, receiving at least one “periodic health examination.” ^62^ The periodic health examination included a health history, “thorough” physical examination, and laboratory, x-ray and electrocardiographic studies. The actual deaths for these men receiving the PHE compared to expected deaths from white, male managerial workers nationally during 1960 was 0.56. The second study was a concurrent cohort study of Taiwanese ages 65 years and older in Kaohsiung City during the time period 1993–1998 when free annual health examinations were offered. ^83^ The health examinations included a physical exam, urine, fecal occult blood, fasting lipids and glucose, electrocardiography and chest x-ray. A randomly selected sample of 1193 elderly residents was followed from 1993–1998 to determine if receipt of this annual health examination in the past year was associated with decreased mortality. The study reported that the relative risk of mortality was 0.50 (95% CI 0.36–0.69) for those receiving the health examination compared to those who did not (Table 8, Evidence Tables 17b–c). Both of these observational studies have limitations. First, because the PHEs were voluntary, it is possible that healthier persons would seek the PHE, making selection bias important to consider. In addition, one study took place decades before the USPSTF or other contemporary clinical preventive guidelines were in effect. ^62^ The other study may not be generalizable to those under age 65 or to non-Taiwanese residents (Table 2). ^83^

### Outcomes of Interest not Reported on in Eligible Studies

No studies reported on changes in patient knowledge of clinical guidelines or health care system use as a result of the PHE. Similarly, no studies reported on ways in which the PHE could affect patients' expectations regarding their care. While eligible studies reported on patients' changes in health habits, no studies reported on whether the PHE could affect patients' motivations to change, self-efficacy, or adherence to continuous care. Few studies (but no RCTs) reported on ^59^ glucose ^77^ and hearing and vision. ^53^ Finally, no studies reported on public health outcomes such family health or communicable disease containment.

## Key Question 3: What is the Evidence that a PHE, Delivered at Different Patient Ages or Different Frequencies, Is Associated with Harms Compared to Care Without a PHE?

We identified no studies reporting on the delivery of non-recommended preventive services or the inducement of poor health outcomes as a result of the PHE. Evidence pertaining to costs induced by the PHE is discussed under Key Question 2.

## Key Question 4: What System-based Interventions Improve the Receipt or Delivery of the PHE?

Summary of findings. Five studies (one RCT, one non-randomized controlled trial, and three observational studies) assessed the effect of various interventions to enhance the PHE. The best available evidence assessing this outcome, comprised of one RCT and one non-randomized controlled trial performed from 1990 to 1992, was deemed to be of “medium” grade based on standard criteria. In these studies, offering a scheduled PHE (versus an unscheduled open invitation to a PHE) and offering a free PHE (versus a PHE at small expense) had a medium to large positive effect on the receipt of the PHE. These studies were noted to be limited by their lack of detail in describing the PHE itself as well as potentially inadequate adjustment for residual confounding.

Findings

Strength and limitations of the evidence. The best available evidence, comprised of the RCT and non-RCT, received an overall grade of “medium.” These studies were felt to have at least moderate limitations in quality, but no major inconsistency in the direction of results (Table 6).The RCT studied the effect of a scheduled invitation (versus an open invitation) on attendance at the PHE. The non-randomized controlled trial studied the effect of offering a free PHE on attendance of the PHE in two communities in Denmark. The most notable limitations of the RCT included poor classification of study withdrawals and potentially inadequate adjustment for residual confounding, while the most notable limitations of the non-randomized controlled trial included limited description of the PHE itself. However, these studies were specifically designed to evaluate the effect of interventions on receipt of the PHE and therefore directly addressed Key Question 4 (Tables 2, 6 and 7).

Randomized controlled trial. In this study, published in 1992, patients of a general practice in the U.K. received either an invitation for a scheduled health check versus an open invitation for a health check. The health check consisted of a history and physical examination performed by a nurse, followed by the generation of a personalized letter summarizing results and providing personalized advice regarding health changes. This study reported a medium to large effect positive effect of the scheduled appointments on receipt of the PHE (Cohen's d (95% CI): 0.69 (0.68, 0.70)) (Tables 2 and 7, Evidence Table 18a). ^60^

Observational studies. The non-randomized controlled trial, performed in 1990, studied the effect of offering a free PHE versus offering a PHE costing 40 Danish Krone (converts to six US dollars in 2006) in two similar communities in Denmark. This study reported a medium to large positive effect of offering a free PHE versus the PHE with minimal expense (Cohen's d (95% CI): 0.61 (0.60, 0.61)). ^84^ Three other observational studies (two cross-sectional studies and one study with pre-post design) studied adults aged 18 to 64 from the Centers for Disease Control's 1991 Behavioral Risk Factor Surveillance System to assess the association of health insurance coverage with the receipt of preventive services, ^22^ employed individuals who had health insurance (indemnity health insurance plan versus prepaid group health insurance) responding to household survey regarding their receipt of clinical preventive services in the past year, ^63^ and patients in an ambulatory family practice residency clinic in which physicians participated in a quality improvement program to enhance the delivery of the “health maintenance examination” and clinical preventive services. ^71^ In this study, patients received written materials and reminder phone calls to enhance their receipt of the PHE. ^71^ In the study of the BRFSS data, persons receiving more health plan coverage for preventive services were more likely to receive the PHE. ^22^ In contrast, the study comparing employees with indemnity health insurance plans versus prepaid group health insurance found no difference in rates of receipt of the PHE. ^63^ The observational study with pre-post design demonstrated a significant increase in receipt of the PHE after institution of written materials and reminder phone calls (Table 8, Evidence Table 18b–c).