# Methods

The ACP requested an evidence report to synthesize the available evidence on the effectiveness and/or harms of implementing the PHE. Our Evidence-based Practice Center was awarded this contract in December 2004. We established a research team and work plan to develop the evidence report. The project consisted of recruiting technical experts, formulating and refining specific research questions, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence and submitting the report for peer review.

## Recruitment of Technical Experts and Peer Reviewers

At the beginning of the project, we recruited a panel of internal and external technical experts to give us input on key steps including the selection and refinement of the questions to be examined. The panel included three internal technical experts from the Johns Hopkins University who had expertise in various aspects of the periodic health exam and eight external experts who had interests in the periodic health exam (see Appendix A ^a^ ). In addition to this panel of technical experts, we recruited a group of peer reviewers to examine a draft of the evidence report, as described further in the section on Peer Review. This group included representatives of organizations or agencies having different perspectives on the topic. We also sought input throughout the project from representatives of the ACP.

a Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/phetp.htm

## Key Questions

We worked with the ACP and technical experts from the CMS, the Agency for Healthcare Research and Quality (AHRQ), and academic and clinical centers (including practicing internists and family physicians) to develop the Key Questions contained in this report. The ACP posed an initial set of questions designed to help its internal medicine physician members gain more insight into the value of the PHE for their adult patients. After consulting with representatives of the ACP and technical experts, we expanded initial questions to incorporate an assessment of the definition of the periodic health evaluation and to identify interventions which might improve the delivery of the PHE. During this process, we developed a conceptual framework, which we used to help with refinement of the initial Key Questions, to help standardize the research team's conceptualization of the PHE, and to help guide the literature search and review.

We asked the following Key Questions concerning the value of the PHE for adults:

1 What definitions are used for the adult PHE in studies of its value?
2 What is the evidence that a PHE, delivered at different patient ages or different frequencies, is associated with benefits (i.e., improved outcomes) compared to care without a PHE (e.g., usual care or opportunistic delivery of clinical preventive services)? Outcomes include:
  a Delivery of recommended clinical preventive services.
  b Patient attitudes/perceptions (e.g., knowledge, satisfaction, trust, respect).
  c Behavioral outcomes (e.g., tobacco cessation, adherence).
  d Proximal/intermediate clinical outcomes (e.g., cholesterol lowering, disease management).
  e Distal clinical outcomes (e.g., measurable clinical events such as death, or myocardial infarction).
  f Economic outcomes (e.g., cost savings, improved health care utilization).
  g Public health (e.g., improvements in family and community health, communicable disease containment).
3 What is the evidence that a PHE, delivered at different patient ages or different frequencies, is associated with harms (i.e., worse outcomes) compared to care without a PHE (e.g., usual care or opportunistic delivery of clinical preventive services)? Outcomes include:
  a Delivery of non-recommended clinical preventive services.
  b Patient attitudes/perceptions (e.g., worry/anxiety).
  c Behavioral outcomes (e.g., continuation of risky behaviors).
  d Proximal/intermediate clinical outcomes (e.g., complications from testing).
  e Distal clinical outcomes (e.g., measurable clinical events such as death).
  f Economic outcomes (e.g., induced costs, less efficient health care utilization).
  g Public health (e.g., declines in family and community health).
4 What system-based interventions improve the receipt or delivery of the PHE (e.g., insurance premium reductions or provider reminders)?

We selected these questions as the final questions for study after assessing the feasibility of addressing these questions in the literature (including brief preliminary reviews of electronic databases for the presence of evidence to address the questions) as well as on the perceived applicability and importance of the questions to current clinical practice.

## Conceptual Framework

We developed a conceptual framework to a) help clarify how the PHE might be identified in the published literature, b) identify the potential goals of the PHE, c) place the PHE into a larger context of its perceived value in the health care system and society, and d) help refine the Key Questions studied. The conceptual framework was developed by group consensus after reviewing sentinel published opinion pieces, clinical reviews, and studies with primary data. ^1,^ ^16,^ ^19,^ ^28^ – ^34^ We worked iteratively to produce an initial conceptual framework which we reviewed with our Technical Expert Panel. We incorporated comments from our technical experts to develop a final framework (Figure 1), which guided our selection of studies for this review.

Figure 1. Conceptual Framework

In our model, we defined the goals and expectations of patients, providers and society, which provide the impetus for institution of the PHE. Performance of the PHE, which consists (at minimum) of a risk assessment, including personal and family history taking and a core physical examination, would be followed by delivery of tailored (to patients' age, gender and clinical risk factors) clinical preventive services. Same day clinical preventive services could be delivered either in the context of a more detailed physical examination (e.g., the gynecological examination/Pap smear for an appropriately aged female) or in the context of the provision of preventive counseling, immunizations or laboratory testing. We defined follow up clinical preventive services as services occurring outside of the initial visit for the PHE. However, both same-day and follow up clinical preventive services could be considered potential outcomes of receiving the PHE. The PHE could occur once or over repeated intervals of time. In addition to the receipt of clinical preventive services, we defined other potential benefits and harms of the PHE, including changes in patient attitudes (e.g., trust or worry), changes in patient behaviors (e.g., adherence or continuity with care), proximal (e.g., blood pressure control) or distal (e.g., death) clinical outcomes), resource use and costs (e.g., costs associated with hospitalizations), and outcomes related to public health in general (e.g., communicable disease containment).

To standardize the investigative team's conceptualization of the PHE, we summarized our conceptual framework using the following statement, which all investigators were encouraged to refer to when reviewing the literature at all stages of the study:

“The PHE consists of one or more visits with a health care provider for the primary purpose of assessing a patient's overall health and risk factors for disease which may be prevented by early intervention. During the PHE, health care providers typically perform a history and risk assessment, followed by a tailored physical exam. Based on the information gathered, patients may receive counseling, immunizations, lab testing or arrangements for other tailored preventive health services during the evaluation. The goal of the PHE is to improve intermediate and long-term patient outcomes and ultimately the public's health by appropriate clinical management of chronic conditions, patient education, and fostering the patient-provider relationship. The PHE has the potential to affect patient health and health care cost for the individual, the health care industry, and society as a whole.”

## Literature Search Methods

### Sources

Our comprehensive search plan included electronic and hand searching. In May 2005, we performed an initial search of the following electronic databases: MEDLINE^®^, the Cochrane database including Cochrane Reviews, Database of Abstracts of Reviews of Effects (DARE), The Cochrane Central Register of Controlled Trials (CENTRAL), The Cochrane Database of Methodology Reviews (Methodology Reviews), The Cochrane Methodology Register (Methodology Register), Health Technology Assessment Database (HTA), the National Health System Economic Evaluation Database (NHS EED), and the Cumulative Index of Nursing and Allied Health Literature (CINAHL^®^). None of the electronic search strategies were limited by year of publication. The search of electronic databases was updated to include any relevant citations published before February 2006.

Hand searching for possibly relevant citations took several forms. Our experts identified 24 journals that were thought to be most likely to contain relevant studies (see Appendix B ^a^ ). We scanned the table of contents of each issue of these journals for relevant citations from January 2005 through February 2006.

Reviewers also reviewed bibliographies of flagged articles of interest and included studies for the team to compare to the existing database. We used SRS^®^ 3.0 (TrialStat! Corporation, Ottawa, Ontario, Canada), a web-based software package developed for systematic review data management, to track the article flagging.

### Search Terms and Strategies

Search strategies, specific to each database, were designed to maximize sensitivity. Initially, we developed a core strategy for MEDLINE, accessed via PubMed^®^, based on an analysis of the Medical Subject Headings (MeSH) and text words of key articles identified a priori. ^1,^ ^7,^ ^29,^ ^32,^ ^33,^ ^35^ – ^47^ The PubMed strategy formed the basis for the strategies developed for the other electronic databases (see Appendix C ^a^ ).

### Organization and Tracking of Literature Search

The results of the searches were downloaded and imported into ProCite® version 5 (ISI ResearchSoft, Carlsbad, CA). From ProCite, the articles were uploaded to SRS 3.0. We used the duplication check feature in SRS 3.0. This feature allowed us to scan for exact article duplicates, author/title duplicates, and title duplicates. Additionally, this database was used to store citations in PDF (portable document format) and to track the search results at title review, abstract review, article inclusion/exclusion, and data abstraction levels (Figure 2).

Figure 2. Summary of literature search and review process (number of articles)

## Title Review

After the electronic databases were searched, citations were downloaded into ProCite, and uploaded to the SRS 3.0 tracking system. The study team scanned all titles. Title scans were conducted in a parallel fashion by two independent reviewers. For a title to be eliminated at this level, both reviewers had to indicate that it was ineligible. If the two reviewers did not agree on the eligibility of an article, it was automatically promoted to the next level (see Appendix D ^a^ , Title Review Form). The title review phase was designed to capture as many studies as possible reporting on the PHE. All titles related to the delivery of clinical preventive services or the PHE itself were included in the initial search and promoted to the abstract review level.

## Abstract Review

### Inclusion and Exclusion Criteria

The abstract review phase was designed to capture as many studies as possible reporting on the PHE. Investigators determined whether clinical preventive services were potentially delivered in the context of the PHE in either the intervention or control groups (for controlled studies) or in the entire study group (for non-comparative observational study designs). All articles with abstracts meeting these criteria were kept for further review. Abstracts were reviewed independently by two investigators, and were excluded if both investigators deemed the abstract to have: 1) no useful information applying to the Key Questions, 2) were not written in the English language, 3) included only subjects younger than 18 years in age, or 4) contained no original data (including reviews or opinion pieces) (see Appendix D, Abstract Review Form). Differences in opinions regarding abstract inclusion were resolved through consensus adjudication.

## Article Inclusion/Exclusion

Because of the broad array of potentially eligible articles obtained at the abstract review phase, full articles initially selected for final review underwent another independent parallel review by investigators to determine if they should be included for full data abstraction. At this phase of review, investigators determined which of the Key Questions (2–4) each article addressed (see Appendix D, Article Inclusion/Exclusion Form). For Key Questions 2 and 3, randomized controlled trials were deemed to have applicable information if they contained a group receiving the PHE compared to a group receiving usual care. Observational studies were deemed to have information applicable to assessing Key Questions 2 and 3 if they compared one group who had received the PHE to a group of persons not receiving the PHE (e.g., if persons reported receipt of a PHE in a cross-sectional survey) or if the compared persons before and after receipt of a PHE (in pre-post study designs). Studies were considered eligible if they focused on adults, and not children. All definitions of the PHE were included without regard to the targeting of adults of specific age groups. Although our uniform conceptualization of the PHE prior to the search stated health care providers “typically perform a history and risk assessment followed by a physical exam” in the PHE, we included articles even if they did not explicitly state which components of the PHE were included. Randomized controlled trials were deemed to be not applicable if they contained two groups both receiving the PHE or if they compared groups receiving different forms of the PHE (e.g., a PHE delivered by a nurse versus a physician). For Key Question 4, studies were deemed to have applicable information if they featured interventions designed to enhance patient attendance at the PHE. This could include randomized controlled trials randomizing certain practices or communities to interventions to enhance delivery of the PHE. Articles still deemed to have applicable information at this stage were included in the final article review. All articles deemed to apply to Key Questions 2–4 were used to answer Key Question one (assessing definitions of the PHE in studies). Differences in opinions regarding article inclusion or exclusion were resolved through consensus adjudication.

## Article Review

The purpose of the article review was to confirm the relevance of each article to the Key Questions, to determine methodological characteristics pertaining to study quality, and to collect evidence that addressed the Key Questions. Articles eligible for full review could address one or more of the Key Questions. If reviewers felt an article addressed more than one question, multiple data abstraction forms were used.

Two investigators reviewed each study for assessment of study quality and full data abstraction. Each reviewer independently judged study quality and rated items on standard quality assessment forms. For all data abstracted from studies, we used a sequential review process. In this process, all data abstraction forms were completed by the primary reviewer. The second reviewer confirmed the first reviewer's data abstraction forms for completeness and accuracy. Reviewer pairs were formed to include personnel with both clinical and methodological expertise. A third reviewer re-reviewed all articles that were marked as “ineligible” by the first two reviewers to ensure consistency in the classification of the articles. Reviewers were not masked to the articles' authors, institution, or journal. In most instances, data were directly abstracted from the article. If possible, relevant data were also abstracted from figures. Differences in opinion were resolved through consensus adjudication.

For each article, data abstracted included: 1) study design; 2) study location (including country of study); 3) dates the study was performed and length of follow up; 4) study setting (geographic setting as well as health care delivery structure); 5) numbers of study subjects enrolled; 6) study eligibility criteria for patients and providers; 7) descriptive characteristics of study patients (including race, gender, education, and income) and providers (including clinical specialty and practice setting); 8) components of the PHE in each study; 9) descriptive information about study interventions; and 10) study outcomes (including baseline and follow up rates of delivery of recommended preventive services, proximal clinical outcomes, distal clinical and economic outcomes as well as improvements in the delivery of the PHE) (see Appendix D, Data Abstraction Review Forms).

### Data Abstraction

All information from the article review process was entered in a relational database (Recruitment Evidence Database). The database was used to maintain and clean the data, as well as to create detailed evidence tables and summary tables (see Appendix G and Tables 1 through 9).

Data abstracted to assess the definition of the PHE (Key Question 1). Data were abstracted on the components of the PHE in each study. Components of the PHE could include: 1) the history and risk assessment of patients (including collection of a history on patients' diet, alcohol/substance abuse, injuries, sexual practices, tobacco use, calcium and folic acid intake, sun exposure, or poly-pharmacy); 2) physical examination of patients (including assessment of blood pressure, height, weight, pulse, and examination of breasts, cardiovascular system, pulmonary system, abdominal region, neurological system, gynecological or urological systems, and extremities); 3) counseling provided to patients (including counseling regarding diet, physical activity, alcohol/substance abuse, injury prevention, safe sexual practices, tobacco use, use of folic acid, sun exposure, oral health, poly-pharmacy); 4) delivery of immunizations during the PHE; and 5) delivery of clinical preventive services during the PHE (including Pap smears, gonorrhea/chlamydia screening, audiometry, vision screening, electrocardiograms, chest x-rays, mammography, sigmoidoscopy, colonoscopy, fecal occult blood tests, bone mineral density tests, serum glucose, lipids, hemoglobin A1c, blood counts, chemistries, prostate specific antigen, urinalysis, and purified protein derivative skin test (PPD) screening for tuberculosis exposure). When the PHE included other components (not listed), they were abstracted for later categorization.

Data abstracted to assess outcomes of the PHE (Key Questions 2 through 4). For studies assessing the benefits and harms associated with the PHE, data were abstracted to capture changes in the delivery (by health care providers) or receipt (by patients) of recommended clinical preventive services which were delivered as a result of the PHE, including the delivery of recommended aspects of the physical examination (e.g., blood pressure measurement, gynecological examination), counseling (e.g., substance abuse counseling), immunizations (e.g., influenza vaccination), and clinical screening tests (e.g., cholesterol testing). Data were also abstracted regarding changes in patient attitudes/perceptions as a result of the PHE (e.g., knowledge, satisfaction), changes in patient behavioral outcomes as a result of the PHE (e.g., rates of tobacco cessation), proximal/intermediate clinical outcomes (e.g., cholesterol lowering, disease detection), distal clinical outcomes (e.g., death), economic outcomes (e.g., cost, health care utilization), and public health outcomes (e.g., communicable disease containment). In studies of system-level interventions, data were abstracted on interventions associated with receipt of the PHE. For randomized controlled trials, non-randomized controlled trials, and comparative observational studies, baseline and follow up data from both intervention and control groups were abstracted for comparison. For observational studies with a pre-post design, outcomes were abstracted at baseline and follow up for the single group under observation.

## Article Quality Assessment

Two reviewers independently judged articles on several aspects of study external and internal validity, including: 1) description of inclusion and exclusion criteria for study subjects (best scores assigned for explicit reporting of criteria); 2) description of study subjects' baseline characteristics (best scores assigned for reporting of all important characteristics including age, gender, race, socioeconomic status, and comorbidities); 3) description of study non-enrollees (best scores assigned for description of differences in sociodemographic or clinical characteristics between study groups); 4) description of handling of study withdrawals (best scores assigned for use of intention to treat analyses with sensitivity analyses to examine differences between as-treated and intention-to-treat analyses); 5) description of the study intervention (best scores assigned for studies in which reviewers judged the intervention could be replicated with the completeness and detail included in the description); 6) adequacy of length of study follow up (best scores assigned when the length of follow up was appropriate for fully capturing outcomes); 7) study subject attrition (best scores assigned when the percentage of subjects remaining study was ≥85%); 8) description of study outcomes (best scores assigned for studies clearly describing outcomes so they could be understood easily); 9) relevancy and appropriateness of outcomes (best scores assigned for studies in which outcomes were deemed to be relevant and appropriate for the study as well as feasibly measured); 10) quality of outcomes assessment (best scores assigned with assessment of outcomes was both standardized and valid); 11) quality of randomization for RCTs, (best scores assigned for reporting of centralized randomization scheme and the presence of sufficient documentation regarding randomization); 12) quality of blinding for RCTs (best scores assigned for studies documenting adequate blinding of patients, providers, and outcomes assessors when appropriate); 13) comparable treatment of treatment groups for RCTs (best scores assigned for studies reporting comparable treatment of study groups with the exception of the intervention); 14) comparable characteristics of enrolled subjects for control and treatment groups for RCTs (best scores assigned when studies reported no significant difference in any characteristic likely to affect the success of the intervention or any outcome); and 15) statistical analysis. Assessments of quality of statistical analyses included assessment of : 1) study power to assess study outcomes (best scores assigned when a priori estimates of the statistical analysis were reported); 2) study investigator choice for statistical tests (best scores assigned when appropriate choice of statistical tests were made); 3) the presentation of statistical significance (best scores assigned when studies reported statistical significance in the form of confidence intervals or p-values); 4) the assessment and adjustment for potential confounding, when present (best scores assigned when multivariable analyses adequately accounted for potential confounding); and 5) potential problems with unit of analyses (best scores assigned for studies with no potential problems or for studies in which potential problems existed but were appropriately addressed). For both experimental and observational studies, we applied a total quality score, based on Chalmers et al, in which items assessing the external validity of studies received 35% of the score, items assessing the internal validity of studies received 35% of the total score, and items assessing the quality of the statistical analysis received 30% of the total score (see Appendix D, Quality Review Form). ^48^ In developing overall quality scores for individual studies, scores for each item were averaged between two reviewers. Total quality scores for each study could range from 0 (worst quality) to 100 (best quality). In the absence of universal standards for recognizing studies of high or low quality, we classified studies according to their score relative to the distribution of all other study scores, defined by tertiles of the distribution of all scores. Studies with quality scores falling within the top 33% of all study quality scores were deemed to have “high” scores, studies with quality scores falling within the middle 33% of all study quality scores were deemed to have “medium” scores, and studies with quality scores falling within the lowest 33% of all scores were deemed to have “low” scores. Because trials were judged on slightly different criteria than observational studies, trials were rated in relation to the scores of all other trials, and observational studies were rated in relation to the scores of all other observational studies.

## Data Entry and Quality Control

Initial data were abstracted by investigators and entered directly into Web-based data collection forms; SRS^®^ 3.0 (TrialStat! Corporation, Ottawa, Ontario, Canada) (Appendix D). After data were reviewed by a second author, adjudicated data were re-entered into Web-based data collection forms by trained research assistants. A standard process for data quality checks was instituted in which research assistants individually inspected all data entries. In addition, research assistants used a redundant system of random data checks to assure data quality.

## Grading of the Evidence

At the completion of our review, we graded the quantity, quality and consistency of the best available evidence addressing Key Questions 2–4 by adapting an evidence-grading scheme approach recommended by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group. ^49^ GRADE is a systematic approach to grading the strength of the total body of evidence that is available to support recommendations on a specific clinical management issue. In applying the GRADE system to the evidence, we incorporated assessments of studies' design, studies' quality, consistency of findings, and magnitude of findings.

### Process for Assigning Evidence Grades

First, we assessed study designs of the best available evidence to assess an individual outcome. We used the term “best available evidence” to indicate studies assessing the effect of the PHE on outcomes of interest in the least biased manner. We considered randomized controlled trials to represent the best study design to address Key Questions 2–4. Thus, when RCTs assessed outcomes, we considered the best available evidence assessing the outcome to be comprised of two or more RCTs. If an outcome was evaluated by at least two RCTs as well as observational studies, our evidence grade was based only on the RCTs and observational studies were ignored. If an outcome was evaluated by one or no RCTs, our evidence grade was based on the single randomized controlled trial in addition to the best available non-randomized controlled trial or the best available observational studies (cohort studies (considered best), followed by cross-sectional studies and studies with pre-post observational design (considered worst)). We reported the number of studies within the category of best available evidence to assess the quantity of evidence.

Based on the design of at least two studies comprising the best available evidence assessing specific outcomes, we designated a starting numeric value between one and four for the evidence applying to each outcome. Accordingly, we assigned a value of 4 (highest value) if the body of evidence for the outcome included two or more RCTs; a value of 3 if there was one RCT with or wihtout at least one non-randomized controlled trial, one RCT with or without at least one cohort study (prospective or retrospective), or one RCT and one pre-post study; a value of 2 if there were cohort studies only (prospective or retrospective) or if there was one controlled trial and two cross-sectional studies. All other study designs started with a value of one (lowest value). Next, we assessed the quality of the individual studies providing the evidence on specific outcomes. We used the standard assessment of individual study quality (described above and completed prior to the evidence grading process) to guide our evaluation of the overall quality of evidence assessing the outcome, including variations in studies' external validity, internal validity, and approach to statistical analysis. We evaluated the consistency of the direction of results reported in the evidence by evaluating the number and type of studies reporting the PHE had positive, negative or no effects on specific outcomes. Bodies of evidence in which results from individual studies were consistent in direction for a specific outcome received no point deduction for inconsistency. Bodies of evidence in which some studies reported results in one direction (either positive or negative) but some studies reported neutral effects of the PHE received a 0.5 point deduction for inconsistency. Bodies of evidence in which studies reported both positive and negative results received a full one point deduction for inconsistency. Finally, we evaluated the directness of evidence by considering how individual studies handled plausible confounders, and we evaluated the strength of the associations between the PHE and outcomes based on the magnitude of effect sizes indicating clinically significant differences in outcomes between groups receiving the PHE and groups not receiving the PHE.

We based the overall grade of evidence on these four key elements for each outcome, categorized as “high” grade (score of 3.0 to 4.0), 2) “medium” grade (score of 2.0 to 2.9), 3) “low” grade (score of 1.0 to 1.9), and 4) “very low” grade (score less than 1.0). A grade of “high” signifies that further research would be unlikely to alter observed effects, a grade of “medium” signifies that further research could alter the observed effects, a grade of “low” signifies that further research would be very likely to alter the observed effects in the abstracted literature, and a grade of “very low” signifies that any estimate of effect is very uncertain. In Figure 3, utilizing colon cancer as an example outcome, we have provided an example of our approach to grading the evidence for each outcome.

Figure 3. Explanation of GRADE Using Colon Cancer as an Example

## Estimating the Magnitude of Effect of the PHE on Outcomes in RCTs

In an effort to provide standard estimates of the effect of the PHE across outcomes, we calculated effect sizes (using Cohen's d Effect Size Estimate for mean differences and differences in proportions) for comparative studies evaluating the effect of the PHE on outcomes where possible. ^50,^ ^51^ We considered effect sizes ranging from 0 to 0.25 to represent “small” effects, ranging from 0.26 to 0.8 to represent “medium” sized effects, and effect sizes greater than 0.8 to represent “large” effects. ^50^ Effect sizes can be thought of as the average percentile standing of the average participant receiving the PHE relative to the average participant not receiving the PHE. An effect size of 0.0 indicates that the mean of the group receiving the PHE is at the 50th percentile of group not receiving the PHE. An effect size of 0.25 indicates that the mean of the group receiving the PHE is at the 58th percentile of the group not receiving the PHE. An effect size of 0.8 indicates that the mean of the group receiving the PHE is at the 79th percentile of the group not receiving the PHE. Thus, larger effect sizes represent greater separation of findings between treatment and control groups. ^52^ We also noted the direction of effects. We considered evidence neutral when the 95% CI of the estimate of effect included zero. When enough data were not presented in articles to present effect sizes (e.g., no information reported regarding the variance of reported means), we presented other standard estimates of effect (e.g., rate ratio) or estimated the direction and clinical significance of reported results.

## Peer Review

Throughout the project, we sought feedback from the technical experts through ad hoc and formal requests for guidance. A draft of the completed report was sent to the technical experts and peer reviewers, as well as to the representatives of the ACP and AHRQ. The range of reviewers included a representative of the sponsor of the Key Questions (ACP), academic experts in the assessment of clinical preventive services and primary care, patient stakeholder organizations (American Association of Retired Persons, American Cancer Society), private and public health insurance stakeholders (American Health Insurance Plans and CMS), and experts from the AHRQ. Substantive comments were entered into a database, and revisions to the draft report addressed reviewer comments. The disposition of all comments was submitted to the AHRQ with the final report.