# Introduction

## The Periodic Health Evaluation

The periodic health evaluation (PHE) consists of one or more visits with a health care provider for the purpose of assessing patients' overall health and risk factors for preventable diseases. The PHE is distinguished from the complete physical examination by its incorporation of tailored clinical preventive services and laboratory testing as a part of health risk assessment. During the PHE, health care providers perform a history and risk assessment in addition to a physical exam. Based on the information gathered by providers, patients may receive counseling, immunizations, lab testing, or arrangements for other preventive health services as part of the evaluation. By promoting appropriate clinical management of chronic conditions, providing patient education, and the patient-provider relationship, the PHE has been hypothesized to improve intermediate and long-term patient outcomes as well as the public's health. Because of its focus on prevention and recommendations for chronic disease management, the PHE has potential to affect patient health and health care cost for the individual, the health care industry, and society as a whole.

## Historical Changes in Conceptualization of the Content and Value of the PHE

Since the late nineteenth century, ideas regarding the content and the value of the PHE have continually evolved, reflecting changing views of the medical community and the public toward the role of prevention in health care. In 1861, Dr. Horace Dobell, considered the father of mass screening in the United Kingdom (U.K.) and a physician at the Royal Chest Hospital in England, outlined his basic belief that discovery of a pre-existent disease state could offer a chance for treatment and cure through the detailed examination of the individual. Others supported this notion such as Dr. George Gould, a prominent Philadelphia physician, who offered the “periodic examinations of patients” as an important mechanism through which future illness could be prevented and quality of life could be enhanced. ^1^

In the early 1900s, motivations for assessing and enhancing individuals' health through the PHE were often financial in nature. The life insurance industry advocated the use of medical histories and periodic physical exams to risk stratify patients for coverage decisions. Studies at the turn of the century, such as those performed by Dr. A.S. Knight of the Metropolitan Life Insurance Company and Eugene Lyman Fisk of the Life Extension Institute, both reported that policyholders undergoing an annual physical exam had lower mortality than would be expected based on actuarial data. ^1^ Similarly, private industry advocated for comprehensive laboratory and physical exams to insure the health of workers and contribute to productivity, morale, and operating efficiency of the work place. ^2^ The physical exam was also often required to attend school, enlist in the military forces, gain employment, and note the early signs of potentially serious diseases. ^3^ However, the central role of physicians in performing the physical exam prompted organized medical agencies to endorse the PHE as an opportunity to establish the physician-patient relationship. Giving his address to Harvard medical students in 1925, Dr. Francis W. Peabody emphasized this relationship by noting, “One of the essential qualities of the clinician is interest in humanity, for the secret of care of the patient is in caring for the patient.” ^4^

Despite the potential virtues of the PHE from both a financial standpoint and from the standpoint of the patient-physician relationship, the PHE was not considered standard medical care and lost momentum as a public interest during the 1930s and the Great Depression. Renewed interest in the PHE arose in the mid-1940s with the development of “multiphasic screening” whereby the PHE assumed the objective of mass screening. This approach only minimally involved physicians, and used technology for the detection of unrecognized diseases or defects. ^1^ While the medical literature at that time continued to emphasize the important role of the periodic health examination, there were few examples of studies objectively supporting the ability of the PHE to promote health and longevity. ^2^

Even with growing popularity of the PHE as standard clinical practice, the emergence of evidence-based medicine in the 1960s raised serious questions concerning the value of the PHE within the medical establishment. ^5^ During this period, several studies were conducted to assess the value of the PHE. In the U.S., Collen undertook a study at Kaiser, which followed 10,000 adults through 7 and 16 year follow ups, collecting data on morbidity and mortality. In this study, the authors concluded that periodic health examinations were associated with lower death rates from potentially postponable causes. ^6^ In the U.K., two group general practices in South London and the Department of Community Medicine at St. Thomas's Hospitals embarked on an ambitious study to assess the value of introducing a general-practice-based screening service for persons 40 to 64 year old as an extension of the National Health Service. ^7^ This study collected data on morbidity, hospital admission rates, certified sickness absence from work, and mortality - ultimately concluding little difference between the screened and unscreened groups. Costs of the screening were also calculated, and the results of this large study ultimately influenced British policy makers against investing in publicly supported multiphasic screening at that time. ^8,^ ^9^

In the 1970s, health care providers moved toward individualizing the PHE. Rather than a single annual exam during which a universal battery of screening and assessment maneuvers were undertaken, the PHE began to be conceptualized as an amalgam of preventive services tailored to individuals' risk profiles. In this manner, the annual physical exam became defined as the comprehensive physical examination which included an extensive history, physical, counseling, and diagnostic testing which was used to determine the patient's baseline health status. In contrast, the periodic health evaluation evolved into one or more visits with the primary emphasis of evaluating and offering preventive health services based the patient's age, gender and risk profile for recognizable and treatable conditions. Redefinition of the PHE in this way prompted another wave of important studies assessing the value of preventive services. Frame and Carlson in 1975 assessed the accuracy of screening measures and their impact on altering disease progression and mortality with regard to 36 major medical conditions. ^10^ In 1979 the Canadian Task Force on the Periodic Health Examination (now known as the Canadian Task Force on Preventive Health Care (CTF) looked at 78 medical conditions and also assessed the strength of evidence behind screening measures to reduce morbidity and mortality. ^11^ In 1984, the newly established U.S. Preventive Services Task Force (USPSTF) began to evaluate specific preventive interventions and their impact on morbidity and mortality in 60 medical conditions. ^12^

These efforts prompted conceptualization of the PHE as an assessment targeted only to the preventive service elements demonstrating an impact on morbidity and mortality. This minimalist approach was endorsed by the American College of Physicians (ACP) and the American Medical Association (AMA) with the caveat that the absence of evidence should not be equated with the ineffectiveness of an omitted screening intervention. These groups also advocated for increased breadth within the PHE supporting the inclusion of counseling and immunization. ^13^

## National Task Forces to Evaluate Preventive Care and the PHE

### Canadian Task Force on Preventive Care

The Canadian Task Force on Preventive Health Care (CTF), formerly known as the Canadian Task Force on the Periodic Health Examination, was established in 1976 to determine how the periodic health examination might enhance or protect the health of Canadians and to recommend a plan for a lifetime program of periodic health assessments. ^11^ During the inception of the CTF, Canadian health care costs were rising significantly as medical technology and services became increasingly available, prompting the Conference of Deputy Ministers of Health to seek a critical assessment of health care services. In 1974, the Lelonde Report released by the Canadian Ministry of National Health and Welfare called for the expansion of the federal government's role in public health, particularly in the examination of evidence for the impact of environmental factors and individual behaviors and on health status. The CTF developed a formal methodology for evaluating scientific evidence in clinical medicine and published its first report on the periodic health examination in 1979. In addition to publishing conclusions regarding 78 different clinical conditions and services, the CTF determined that the undefined “annual checkup” should be abandoned and replaced with a series of age-specific “health protection packages” implemented during the course of medical visits for other purposes. ^14^

Although the CTF recommended the elimination of the oftentimes-nebulous “annual checkup,” the practice persists in Canada. A survey of 285 Canadian primary care physicians in 1991 reported most doctors engage in preventive care during an annual general physical rather than routine patient care. ^15^ Similarly, a retrospective chart audit published in 2000 reported rates of recommended health screening tests for Canadian elderly were improved during a visit devoted to the periodic health examination when compared to visits for specific reasons where screening tests were done. ^16^

### United States Preventive Services Task Force

In 1984, the USPSTF was created under the auspices of the U.S. Public Health Service and the Department of Health and Human Services. Comprised of independent primary care experts in the field of preventive care, the USPSTF was charged with the task of impartially assessing the strength of evidence behind individual clinical preventive services. This focus on tailored individual preventive services adopted by the CTF in 1979 was a departure from previous efforts, which had concentrated on an annual exam, comprised of a universal group of services without regard to individual risks. Subsequent USPSTF Guides “evaluated the benefits of individual services based on age, gender, and risk factors for disease, made recommendations about which preventive services should be incorporated routinely into primary medical care and for which populations, and identified a research agenda for clinical preventive care.” ^12^

### Preventive Health Guidelines in Other Geographic Regions (Australia, Europe, Asia)

Australia's leading expert body on health promotion is the National Health and Medical Research Council (NHMRC) under the auspices of the Australian Government. While the NHMRC and other organizations produce clinical guidelines, Australia has no established single source for guidelines. Existing guidelines address individual health interventions and there is little mention of bundled preventive services or periodic health examinations for the general population. Australia does, however, provide expanded preventive health services for seniors age 75 and older through their Enhanced Primary Care program and for indigenous people aged 15 to 54 years through their Health Checks program both of which are based on the CTF recommendations.

The population-based evaluation of health status of the European community by history and physical exam primarily takes place in the form of the Health Interview Surveys and Health Examination Surveys. ^17^ There does not seem to be a consistent nationally supported doctrine of clinical preventive medicine among the European countries. The most consistent use of the PHE in Europe seems to be in regard to employee physicals and their utility in maintaining a healthy, productive workforce.

Examples of organized efforts to evaluate the health screening practices in Asia include Singapore's Ministry of Health Clinical Practice Guidelines. Similar to the USPTF, levels of evidence are assessed and recommendation grades are provided for various clinical conditions. These guidelines were first introduced to the public in the late 1990's and cover a wide range of topics. ^18^

## Continued Use of the PHE Despite Recommendations

Continued implementation of the PHE, despite the CTF's guidelines eliminating the “routine checkup,” may reflect the significant influence of patient and provider expectations regarding the PHE in clinical practice. According to a study assessing patients' expectations of the PHE, over 90% desired such examinations, most often on an annual basis. Accordingly, patients desired extensive examinations which included laboratory and other procedures which were in excess of CTF guideline recommendations. ^19^

In a qualitative assessments of healthcare providers' perspectives on the integration of preventive practices during clinical visits, several barriers to delivering care were identified. Barriers within the physician-patient relationship include lack of patient compliance with preventive recommendations, lack of continuity of care, and discordant expectations of patients and providers within the clinical encounter. Studies seem to suggest patients place greater reliance on diagnostic labs and tests than do providers who often use the clinical history and physical to guide their recommendations during periodic health visit. ^20,^ ^21^ Health systems barriers which providers believed affected the integration of preventive measures into the clinical visit included lack of time, remuneration, and lack of provider reminders or tools to aid in the receipt of care.

## Private Insurance Coverage for the PHE

Numerous studies have demonstrated a positive association between health insurance coverage and the receipt of preventive services. Coverage for preventive services in the U.S. by both private and public payers has gradually increased over time. However, this increase in coverage is usually for one recommended service at a time, rather than a comprehensive set of preventive services. ^22^ In one recent study of employer-sponsored insurance plans by Partnership for Prevention, roughly 80% of plans reimbursed for a general physical examination with health maintenance organizations being slightly more likely to cover this service when compared to preferred provider organizations or point of service health plans. ^23^ According to the National Health Policy Forum at George Washington University, states rarely mandate insurance coverage for preventive services based on USPSTF guidelines. However, of those preventive services which are mandated, large employer-based health plans remain exempt from such requirements through the Employee Retirement Income Security Act. Thus, there is no consistent policy regarding coverage for preventive health services, including the periodic health examination.

## Centers for Medicare and Medicaid Service (CMS) Legislation and the PHE

Under the Medicare Prescription Drug Improvement and Modernization Act (MMA) of 2003, the PHE will be covered for some individuals for the first time in Medicare's history. The Act provides Medicare reimbursement for an initial preventive visit at enrollment into Medicare, as long as the enrollee completes the examination within six months of enrollment. ^24^ The examination will cover a wide range of services, including: medical history; physical examination; counseling; laboratory tests; radiological interventions; and electrocardiograms. The Secretary of Health and Human Services has been granted permission to make some coverage decisions, but many interventions such as bone mass measurement, cancer screening and immunizations are specifically provided for in the MMA. This new legislation reflects intentions and efforts of the U.S. Department of Health and Human Services to combat rising health care costs and improve patient outcomes through the promotion of preventive measures. ^25^

## Need for Review of the Evidence on the Value of the PHE

Historical changes in the conceptualization and implementation of the PHE reflect not only the complex and multidimensional nature of the PHE but also the lack of clear evidence to support or refute its continued use. While the PHE could be seen as an explicit opportunity outside of compressed symptom-based ambulatory visits for clinicians to implement recommended clinical preventive services (particularly for preventive interventions which require more time to perform or advance planning), it is unclear whether any improvements that could be gained from the implementation of the PHE would be justified by increased costs or harms which may be associated with its implementation. At the same time, it is unclear if symptom-based visits allow adequate time for clinicians to address all age-specific recommendations for prevention or behavioral issues such as smoking and diet (which are substantial contributors to the development of many of the most costly chronic illnesses burdening patients today). ^26,^ ^27^ We therefore performed this comprehensive review of the extensive literature to elucidate the value of the PHE and ways in which the PHE could be improved. The review was intended to provide an evidence basis which patients, health care providers and health policy makers can use to guide future clinical practice.