# Appendix G: Evidence Tables

Evidence Table 1a. Delivery of Preventive Health Care Services, Pap Smear Delivered: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual.score score
| | | | | | | | | | | tertile
Morrissey, 1995 | Full Medicare reimbursement and office reminders (intervention group) | Providers and patients | 12-26 months | Delivery of Pap smear | Not self-reported | 231§ | 46% | 85% | NR | No | 87
| Control group | | | | | 224§ | 57% | 31% | | | High
Burton, 1995; German, 1995; Burton, 1997; Burton, 1995 | Received coverage for an annual preventive visit and tests (Medicare vouchers for 2 free preventive visits) | Patients | 2 years | Percentage change in use of Pap smear within last year ^80^ | Not self-reported | Baseline: 2105 | NR | NR | +16.5%^‡^ | No | 76
| | | | | | F/U: 1573 | | | | | High
| No coverage for an annual preventive visit and tests | | | | | Baseline: 2090 | | | +13.1%
| | | | | | F/U: 1524

*Physicians were unit of randomization and outcomes are reported at patient level; group 1 = patients in CART.

† Randomly selected new patient charts

‡ p<0.001.

§ Sample size includes men and women; gender breakdown not provided.

F/U = follow-up; HME = health maintenance exam; NR = not reported; CART = comprehensive annotated reminder tool.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 1b. Delivery of Preventive Health Care Services, Pap Smear Delivered: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Williams,1998 | Intervention: (touch-sensitive computer system) with HME | Patients and providers* | 12 months | Delivery of Pap smear | Not self-reported | 507 | 58.2% | 57% | -1.2% | No | 76
| Intervention: (touch-sensitive computer system) not receiving HME | | | | | 507 | 8.3% | 8.1% | -0.2% | | High
| Control (no computer system) with HME | | | | | 50 | 71.4% | 65.5% | -5.9%
| Control (no computer system)not receiving HME | | | | | 50 | 9.8% | 10.3% | 0.5%

* For control groups only.

Evidence Table 1c. Delivery of Preventive Health Care Services, Pap Smear Delivered: Cross-sectional Studies

Author, year | Description of study groups | Target of intervention | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | tertile
Somkin, 2004 | Checkup in last 12 months | Patients | Received Pap smear | Patients | 1463 | OR: 4.38; 95% CI: (2.95–6.50) | Yes* | 77
| No checkup in last 12 months | | | | | 1.0 (Reference) | | High
Finkelstein, 2002 | Receive annual health examination or preventive screening | Patients | Received Pap smear | NA | 2232 | OR: 6.69; 95% CI: (4.6–9.8) | Yes^†^ | 70
| No annual health examination or preventive screening | | | | | 1.0 (Reference) | | Med.
Hahn, 1999 | Received preventive services with HMO insurance | Patients | Received Pap smear | NA | 17032 | 97% | No | 50
| Did not receive preventive services with HMO insurance | | | | 16629 | 62% | | Low
| Received preventive services with FFS insurance | | | | 9199 | 95%
| Did not receive preventive services with FFS insurance | | | | 13425 | 47%
Tao, 2001 | Received a general medical examination | Patients | Received Pap smear | Providers | NA | 56% | No | 53
| Did not receive a general medical examination | | | | | 44% | | Low
Parchman, 2001 | Check-up in past year | Patients | Received Pap smear in the last year | Patients | Total = 1409 | 68.4% OR: 5.7; 95% CI: (4.0-8.2) | No | 55
| No check-up in past year | | | | | 27.5%OR: 1.0;95% CI:(Reference) OR: 1.0; 95% CI: (Reference) | | Low
Kottke, 1997 | Patients with visit for a health risk appraisal | Providers | Rate^‡^ Pap smears offered by providers | Patients | Total = 6830 | Mean (± SD): 0.55 (± 0.24)^§^ | | 64
| Patients with visit for urgent problem | | | | | Mean (± SD): 0.21 (± 0.26) | | Med.
| Patients with visit for continuing condition | | | | | Mean (± SD): 0.15 (± 0.25)
| Patients with visit for F/U | | | | | Mean (± SD): 0.19 (± 0.26)
| Patients with other reason for visit | | | | | Mean (± SD): 0.19 (± 0.28)
Sox, 1997 | Received a PHE | Patients | Mean proportion of patients receiving Pap smear | Patients | 2775 | Mean (± SD): 0.782 (± 0.192)^∥^ | Yes^¶^ | 63
| Usual care | | | | | Mean (SD): 0.38 (0.307) | | Med.
Slesinger, 1976 | Employees who chose prepaid group insurance plan | Patients | Receipt of Pap smear | Patients | Total N = 506, intervention; 483, control. Outcome: to women only within sample (number of women not reported) | 64 | No | 47
| Random sampling of employees who chose the traditional BC/BS plan | | | | | 63 | | Low

* Age, race, insurance, education, language, years in U.S., annual household income.

† Age, income, residence, patient has regular physician.

‡ Clinic weighted rate across 44 primary care clinics.

§ p<0.001 for this group versus all other groups combined.

∥ p<0.001.

¶ Sex, education, practice mix, provider sex, number of years with physician; number of visits per year; perceived health status.

F/U = follow-up; OR = odds ratio; CI = confidence interval; PHE = periodic health exam; NA = not applicable; HMO = health maintenance organization; FFS = fee for service; SD = standard deviation; BC/BS = Blue Cross/Blue Shield.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 1d. Delivery of Preventive Health Care Services, Pap Smear Delivered: Pre-post Studies

Author, year | Description of intervention | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Adjusted | Qual.score
| | | | | | | | | | tertile
Schneider, 2003 | Patients: written material, reminder, phone call; Providers: education on prevention measures. | Patients and providers | 2 months | Pap smear delivered | NA | Baseline: 220,* | 56.9% | 69% | N0 | 69
| | | | | | F/U: 214 | | | | Med.
Geiger, 1993 | Physicians educated about providing preventive services in the context of a “health check” | Patients | 5 months | Pap smear delivered | NA | Baseline: 24, | 16 (67%) | 35 (97%)^†^ | N0 | 72
| | | | | | F/U: 37^±^ | | | | High

* Random cross-sectional samples of patients in 1999 and 2000.

† Not statistically significant.

± Chart reviews of new patient physicals

F/U = follow-up; NA = not applicable; PHE = periodic health evaluation.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 2a. Delivery of Preventive Health Care Services, Preventive Counseling Delivered: Randomized ControlledTrial

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Belcher, 1990 | The intervention group was offered self-referral to a health promotion clinic. | Patients | 5 years | A: Counseling on alcohol abuse | Not self-reported | 400 (baseline); 260 (F/U) | A: 20% | A: 70%* | NR | Yes^‡^ | 63
| | | | B: Smoking cessation counseling | | | B: 21% | B: 71%^†^ | | | Low
| The comparison group received usual care. | | | | | 274 (baseline); 192 (F/U) | A: 25% | A: 24%
| | | | | | | B: 28% | B: 30%

* p <0.05.

† p = 0.001.

‡ Age, sex, education, practice mix, provider sex, years with physicians and number of visits per year, perceived health status.

F/U = follow-up; CART = comprehensive annotated reminder tool; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 2b. Delivery of Preventive Health Care Services, Preventive Counseling Delivered: Cross-sectional Studies

Author, year | Description of study groups | Target of intervention | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | tertile
Lin, 2004 | OPD visits involving an NP | Patients | A: Diet counseling | Not self-reported | 1929 (baseline) | A: 32.6% OR: 1.7; 95% CI: (1.2–2.5) | Yes* | 71
| | | B: Injury prevention counseling | | | B: 8.8% OR: 2.2; 95% CI: (1.3–3.5) | | High
| | | C: Physical activity counseling | | | C: 14.5% OR: 1.8; 95% CI: (1.2–2.8)
| | | D: Safe sexual practices counseling | | | D: 12.2% OR: 3.2; 95% CI: (1.6–6.3)
| | | E: Tobacco use counseling | | | E: 6.7% OR: 1.7; 95% CI: (1.2–2.5)
| OPD visits not Involving an NP | | | | 19096 (baseline) | Reference groups
| | | | | | A: 22.9%
| | | | | | B: 4.6%
| | | | | | C: 9.3%
| | | | | | D: 3.2%
| | | | | | E: 4.3%
Flocke, 2004; Eaton, 2002 | Well care | Patients | A: Patient diet advice recall ^74^ | Patients | | A, B, C: OR^†^:1 (reference) | Yes^‡^ (for out-comes A, B, C) | 76
| | | B: Patient smoking counseling recall ^74^ | | | D: 41% | No (out-come D) | High
| | | C: Physical activity patient recall ^74^ | | | E: OR: 2.35; 95% CI: (1.78–3.11) | Yes^§^ for outcome E
| | | D: Nutritional counseling— univariate analysis total n = 3475 ^98^
| | | E: Nutritional counseling—multivariate analysis total n = 3475 ^98^
| Acute care | | | | | A: OR: 0.44; 95% CI: ^†^ (0.25–0.75)
| | | | | | B: OR: 0.48; 95% CI: (0.24–0.97)
| | | | | | C: OR: 0.35; 95% CI: (0.21–0.57)
| | | | | | D: 17%
| | | | | | E: OR: 1.00 (reference group)
| Chronic care | | | | | A: OR: 0.47; 95% CI: (0.28–0.81)
| | | | | | B: OR: 0.74; 95% CI: (0.31–1.7)
| | | | | | C: OR: 0.72; 95% CI: (0.44–1.2)
| | | | | | D: 30%
| | | | | | E: OR: 1.69; 95% CI: (1.38–2.06)
| Other visit | | | | | A: OR: 0.23; 95% CI: (0.09–0.59)
| | | | | | B: OR: 0.5; 95% CI: (0.15–1.7)
| | | | | | C: OR: 0.29; 95% CI: (0.12–0.73)
| | | | | | D: NR
| | | | | | E: OR: 1.45; 95% CI: (1.03–2.02)
Tao, 2001 | Received a general medical examination | Patients | Percentage of visits in which counseling about family planning or contraception was delivered | Providers | 356,868,103 visits | % (SE) =40^∥^ | No | 53
| Did not receive a general medical examination | | | | 39,265,757 visits | % (SE) = 60% (5) | | Low
Stange, 2000 | Well visits | Patients | A: Mean % (SD) receipt of USPTF health habits counseling | Not self-reported | A and B: 442 (baseline) | A: Mean (SD): 9 (10) | No | 74
| | | B: Mean % (SD) receipt of cancer-related health habits counseling | | | B: Mean (SD): 10 (13) | | High
| Illness visits | | | | A and B: 3332 (baseline) | A: Mean (SD): 2 (5)
| | | | | | B: Mean (SD): 4 (8)
Kottke, 1997 | Patients with visit for a health risk appraisal | Providers | Clinic weighted rates at which smoking cessation counseling was offered to patients who were not up-to-date at beginning of visit | | All patients =6830 (baseline patients) | Mean (SD): 0.56 (0.26) | No | 64
| Patients with visit for urgent problem | | | | | Mean (SD): 0.40 (0.23) | | Med.
| Patients with visit for continuing condition | | | Patients | | Mean (SD): 0.50 (0.19)
| Patients with visit for F/U | | | | | Mean (SD): 0.19 (0.27 )
| Patients with other reason for visit | | | | | Mean (SD): 0.40 ( 0.18)
Sox, 1997 | Received a PHE | Patients | Recommend dietary change | Patients | Both groups = 2775 | Mean (SD): 0.604 (0.128) | Yes^¶^ | 63
| Usual care ^¶^ | | | | | Mean (SD): 0.520 (0.206) | | Med.

* Age sex, provider experience, clinic type, metropolitan status, geographic region of hospital.

† p<0.001 for checkup physical examination versus all other groups.

‡ Visit reason, visit duration, mean health status, time discussing targeted behavior.

§ Age, sex, race, diabetes, history of myocardial infarction or stroke; history of depression, length of visit; new vs. established patient; number of chronic illness; number of visits in previous year.

∥ SE not available.

¶ Age, sex, education, practice mix, provider sex, years with physician, number of visits per year, perceived health status.

F/U = follow-up; OPD = outpatient department; NP = nurse practitioner; OR = odds ratio; CI; confidence interval; SD = standard deviation; USPSTF = United States Preventive Services Task Force; SE = standard error; PHE = periodic health exam.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 2c. Delivery of Preventive Health Care Services, Preventive Counseling Delivered: Pre-post Studies

Author, year | Description of intervention | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Qual. score
| | | | | | | | | | tertile
Schneider, 2003 | Patients: written material, reminder, phone call; Providers: education on prevention measures. | Patients | 2 months | A: Exercise counseling | Not self-reported | Baseline: 321, F/U: 356^∞^ | A: 19% | A: 34.6% | A: +15.6%* | 69
| | | | B: Diet counseling | | | B: 29.9% | B: 38.3% | B: +8.4%^†^ | Med.
| | | | C: Alcohol counseling | | | C: 64.2% | C: 55.3% | C: -8.9% ^‡^
| | | | D: Substance abuse counseling | | | D: 40.9% | D: 42.4% | D: +1.5%
| | | | E: Tobacco cessation counseling | | | E: 67.9% | E: 63.2% | E: -4.7%
Geiger,1993 | Physicians educated about providing preventive services in the context of a “health check” | Patients | 5 months | A: Substance abuse counseling | Not self-reported | Baseline: 50, F/U: 53^ä^ | A: 4 (8%) | A: 51 (96%) ^§^ | | 72
| | | | B: Diet counseling | | | B: 12 (24%) | B: 52 (98%)^§^ | | High
| | | | C: Oral health counseling (dental care) | | | C: 2 (9%) | C: 12 (23%)^§^
| | | | D: Physical activity counseling | | | D: 6 (12%) | D: 50 (94%)^§^

* p = 0.001.

† p = 0.013.

‡ p = 0.012.

§ p < 0.05.

∞ Chart reviews of new patient physicals

ä Randomly selected patient charts

F/U = follow-up; Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 3a. Delivery of Preventive Health Care Services, Immunizations: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Patrick, 1999 | Medicare beneficiaries (enrolled in a HMO) randomized to preventive services package and to receive a health risk assessment for 2 years | Patients | 48 months | Influenza vaccine within last 24 months | Patients | Baseline: 1282 | 62% | 79% | 17%* | No | 62
| | | | | | F/U: 1211 | | | | | Low
| Usual care | | | | | Baseline: 1276 | 66% | 78% | 12%
| | | | | | F/U: 1234
Morrissey, 1995 | Full Medicare reimbursement and office reminders (intervention group) | Providers and patients | 12–26 months | Delivery of influenza vaccine | Not self-reported | Baseline: 231 | 48% | 72% | NR | No | 87
| | | | | | | | | | | High
| Control group | | | | | Baseline: 224 | 45% | 52%
Belcher, 1990 | The intervention group was offered self-referral to a health promotion clinic. | Patients | 5 years | Percentage receiving influenza vaccination | Not self-reported | Baseline: 400 | 16% | 56%^†^ | NR | No | 63
| | | | | | F/U: 260 | | | | | Low
| The comparison group received usual care. | | | | | Baseline: 274 | 16% | 67%^†^
| | | | | | F/U: 192

* p < 0.05 for change from baseline to follow-up.

† Rend test: z-value 2.09, p-value 0.045.

F/U = follow-up; CART = comprehensive annotated reminder tool; NR = not reported; HMO = health maintenance organization.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 3b. Delivery of Preventive Health Care Services, Immunizations: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Adjusted | Qual. score
| | | | | | | | | | tertile
Freedman, 2000 | Received a periodic health examination | Patients | 18 months | A: Received influenza vaccine | Not self-reported | 100 | NA | A: N (%) = 70 (70); | No | 75
| | | | B: Received tetanus vaccine | | | | RR (95% CI) = 1.01 (0.8–1.3) | | High
| | | | | | | | B: N (%) = 62 (62);
| | | | | | | | RR (95% CI) = 1.72 (1.1–2.7)
| Received no periodic health examination and attended clinic 3 or more times | | | | | 36 | NA | A: N (%) = 25 (69)
| | | | | | | | (reference group)
| | | | | | | | B: N (%) = 13 (36)
| | | | | | | | (reference group)

F/U = follow-up; NA = not available; RR = risk ratio; CI = confidence interval.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 3c. Delivery of Preventive Health Care Services, Immunizations: Cross-sectional Studies

Author, year | Description of study groups | Target of intervention | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | tertile
Hahn, 1999 | Received preventive services with HMO insurance | Patients | Received tetanus vaccine | Not self-reported | 17032 | 45% | No | 50
| Did not receive preventive services with HMO insurance | | | | 16629 | 36% | | Low
| Received preventive services with FFS insurance | | | | 9199 | 40%
| Did not receive preventive services with FFS insurance | | | | 13425 | 28%
Stange, 2000 | Well visits | Patients | Mean % receiving USPSTF recommended vaccinations | Not self-reported | 355 | Mean (± SD): 16% (± 32) | No | 74
| Illness visits | | | | 3006 | Mean (± SD): 2% (± 9) | | High
Kottke, 1997 | Patients with visit for a health risk appraisal | Providers | A: Rate* influenza vaccine offered by providers | Patients | 6830 | A: Mean (± SD): 0.36 (± 0.37)^†^ | No | 64
| | | B: Rate* pneumococcal vaccine offered by providers | | | B: Mean (± SD): 0.10 (± 0.17)^‡^ | | Med.
| Patients with visit for urgent problem | | | | | A: Mean (± SD): 0.24 (± 0.37)
| | | | | | B: Mean (± SD): 0.02 (± 0.09)
| Patients with visit for continuing condition | | | | | A: Mean (± SD) : 0.25 (± 0.29)
| | | | | | B: Mean (± SD): 0.03 (± 0.06)
| Patients with visit for follow-up | | | | | A: Mean (± SD) : 0.36 (± 0.33)
| | | | | | B: Mean (± SD): 0.04 (± 0.08)
| Patients with other reason for visit | | | | | A: Mean (± SD): 0.20 (± 0.31)
| | | | | | B: Mean (± SD): 0.03 (± 0.12)

* Clinic weighted rate across 44 primary care clinics.

† p = 0.17 for this group versus all other groups combined.

‡ p = 0.009 for this group versus all other groups combined.

F/U = follow-up; HMO = health maintenance organization; FFS = fee for service; USPSTF = United States Preventive Services Task Force; SD = standard deviation.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 4a. Delivery of Preventive Health Care Services, Cholesterol Screening: Randomized Controlled Trial

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. Score
| | | | | | | | | | | tertile
Morrissey, 1995 | Full Medicare reimbursement and office reminders (intervention group) | Providers and patients | 12-26 months | Cholesterol screening performed | Not self-reported | Baseline: 231 | 62% | 60% | NR | No | 87
| Control group | | | | | Baseline: 224 | 61% | 58% | | | High

F/U = follow-up; CART = comprehensive annotated reminder tool; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 4b. Delivery of Preventive Health Care Services, Cholesterol Screening: Cross-sectional Studies

Author, year | Description of study groups | Target of intervention | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Adjusted | Qual. score
| | | | | | | | | tertile
Finkelstein, 2002 | Receive annual health examination or preventive screening | Patients | Cholesterol | Not self-reported | NR | NR | OR (95% CI): 3.0 (2.0‐4.5) | Yes* | 70
| No annual health examination or preventive screening | | | | | | OR (95% CI): 1.0 (Reference) | | Med.
Hahn, 1999 | Received preventive screening with HMO insurance | Patients | Cholesterol test | NA | Baseline: 17032 | NR | 74% | No | 50
| Did not receive preventive screening with HMO insurance (acute care visit) | | | | Baseline: 16629 | | 68% | | Low
| Received preventive screening with FFS insurance | | | | Baseline: 9199 | | 68%
| Did not receive preventive screening with FFS insurance (acute care visit) | | | | Baseline: 13425 | | 59%
Parchman, 2001 | Had check-up exam in past year | Patients | Cholesterol check in last 5 years | Patient | NR | NR | 71.3% OR (95% CI): 3.7 (2.8–4.8) | No | 55
| No check-up in past year | | | | | | 40.4% (Reference) | | Low
Kottke, 1997 | Patients with visit for a health risk appraisal | Providers | Clinic weighted rates at which cholesterol testing was offered to patients who were not up-to-date at beginning of visit | Patients | NR | Mean (SD): 0.21 (0.16)^†^ | NR | No | 64
| Patients with visit for urgent problem | | | | | Mean (SD): 0.05 (0.09) | | | Med.
| Patients with visit for continuing condition | | | | | Mean (SD): 0.04 (0.06)
| Patients with visit for F/U | | | | | Mean (SD): 0.08 (0.14)
| Patients with other reason for visit | | | | | Mean (SD): 0.04 (0.07)

* Age, education, income, residence, has regular doctor.

† Compared to all others (combined) p < 0.001.

F/U = follow-up; NR = not reported; OR = odds ratio; CI = confidence interval; HMO = health maintenance organization; FFS = fee for service; SD = standard deviation.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 4c. Delivery of Preventive Health Care Services, Cholesterol Screening: Pre-post Studies

Author, year | Description of intervention | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Qual. score
| | | | | | | | | | tertile
Schnei-der, 2003 | Patients: written material, reminder, phone call; | Patients | NR | Cholesterol screening | Not self-reported | Baseline: 455 | 77.4% | 83.4% | +6.0* | 69
| Providers: education on prevention measures. | | | | | | | | | Med.
Geiger, 1993 | Physicians educated about providing preventive services in the context of a “health check” | Patients | 5 months | Total cholesterol testing | Not self-reported | Baseline: 50 | 32 (64%) | 52 (98%)^†^ | | 72
| | | | | | F/U: 53 ^ä^ | | | | High

* p = 0.068.

† p-value not significant.

ä Randomly selected patient charts

F/U = follow-up; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 5a. Delivery of Preventive Health Care Services, Colon Cancer Screening: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Morrissey, 1995 | Full Medicare reimbursement and office reminders (intervention group) | Providers and patients | 12–26 months | Fecal occult blood test delivered | Not self-reported | Baseline: 231 | 55% | 91% | NR | No | 87
| Control group | | | | | Baseline: 224 | 58% | 43% | | | High
Belcher,1990 | The intervention group was offered self-referral to a health promotion clinic. | NR | 5-year | Fecal occult blood testing performed. | Not self-reported | Baseline 400, | 24% | 70% | * | No | 63
| | | | | | F/U: 260
| The comparison group received usual care. | | | | | Baseline 274, | 21% | 20% | | | Low
| | | | | | F/U:192

*p <0.05 for change from baseline to follow-up.

F/U = follow-up; CART = comprehensive annotated reminder tool; NR = not reported; HME = health maintenance exam.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 5b. Delivery of Preventive Health Care Services, Colon Cancer Screening: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Williams, 1998 | Intervention: (touch-sensitive computer system) with HME | Patients and providers (providers: primary care study practices =unit of analysis) | 12 months | A: Flexible sigmiodoscopy | Not self-reported | NR | A: 4.8% | A: 5.3% | A: 0.5% | Yes^†^ | 76
| | | | B: Fecal occult blood test | | | B: 2.8% | B: 4.3% | B: 1.5% | | High
| Intervention: (touch-sensitive computer system) not receiving HME | | | | | | A: 4.4% | A: 6.9% | A: 2.5%
| | | | | | | B: 17% | B: 12.8% | B: -4.2%
| Control (no computer system) with HME | | | | | | A: 8.7% | A: 12.3% | A: 3.6%
| | | | | | | B: 20.3% | B: 14.7% | B: -5.6%
| Control (no computer system)not receiving HME | | | | | | A: 4.2% | A: 2.9% | A: -1.3%
| | | | | | | B: 5.5% | B: 3.1% | B: -2.4%

Evidence Table 5c. Delivery of Preventive Health Care Services, Colon Cancer Screening: Cross-sectional Studies

Author, year | Description of study groups | Target of intervention | Outcome | Outcome self-reported by patients or providers | N | F/U | Qual. score
| | | | | | | tertile
Hahn, 1999 | Received preventive services with HMO insurance | Patients | A: Sigmoidoscopy | Not self-reported | Baseline: 17032 | A: 29% | 50
| | | B. Fecal occult blood testing | | | B: 41% | Low
| Did not receive preventive services with HMO insurance (acute care visit) | | | | Baseline:16629 | A: 21%
| | | | | | B: 27%
| Received preventive services with FFS insurance | | | | Baseline: 9199 | A: 21%
| | | | | | B: 35%
| Did not receive preventive services with FFS insurance (acute care visit) | | | | Baseline: 13425 | A: 15%
| | | | | | B: 20%
Sox, 1997 | Received a PHE | Patients and providers | A: Mean proportion of persons in each practice receiving sigmoidoscopy | Yes (patients) | Baseline: both groups=2775 | A: Mean (SD): 0.158 (0.134) * | 63
| | | B: Mean proportion of persons in each practice receiving fecal occult blood testing | | | B: Mean (SD): 0.504 (0.264) ^†^ | Med.
| Usual care | | | | | A: Mean (SD): 0.126 (0.179)
| | | | | | B: Mean (SD): 0.307 (0.267)

* p = 0.04 between groups.

† p <0.001 between groups.

F/U = follow-up; HMO = health maintenance organization; FFS = fee for service; SD = standard deviation; PHE = periodic health exam.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 5d. Delivery of Preventive Health Care Services, Colon Cancer Screening: Pre-post Study

Author, year | Description of intervention | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Qual. score
| | | | | | | | | | tertile
Schneider, 2003 | Patients: written material, reminder, phone call; Providers: education on prevention measures | Patients and providers | 2 months | A: Percentage receiving fecal occult test. | Not self-reported | A: Baseline 303 | A: 40% | A: 54.2% | A: 14.2%* | 69
| | | | B: Percentage receiving sigmoidoscopy | | B: Baseline 296 | B: 30.5% | B: 39.9% | B: 9.4%^†^ | Med.
| | | | | | F/U 296

* p = 0.01.

† p = 0.06.

F/U = follow-up.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 6a. Delivery of Preventive Health Care Services, Mammogram Delivered: Randomized Controlled Trial

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. Score
| | | | | | | | | | | tertile
Morrissey, 1995 | Full Medicare reimbursement and office reminders (intervention group) | Providers and patients | 12–26 months | Delivery of mammogram | Not self-reported | 231 | 33% | 43% | NR | No | 87
| Control group | | | | | 224 | 25% | 28% | | | High

F/U = follow-up; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 6b. Delivery of Preventive Health Care Services, Mammogram Delivered: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Williams, 1998 | Intervention: (touch-sensitive computer system) with HME | Patients and providers: patients receiving HME during study year | 12 months | Delivery of mammogram | Not self-reported | Total N = 507 (random sample of 9858 patients) | 37.2% | 47.6% | 10.4%* | No | 76
| Intervention: (touch-sensitive computer system) not receiving HME | | | | | | 18.1% | 20.8% | 2.7% | | High
| Control (no computer system) with HME | | | | | | 64.1% | 44.2% | -19.9%*
| Control (no computer system)not receiving HME | | | | | | 10.8% | 11% | 0.2%

* p <0.05 (comparing baseline and follow-up).

F/U = follow-up; HME = health maintenance exam; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 6c. Delivery of Preventive Health Care Services, Mammogram Delivered: Cross-sectional Studies

Author, year | Description of study groups | Target of intervention | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. Score
| | | | | | | | tertile
Somkin, 2004 | Check-up in last 12 months | Patients | Received mammogram | Patients | 1463 | OR: 2.28; 95% CI: (1.68–3.0) | Yes* | 77
| No check-up in last 12 months | | | | | 1.0 (Reference) | | High
Tao, 2001 | Received a general medical examination | Patients | Received mammogram | Providers | NA | 45% | No | 53
| Did not receive a general medical examination | | | | | 55% | | Low
Finkelstein, 2002 | Received an annual health examination/ preventive screening | Patients | Received mammogram | Not self-reported | Total=2232 | OR: 3.89; 95% CI: (2.5–6.1) | Yes^†^ | 70
| No annual health examination/ preventive screening | | | | | 1.0 (Reference) | | Med.
Hahn, 1999 | Received preventive services with HMO insurance | Patients | Received mammogram | Not self-reported | 17032 | 87% | No | 50
| Did not receive preventive services with HMO insurance | | | | 16629 | 60% | | Low
| Received preventive services with FFS insurance | | | | 9199 | 83%
| Did not receive preventive services with FFS insurance | | | | 13425 | 46%
Parchman, 2001 | Check-up in past year | Patients | Received mammogram in past 2 years | Patients | Total=1409 | 65.2% OR: 5.8; 95% CI: (2.5–13.4) | No | 55
| No check-up in past year | | | | | 24.4% 1.0 (Reference) | | Low
Kottke, 1997 | Patients with visit for a physical examination or check-up | Providers | Rate^‡^ mammograms offered by providers | Patients | Total = 6830 | Mean (± SD): 0.38 (± 0.35) ^§^ | No | 64
| Patients with visit for urgent problem | | | | | Mean (± SD): 0.21 (± 0.30) | | Med.
| Patients with visit for continuing condition | | | | | Mean (± SD): 0.13 (± 0.17)
| Patients with visit for F/U | | | | | Mean (± SD): 0.14 (± 0.18)
| Patients with visit for other reason | | | | | Mean (± SD): 0.21 (± 0.20)
Nutting, 2001 | Had annual examination | | Mammogram recommended by physician | Providers | | OR: (A) 4.5; (B) 8.1 95% CI: (A) (3.2–6.3); (B) (3.3–20.1) | Yes^∥^ | 43
| Had chronic care visit | | | | | 1.0 (Reference) | | Low
Sox, 1997 | Received a PHE | Patients | Mean proportion of patients receiving mammogram | Patients | 2775 | Mean (± SD): 0.736 (± 0.191)^¶^ | Yes# | 63
| Usual care | | | | | Mean (± SD): 0.414 (± 0.317) | | Med.

* Age, race, insurance, education, language, years in U.S., annual household income.

† Age, income, residence, patient has regular physician.

‡ Clinic weighted rate across 44 primary care clinics.

§ p = 0.003 for this group versus all other groups combined.

∥ Model A: adjusted for physician characteristics: sex, training level, knowledge, beliefs, past experiences; Model B: adjusted for patient and physician characteristics: patient history and beliefs. physician sex, training level, knowledge, beliefs, past experiences.

# Age, sex, education, practice mix, provider's sex, number of years with physician; number of visits per year; perceived health status.

¶ p <0.001.

F/U = follow-up; OR=odds ratio; CI=confidence interval; NA = not applicable; HMO = health maintenance organization; FFS = fee for service; SD = standard deviation; PHE = periodic health exam.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 6d. Delivery of Preventive Health Care Services, Mammogram Delivered: Pre-post Studies

Author, year | Description of study Groups | Target of intervention | Length of F/U | Outcome | Outcomeself-reported by patients or providers | N | Baseline | F/U | Adjusted | Qual. score
| | | | | | | | | | tertile
Schneider, 2003 | Patients: written material, reminder, phone call; Providers: education on prevention measures | Patients and providers | 2 months | Mammogram delivered | NA | Baseline: 220* | 70.1% | 80.2%^†^ | No | 69
| | | | | | F/U: 214 | | | | Med.
Geiger, 1993 | Physicians educated about providing preventive services in the context of a “health check” | Patients | 5 months | Mammogram delivered | NR | Baseline: 15 | 7 (47%) | 23 (100%)^†^ | No | 72
| | | | | | F/U: 23 | | | | High

* Random cross-sectional samples of patients in 1999 and 2000.

† Not statistically significant.

F/U = follow-up; NA = not applicable; NR = not reported. Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 7a. Proximal Clinical Outcome, Disease Detection: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome: disease detected | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Stone, 1981; Stone, 1978; SE London, 1977; SE London, 2001; Trevelyan, 1973; Stone, 1978 | The intervention group were South London patients aged 40 to 64 years in specific group practices; received 2 multiphasic screenings 2 years apart. | Patients | 5 years after initial screening | A: Angina ^76^ | Patients (questionnaire) | 1978 | | A: 21.9% | NR | Yes* | 68
| | | | B: High diastolic blood pressure ^76^ | | | | B: 2.8% | | | Med.
| | | | C: Ischemia on electrocardiogram ^76^ | | | | C: 17.9%
| | | | D: Bronchitis symptoms ^76^ | | | | D: 29.0%
| The comparison group consisted of South London patients aged 40 to 64 years in specific group practices; received usual care. | | | | | 1950 | | A: 22.4%
| | | | | | | | B: 3.1%
| | | | | | | | C: 16.6%
| | | | | | | | D: 30.6%
Fletcher, 1977 | Multiphasic screening group | Providers | 1 year | A: Disease detection of ALL problems before and after intervention (number of new medical problems detected at F/U) | Not self-reported | 36 | A: N = 169 | A: N = 246 | NR | No | 70
| | | | B: Disease detection of important problems before and after intervention | | | B: N = 98 | B: N = 123 | | | Med.
| Medical chart abstraction group (physicians given abstracted information about patients from chart) | | | | | 40 | A: N = 144 | A: N = 158
| | | | | | | B: N = 95 | B: N = 101
| Physicians reviewed patients chart | | | | | 36 | A: N = 181 | A: N = 185
| | | | | | | B: N = 100 | B: N = 100

* Age, sex, smoking, lipids, blood pressure, diabetes, social class, general practice group.

F/U = follow-up; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 7b. Proximal Clinical Outcome, Disease Detection: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome: disease detected | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | | tertile
Hama, 2001 | Pre-assignment medical exam 1 year before assignment | Patients | 1 year | A: Cardiac arrhythmia | Not self-reported | 196 | A: 0% | Yes* | 73
| | | | B: Neurological problems | | | B: 0% | | High
| | | | C: Hyperlipidemia | | | C: 3.1%
| | | | D: GI ulcers | | | D: 0.5%
| | | | E: Hypertension | | | E: 4.1%
| | | | F: Severe obesity (BMI >28.6 kg/m^2^) | | | F: 0.5%
| | | | G: Proteinuria | | | G: 1.5%
| No pre-assignment medical exam 1 year before assignment | | | | | 44 | A: 2.3%
| | | | | | | B: 2.3%
| | | | | | | C: 15.9%^†^
| | | | | | | D: 0%
| | | | | | | E: 11.4%
| | | | | | | F: 4.5%^†^
| | | | | | | G: 0%

* Age, sex, smoking, lipids, blood pressure, diabetes, social class, general practice group.

† Odds ratio (95% confidence interval) for group C = 5.86 (1.94–17.74) and for group F = 10.99 (1.58–76.63).

F/U = follow-up; GI = gastro-intestinal; BMI = body mass index.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 8. Proximal Clinical Outcome, Change in Health Habits: Randomized Controlled Trials

Author, year | Description of study Groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Patrick, 1999 | Medicare beneficiaries (enrolled in a HMO) randomized to preventive services package and to receive a health risk assessment for 2 years | Patients | 24 months | Improvement in | Patients | Baseline: 1282 | NR | NR | A: 27%* | No | 62
| | | | A: Physical activity | | F/U:1211 | | | B: 19% | | Low
| | | | B: Diet (fat and fiber) | | | | | C: 35%^†^
| | | | C: Advance directives | | | | | D: 21%
| | | | D: Breast self-exam | | | | | E: 2%
| | | | E: Smoking | | | | | F: 6%
| | | | F: Alcohol | | | | | G: 10%
| Usual care | | | G: Seat belt use | | Baseline: 1276 | | | A: 21%
| | | | | | F/U: 1234 | | | B: 17%
| | | | | | | | | C: 18%
| | | | | | | | | D: 17%
| | | | | | | | | E: 3%
| | | | | | | | | F: 7%
| | | | | | | | | G: 12%
Elder, 1995; Mayer, 1994 | Medicare beneficiaries receiving a health promotion workshop including a health risk appraisal | NR | 48 months | A: Fiber servings per day ^54^ | Patients | Baseline: 405 | Mean (SD): | Mean (SD): | NR | No | 75
| | | | B: Fat servings per week ^54^ | | F/U: 405 | A: 5.89 (0.98) | A: 6.01 (1.00) | | | Med.
| | | | C: Salt use ^54^ | | | B: 2.76 (0.99) | B: 2.63 (0.89)
| | | | D: Caffeine drinks per day ^54^ | | | C: 2.88 (0.92) | C: 2.85 (0.92)
| | | | E: Stretching minutes per week ^54^ | | | D: 2.16 (0.79) | D: 2.09 (0.71)
| | | | F: Consumption of cruciferous foods ^54^ | | | E: 14.98 (22.75) | E: 20.3 (27.43) ^†^
| | | | | | | F: 1.89 (0.64) | F: 1.93 (0.65)
| Usual care | | | | | Baseline: 393 | A: 5.75 (0.92) | A: 5.87 (0.94)
| | | | | | F/U: 393 | B: 2.77 (0.99) | B: 2.65 (0.87)
| | | | | | | C: 2.88 (0.96) | C: 2.87 (0.93)
| | | | | | | D: 2.23 (0.78) | D: 2.21 (0.74)
| | | | | | | E: 19.23 (27.00) | E: 17.9 (25.01)
| | | | | | | F: 1.8 (0.62) | F: 1.85 (0.62)
Burton, 1995; German, 1995; Burton, 1997; Burton, 1995 | Received coverage for an annual preventive visit and tests (Medicare vouchers for 2 free preventive visits) | Patients | 2 years | A: Smoking ^78^ | Patients | Baseline (of 1573): | | | A: -24.2% | No | 76
| | | | B: Problem alcohol drinking ^78^ | | A: 241 | | | B: -57% | | High
| | | | | | B: 79
| No coverage for an annual preventive visit and tests | | | | | Baseline (of 1524): | | | A: -17.9%
| | | | | | A: 252 | | | B:-67.1%
| | | | | | B: 85
Stone, 1981; Stone, 1978; Southeast London, 1977; Trevelyan, 1973; Southeast London, 2001 | The intervention group were South London patients aged 40 to 64 years in specific group practices; received 2 multiphasic screenings 2 years apart. | Patients | 5 years | Percentage still smoking ^7^ | Patients | Baseline: 1651 | NR | 51.5 | NR | No | 68
| | | | | | | | | | | Med.
| The comparison group consisted of South London patients aged 40 to 64 years in specific group practices; received usual care. | | | | | Baseline: 1950 | | 50.8
OX-CHECK, 1995; Langham, 1996 | Intervention group: Health check at baseline | Patients | 3 years | A: Smoking ^59^ | NR | Baseline: 2205 | NR | A: 356 (21.4) | A: Diff (95% CI)* 5.0 (2.2–7.8) | NR | 65
| | | | B: Alcohol use ^59^ | | F/U: 1660 | | B: 156 (9.4) | B: 1.6 (-0.42–0.04) | | High
| | | | C: Exercise less than once per month ^59^ | | | | C: 1094 (66.5) | C: 4.5 (1.4–7.5)
| | | | D: Use full cream milk ^59^ | | | | D: 300 (18.5) | D: 12.1 (9.4–26.0)
| | | | E: Use butter or hard margarine ^59^ | | | | E: 303 (18.3) | E: 12.4 (9.6–15.2)
| Control group: No health check at baseline | | | | | Baseline: 2783 | | A: 506 (26.4)
| | | | | | F/U: 1916 | | B: 210 (11.0)
| | | | | | | | C: 1354 (70.9)
| | | | | | | | D: 587 (30.6)
| | | | | | | | E: 587 (30.7)

* p = 0.020.

† p = 0.000.

‡ p = 0.0002.

F/U = follow-up; HMO = health maintenance organization; NR = not reported; SD = standard deviation; NR = not reported; CI = confidence interval.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

** Data does not contribute to findings reported in summary tables but displayed here for completeness.

Evidence Table 9. Proximal Clinical Outcome, Patient Attitudes: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Patrick, 1999 | Medicare beneficiaries (enrolled in a HMO) randomized to preventive services package and to receive a health risk assessment for 2 years | Patients | 24 months | Mean score health worry* | Patients | Baseline: 1282 | 3.09 | 3.51 | 0.42^†^ | NR | 62
| | | | | | F/U: 1089 | | | | | Low
| Usual care | | | | | Baseline: 1276 | 2.94 | 3.63 | 0.69
| | | | | | F/U: 1144

* Larger values indicate worse health.

† p = 0.047.

F/U = follow-up; HMO = health maintenance organization; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 10. Proximal Clinical Outcomes, Health Status: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Patrick, 1999 | Medicare beneficiaries (enrolled in a HMO) randomized to preventive services package for 2 years | Patients | 24 months | Change in health status (on Quality of Well-Being Scale) ^53^ | Patients | Baseline: 1134 | 0.71 | 0.70 | -0.01‡ | No | 62
| | | | | | F/U: 1134 (excluded deaths) | | | | | Low
| Usual Care | | | | | Baseline: 1176 | 0.70 | 0.70 | 0.00
| | | | | | F/U: 1176 (excluded deaths)
Burton, 1995; German, 1995; Burton, 1997; Burton, 1995 | Received coverage for an annual preventive visit and tests (Medicare vouchers for 2 free preventive visits) | Patients | A: baseline to 2 years | Change in health status (on Quality of Well Being Scale) of intervention and control groups from baseline to 2 years ^79^ or from 2 to 4 years after intervention ^80^ | Patients | Baseline: 1748 | NR | NR | A: -0.0631† | No | 76
| | | B: 2 years to 4 years | | | | | | B: -0.091‡ | | High
| No coverage for an annual preventive visit and tests | | | | | Baseline: 1755 | | | A: -0.0832
| | | | | | | | | B: -0.084

* Difference from control at follow-up.

F/U = follow-up; NR = not reported

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

† p=0.0109

‡ not statistically significant

Evidence Table 11a. Proximal Clinical Outcome, Blood Pressure: Randomized Controlled Trials

Author, year | Description of study Groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Elder, 1995; Mayer, 1994 | Medicare beneficiaries receiving a health promotion workshop including a health risk appraisal | NR | 48 months | A: Mean systolic blood pressure at 12 months ^54^ | Patients | Baseline: 899 | Mean (SD) | Mean (SD) | NR | No | 75
| | | | B: Mean diastolic blood pressure at 12 months ^54^ | | | A: 139.21 (18.79) | A: 135.5 (16.12) | | | Med
| | | | | | | B: 75.06 (10.46) | B: 71.05 (9.21)
| Usual care | | | | | Baseline: 901 | Mean (SD) | Mean (SD)
| | | | | | | A: 140.00 (18.32) | A: 137.44 (16.94)
| | | | | | | B: 74.56 (9.85) | B: 71.36 (9.49)
OX-CHECK, 1995; Lang-ham, 1996 | Intervention group: Health check at baseline | Patients | 3 years | A: Systolic blood pressure at 3-year follow up ^59^ | NR | Baseline:2205 | Mean (SD) | Mean (SD) | Mean (SD) | NR | 65
| | | | B: Diastolic blood pressure at 3-year follow up ^59^ | | F/U: 1660 | A: 126.5 (19.3) | A: 126.8 (19.6) | A: 2.2* CI (0.9,3.5) | | High
| | | | C: Proportion of high risk diastolic pressure (≥100mm Hg) from 3 year F/U when compared to control ^59^ | | | B: 75.7 (11.6) | B:75.7 (11.5) | B: 1.5* CI (0.7,2.3);
| | | | | | | C: 3.3% | C: 3.4% | C: 1.2%* CI (-0.1,2.5)
| Control group: No health check at baseline | | | | | F/U: 1916 | NR | Mean (SD) | NR
| | | | | | | | A: 129 (20.4)
| | | | | | | | B: 77.2 (11.7)
| | | | | | | | C: 4.5%

* Difference from control at follow-up

F/U = follow-up; NR = not reported; CI = confidence interval (95%); SD = standard deviation

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 11b. Proximal Clinical Outcome, Blood Pressure: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome: disease detected | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | | tertile
Hama, 2001 | Pre-assignment medical exam 1 year before assignment | Patients | 1 year | A: Mean systolic blood pressure | Not self-reported | 196 | Mean(SD) | Yes* | 73
| | | | B: Mean diastolic blood pressure | | | A: 122 (13.6)† | | High
| | | | C: Proportion of hypertension | | | B: 74.9 (11.7)‡
| | | | | | | C: 4.1%
| No pre-assignment medical exam 1 year before assignment | | | | | 44 | Mean(SD)
| | | | | | | A: 122.2 (12.9)
| | | | | | | B: 76.3 (10.6)
| | | | | | | C: 11.4%

* Age, sex, smoking, lipids, blood pressure, diabetes, social class, general practice group.

F/U = follow-up; SD = standard deviation

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

† p=0.914 for comparison between pre-assignment group and group not receiving pre-assignment

‡ p=0.468 for comparison between pre-assignment group and group not receiving pre-assignment

Evidence Table 12a. Proximal Clinical Outcome, Changes in Serum Cholesterol: Randomized Controlled Trial

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
OX-CHECK, 1995; Lang-ham, 1996 | Intervention group: Health check at baseline | Patients | 36 months | A: Mean total cholesterol at 3-year F/U ^59^ | NR | Baseline: 2205; F/U: 1660 | Mean (SD) | Mean (SD) | A: 0.25* CI (0.18, 0.33)) | NR | 65
| | | | B: Proportion of high risk cholesterol (≥8mmol/l) at 3 year F/U ^59^ | | | A: 5.99 (1.10) | A: 5.93 (1.06) | B: 4.7%* CI (3.2,6.2) | | High
| | | | | | | B: 3.9% | B: 3.1%
| Control group: No health check at baseline | | | | | F/U: 1916 | NR | Mean (SD) | NR
| | | | | | | | A: 6.18 (1.17)
| | | | | | | | B: 7.8%

* Difference from control at follow-up.

F/U = follow-up; NR = not reported; CI = confidence interval; SD = standard deviation

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 12b. Proximal Clinical Outcome, Changes in Serum Cholesterol: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome: disease detected | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | | tertile
Hama, 2001 | Pre-assignment medical exam 1 year before assignment | Patients | 1 year | A: Mean total cholesterol | Not self-reported | A-D:94 | Mean(SD) | Yes* | 73
| | | | B: Mean LDL cholesterol | | E: 196 | A: 204.9 (31.1)† | | High
| | | | C: Mean triglycerides | | | B: 117.6 (33.4)‡
| | | | D: Mean HDL cholesterol | | | C:144.9 (120)§
| | | | E: Proportion of hyperlipidemia | | | D: 58.2 (15.1)ε
| | | | | | | E: 3.1%¥
| No pre-assignment medical exam 1 year before assignment | | | | | A-D: 21 | Mean(SD)
| | | | | | E: 44 | A: 187.8 (51.0)
| | | | | | | B: 117.1 (36.7)
| | | | | | | C: 124.7 (63.0)
| | | | | | | D: 57.3 (16.4)
| | | | | | | E: 15.9%

* Age, sex, smoking, lipids, blood pressure, diabetes, social class, general practice group.

† 0.028 for comparison of those receiving pre-assignment medical examination versus those not receiving pre-assignment medical examination

‡ 0.944 for comparison of those receiving pre-assignment medical examination versus those not receiving pre-assignment medical examination

§ 0.416 for comparison of those receiving pre-assignment medical examination versus those not receiving pre-assignment medical examination

ε 0.799 for comparison of those receiving pre-assignment medical examination versus those not receiving pre-assignment medical examination

¥ <0.05 for comparison of those receiving pre-assignment medical examination versus those not receiving pre-assignment medical examination

F/U = follow-up; LDL = low-density lipoprotein; HDL = high-density lipoprotein; SD = standard deviation

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 13a. Proximal Clinical Outcomes, Body Mass Index: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Patrick, 1999 | Medicare beneficiaries (enrolled in a HMO) randomized to preventive services package and to receive a health risk assessment for 2 years | Patients | 48 months | A: At risk for obesity, 24-month F/U | Patients | Baseline: 1282; F/U:1211 | | | A: -3% | No | 62
| Usual care | | | | | Baseline: 1276; F/U: 1234 | | | A: -4% | | Low
Elder, 1995; Mayer, 1994 | Medicare beneficiaries receiving a health promotion workshop including a health risk appraisal | NR | 48 months | A: Mean BMI at 24 months (end of intervention period) ^54^ | Patients | Baseline, 405** | Mean (SD) 26.15 (3.96) | Mean (SD) | NR | No | 75
| | | | B: Mean BMI at 48 months (end of F/U) ^54^ | | | | A: 25.92 (3.93) | | | Med.
| | | | | | | | B: 26.21 (4.33)
| Usual care | | | | | Baseline, 393** | Mean (SD) 25.72 (3.81) | Mean (SD)
| | | | | | | | A: 25.8 (3.82)
| | | | | | | | B: 26.06 (4.08)
OX-CHECK, 1995; Lan-gham, 1996 | Intervention group: Health check at baseline | Patients | 36 months | A: Mean BMI at 3-year F/U ^59^ | NR | Baseline: 2205; F/U: 1660 | Mean (SD) | Mean (SD) | A: 0.37* CI (0.9,0.65) | NR | 65
| | | | B: Percentage of participants with BMI ≥ 30 ^59^ | | | A: 25.88 (4.21) | A: 25.89 (4.14) | B: 2.4%* CI (0.0,4.7) | | High
| | | | | | | B: 13.5% | B: 14.3%
| Control group: No health check at baseline | | | | | F/U: 1916 | NR | Mean (SD) | NR
| | | | | | | | A: 26.26 (4.31)
| | | | | | | | B: 15.9%

* Difference from control at follow-up

** Sample completing 4-year follow-up

F/U = follow-up; BMI = body mass index; NR = not reported; HMO = health maintenance organization; CI = confidence interval; SD = standard deviation

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 13b. Proximal Clinical Outcomes, Body Mass Index: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome: disease detected | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | | tertile
Hama, 2001 | Pre-assignment medical exam 1 year before assignment | Patients | 1 year | A: Mean BMI; | Not self-reported | 196 | Mean(SD) | Yes* | 73
| | | | B: Proportion of severe obesity (BMI ≥ 28.6) | | | A: 23.8† (3.0) | | High
| | | | | | | B: 0.5%‡
| No pre-assignment medical exam 1 year before assignment | | | | | 44 | Mean(SD)
| | | | | | | A: 24.8 (4.6)
| | | | | | | B: 4.5%

* Age, sex, smoking, lipids, blood pressure, diabetes, social class, general practice group.

F/U = follow-up; BMI = body mass index; SD = standard deviation.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

† p=0.068 for persons receiving pre-assignment examination versus those not receiving pre-assignment examination

‡ p<0.05 for persons receiving pre-assignment examination versus those not receiving pre-assignment examination

Evidence Table 14a. Economic Outcomes, Costs: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Cutler, 1973; Collen, 1973; Dales, 1973; Ramcharan, 1973; Fried-man, 1986; Dales, 1979; Norinder, 2002 | Intervention group: California Kaiser Health Plan members aged 35–54 years encouraged to have multiphasic checkup | Patients | 11 years | A: Average annual cost for physician visit per participant at 7 years (men, aged 45–54 years at baseline) ^47^ | Not self-reported | Sub-sample of larger study- | NR | A: $32 | NR | No | 56
| | | | B: Average annual cost for physician visit per participant at 11 years (men, aged 45–54 years at baseline) ^94^ | | A and C: 1229 | | B: $43 | | | Low
| | | | C: Average annual expense per participant in multiphasic health checkup expense at 7 years. (men, aged 45–54 years at baseline) ^47^ | | | | C: $36
| | | | D: Average annual expense per participant in multiphasic health checkup expense at 11 years. (men, aged 45–54 years at baseline) ^94^ | | | | D: $59
| California Kaiser Health Plan members aged 35–54 years received usual care | | | | | A and C: 1364 | | A: $28
| | | | | | | | B: $41
| | | | | | | | C: $10
| | | | | | | | D: $23
Burton, 1995; German, 1995; Burton, 1997; Burton, 1995 | Received coverage for an annual preventive visit and tests (Medicare vouchers for 2 free preventive visits) | NR | 2 to 4 years (intervention duration = 2 years) | A: Total health care charges, Year 1 ^56^ | Not self-reported | A,C: 2105 | NR | A: $8,826,078 | NR | Yes* | 76
| | | | B: Total health care charges, Year 2 ^56^ | | B,D: 2020 | | B: $10,735,142 | | | High
| | | | C: Mean monthly Medicare Part A charges, Year 1 ^56^ | | E: 2105 (baseline), 1573 (F/U) | | C: $205
| | | | D. Mean monthly Medicare Part A, charges Year 2 ^56^ | | F: 1573 (baseline),1382 (F/U) | | D: $264
| | | | E. Mean monthly Medicare Part A charges Year 3 (1 year post-intervention) ^56^ | | | | E: $242
| | | | F. Mean monthly Medicare Part A charges Year 4 (2 years post-intervention) ^56^ | | | | F: $281
| No coverage for an annual preventive visit and tests | | | | | A,C: 2090) | | A: $8,991,063
| | | | | | B,D: 1971 | | B: $11,014,199
| | | | | | E: 2090 (baseline),1524 (F/U) | | C: $216
| | | | | | F: 1524 (baseline),1380 (F/U) | | D: $274
| | | | | | | | E: $267
| | | | | | | | F: $298
Morrissey, 1995 | Full Medicare reimbursement and office reminders (intervention group) | Physicians and patients | 2- year intervention, follow-up to one year post intervention | A: 3-year post-intervention cumulative Medicare charges. | Not self-reported | A: 954 | NR | A: $8,937♦ (S.D. 17,009) | NR | No | 87
| | | | B: 3-year post-intervention cumulative Medicare reimbursement | | B: 954 | | B: $4,607^§^ (S.D. 8463) | | | High
| Control group | | | (2 years of intervention and one year following) | | A: 960 | | A: $10,143 (SD 21,143)
| | | | | | B: 960 | | B: $5110 (SD 10024)
Patrick, 1999 | Medicare beneficiaries (enrolled in a HMO) randomized to preventive services package and to receive a health risk assessment for 2 years | | 48 months | Average total cost per participant | NR | 1282 | Year prior to intervention: $3595^†^ | 24 months: ^∥^ $3564 | NR | No | 62
| | | | | | | | 48 months: ^∥^ $3998^‡^ | | | Low
| Usual care | | | | | 1276 | Year prior to intervention: $3414 | 24 months: $3300
| | | | | | | | 48 months: $4010
OX-CHECK, 1995; Langham, 1996 | Intervention group: Health check at baseline | Patients | 36 months (intervention group) | Cost effectiveness: cost per 1% reduction in coronary risk using Dundee risk scores | NR | Baseline 2205: F/U: 1660 | | Men: 1.63 | NR | No | 65
| | | | | | | | Women: 1.22 | | | High
| | | | | | | | All: 1.46
| Control group: No health check at baseline | | | | | 1916

* Time.

† p = 0.392.

‡ p = 0.320.

§ These costs do not include $294 per patient cost of the preventive services delivered as the intervention.

∥ These costs do not include $186 per patient cost of the preventive services delivered as the intervention.

F/U = follow-up; NR = not reported; SD = standard deviation.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 14b. Economic Outcomes, Costs: Retrospective Cohort Studies

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | | tertile
Burton, 2002 | Exposed group: executives eligible for and receiving the periodic health examination | Patients | 3 years | Average cost in medical claims paid per employee | Not self-reported | 1046 | $5361* | Yes^†^ | 55
| Unexposed group: executives eligible for but not participating in the periodic health examination | | | | | 727 | $6426* | | Low
Bernacki, 1988 | Exposed group: corporation executives eligible for PPE and receiving 3 PPEs during 3-year study period | Patients | 3 years | Health care claims cost per capita in Year 3 | Not self-reported | 315 | $1039 | No | 48
| Exposed group: corporation executives eligible for PPE and receiving 1 or 2 PPEs during 3-year study period | | | | | 314 | $588 | | Low
| Unexposed group: corporation executives eligible for PPE and not receiving a PPE during the 3-year study period | | | | | 81 | $452
Grimaldi, 1965 | Exposed group: corporation middle management employees opting to participate in PPE | Patients | 8 years | Mean medical expense per claim | NR | 74 | $292.03^μ^ | No | 37
| Unexposed group: corporation middle management employees opting not to participate in PPE | | | | | 26 | $529.58 | | Low
| Unexposed group: employees from another site not offered the PPE | | | | | 94 | $393.75

* p = 0.0263.

† Age, sex.

μ t=3.147 for comparison with unexposed corporation middle manager group

F/U = follow-up; PPE = periodic physical examination; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 14c. Economic Outcomes, Costs: Cross-sectional Studies

Author, year | Description of study groups | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | tertile
Nakanishi, 1996 | Japanese adults aged 40 years and older in National Health Insurance program | Receipt of health checkup(s) in 1992; outcomes measured in May 1993 | A: Inpatient cost per insured person (yen) correlated with rate of use of health check-ups | | 227,581 | A: CC = -0.724* | Yes^†^ | 72
| | | B: High inpatient cost (600,000 yen or more) correlated with rate of use of health check-ups | | | B: CC = -0.625^‡^ | | High
| | | C: Outpatient cost per insured person correlated with rate of use of health check-ups | | | C: CC = -0.454^§^

* p = 0.014.

† Age, sex.

‡ p = 0.036.

§ p = 0.110.

F/U = follow-up; CC = correlation coefficient.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 15a. Distal Economic Outcomes, Disability: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. Score
| | | | | | | | | | | tertile
Stone, 1981; Southeast London, 1977; Southeast London, 2001; Stone, 1978a; Stone, 1978b; Trevelyan, 1973 | The intervention group were South London patients aged 40 to 64 years in specific group practices; received 2 multiphasic screenings 2 years apart. | Patients | 5 years | Major disability (e.g., inability to dress or undress themselves) ^7^ | Patients | 1978 | NR | 2.5%* | NA | Yes^†^ | 68
| The comparison group consisted of South London patients aged 40 to 64 years in specific group practices; received usual care. | | | | | 1950 | | 1.8%* | | | Med.
Cutler, 1973; Collen, 1973; Dales, 1973; Ramcharan, 1973; Friedman, 1986; Dales, 1979; Norinder, 2002 | Intervention group: California Kaiser Health Plan members aged 35–54 encouraged to have multiphasic checkup | Patients | 7–11 years | A: Disability at 7 years ^95^ | Patients | A: baseline= 871, 7-year F/U = 793 | A: 95, 10.9% | A: 168, 21.1% | B: Health risk factors | NR | 56
| | | | B: Disability at 11 years among men aged 45–54 ^96^ | | B: 677 | | B: 158, 23.3%^‡^ | | | Low
| Control group: California Kaiser Health Plan members aged 35–54 received usual care | | | | | A: baseline= 941, 7-year F/U = 829 | A: 137, 14.6% | A: 204, 24.6%
| | | | | | B: 738 | | B: 219, 29.7%^‡^

* Authors reported there were no statistically significant differences, but formal significance testing was not reported.

† Age, smoking, lipids, blood pressure, diabetes, social class, general practice group.

‡ p <0.01, chi square test.

F/U = follow-up; NR = not reported NA = not applicable; NR = not recorded.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 15b. Distal Economic Outcomes, Disability: Retrospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. Score
| | | | | | | | | | | tertile
Burton, 2002 | Exposed group: executives eligible for and receiving the periodic health examination | Patients | 3 years | A: Average number of short-term disability days per employee | Not self-reported | 1046 | NA | A: 2.78 days absent* | NA | Yes^‡^ | 55
| | | | B: Total short-term disability days in 3 years | | | | B: 2134* | | | Low
| | | | C: Any short-term disability days (%) | | | | C: 6.2%^†^
| Unexposed group: executives eligible for but not participating in the periodic health examination | | | | | 727 | | A: 4.02 days absent* | NR | No
| | | | | | | | B: 2707*
| | | | | | | | C: 11.0%^§^

* Study terminology; PHE = periodic health examination.

* p <0.01, chi square test.

† p <0.001.

‡ Age, sex.

§ Authors reported there were no statistically significant differences, but formal significance testing was not reported.

F/U = follow-up; NA = not applicable; NR = not recorded.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 16a. Distal Clinical Outcomes, Hospitalization: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. Score
| | | | | | | | | | | tertile
Morrissey, 1995 | Full Medicare reimbursement and office reminders (intervention group) | Providers and patients | 12–36 months | A: Utilization data: hospital days per enrollee over two years of intervention and one year post-intervention | Not self-reported | 954 (baseline) | NR | A: Mean (SD): | NR | No | 87
| | | | B: Admissions per enrollee over two years of intervention and one year post-intervention | | | | B: 0.73 (1.43) | | | High
| Contl group | | | | | 960 (baseline) | | A: Mean
| | | | | | | | (SD): 8.55 (26.25)
| | | | | | | | B: 0.79 (1.50)
Burton, 1995; German, 1995; Burton, 1997; Burton, 1995 | Received coverage for an annual preventive visit and tests (Medicare vouchers for 2 free preventive visits) | Patients | 2 years | A: Mean inpatient days for the intervention and control groups who had a hospital discharge in that year (Year 1) ^56^ | Not self-reported | A: 2105 (baseline) | NR | A: 15.7 days | NR | No | 76
| | | | B: Mean inpatient days Year 256 | | B: 2020 (baseline) | | B: 17.6 days | | | High
| | | | C: Hospital discharges per 1000 Year 1 ^56^ | | | | C: 345.6
| | | | D: Hospital discharges per 1000 Year 2 ^56^ | | | | D: 378.0
| No coverage for an annual preventive visit and tests | | | | | A: 2090 (baseline) | | A: 14.7 days
| | | | | | B: 1971 (baseline) | | B: 16.8 days
| | | | | | | | C: 355.2
| | | | | | | | D: 404.4
Stone, 1981; South-east London, 1977;Southeast London, 2001;Stone, 1978a; Stone,1978b; Trevelyan, 1973 | The intervention group were South London patients aged 40 to 64 years in specific group practices; received 2 multiphasic screenings 2 years apart. | Patients | 9 years | Hospitalizations/ 1000 person years at risk (1976) ^7^ | Patients | Baseline: 3876, | NR | 73.4 | NR | No | 68
| | | | | | F/U: 3292 | | | | | Med.
| The comparison group consisted of South London patients aged 40 to 64 years in specific group practices; received usual care. | | | | | Baseline: 3353, | | 70.7
| | | | | | F/U: 3132

F/U = follow-up; NR = not reported; SD = standard deviation.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 16b. Distal Clinical Outcomes, Hospitalization: Cross-sectional Study

Author, year | Description of study groups | Target of intervention | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. Score
| | | | | | | | tertile
Nakanishi, 1996 | Japanese adults aged 40 years and older in National Health Insurance program | Patients | A: Hospital admission rate per 1000 insured persons correlation with rate of use of health checkups | Not self-reported | 227,581 | A: CC = -0.890* | Yes^†^ | 72
| | | B: Length of stay of 180 days or more per 1000 insured persons correlated with rate of use of health checkups | | | B: CC = -0.584^‡^ | | High

* p = 0.001.

† Age, sex.

‡ p = 0.049.

F/U = follow-up; CC = correlation coefficient.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 17a. Distal Clinical Outcome, Mortality: Randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. Score
| | | | | | | | | | | tertile
Patrick, 1999 | Medicare beneficiaries (enrolled in a HMO) randomized to preventive services package and to receive a health risk assessment for 2 years | Patients | 4 years | A: Mortality at 24 months | Not self-reported | 1282: 854 aged under 75 years, 428 aged 75 years or older | NR | A: 5.5%; 3.3% under 75; 10.0% aged 75 or older* | NR | No | 62
| | | | B: 48 months | | | | B: 9.8%;6.3% under 75; 18.6% aged 75 or older ^†^ | | | Low
| Usual care | | | | | 1276: 839 aged under 75 years, 437 aged 75 years or older | | A: 3.3 %; 2.4% aged under 75; 5.0% aged 75 or older
| | | | | | | | B: 8.2%; 5.6% aged under 75; 13.5% aged 75 or older
Burton, 1995; German, 1995; Burton, 1997; Burton, 1995 | Received coverage for an annual preventive visit and tests (Medicare vouchers for 2 free preventive visits) | Patients | 2 years | Mortality ^79^ | Not self-reported | 2105 | NR | 175 (8.3%)^‡^ | NR | N | 76
| No coverage for an annual preventive visit and tests | | | | | 2090 | | 231 (11.1%)
Stone, 1981; South-east London, 1977; South-east London, 2001; Stone, 1978a; Stone, 1978b; Trevelyan, 1973 | The intervention group were South London patients aged 40 to 64 years in specific group practices; received 2 multiphasic screenings 2 years apart. | Patients | 9 years | Mortality rate per 1000 person-years at risk: | Not self-reported | 3292 18,404.3 person-years | NR | A: 10.0∥ | NR | Yes^§^ | 68
| | | | A. All cause death ^7^ | | | | B: 2.5∥ | | | Med.
| | | | B: Neoplasm ^7^ | | | | C: 0.9∥
| | | | C. Central nervous system ^7^ | | | | D: 4.3∥
| | | | D. Cardiovascular disease ^7^ | | | | E: 1.4∥
| | | | E: Respiratory disease ^7^ | | | | F: 0.9∥
| | | | F: All other causes ^7^
| The comparison group consisted of South London patients aged 40 to 64 years in specific group practices; received usual care. | | | | | 3132 19,972.3 person-years | | A: 9.2
| | | | | | | | B: 2.6
| | | | | | | | C: 0.7
| | | | | | | | D: 2.8
| | | | | | | | E: 2.9
| | | | | | | | F: 1.1
Cutler, 1973; Collen, 1973; Dales, 1973; Ramcharan, 1973; Friedman, 1986; Dales, 1979; Norinder, 2002 | Intervention group: California Kaiser Health Plan members aged 35–54 encouraged to have multiphasic checkup | Patients | 16 years | Deaths, rate per 1000 persons | Not self-reported | 7-year F/U: | NR | 7-year F/U: | NR | N | 56
| | | | A: All cause deaths ^9,^ ^94,^ ^96^ | | A: 5146 | | A: 183, 35.6 | | | Low
| | | | B: Death from potentially postponable causes ^9,^ ^94,^ ^96^ | | B: 5146 | | B: 19, 3.7#
| | | | C: Death from colorectal cancer ^9,^ ^94,^ ^96^ | | C: 5146 | | C: 2, 0.4#
| | | | D: Death from breast cancer (women only) ^9,^ ^94,^ ^96^ | | D: 2718 | | D: 4, 1.4
| | | | E: Death from cervical/uterine cancer (women only) ^9,^ ^94,^ ^96^ | | E: 2718 | | E: 1, 0.4
| | | | F: Death from prostate cancer (men only) ^9,^ ^94,^ ^96^ | | F: 2360 | | F: 0, 0.0
| | | | G: Death from hypertension-associated causes ^9,^ ^94,^ ^96^ | | G: 5146 | | G: 8, 1.6
| | | | H: Death from ischemic heart disease ^9,^ ^94,^ ^96^ | | H: 5146 | | H: 49, 9.5
| | | | I: Death from respiratory system disease ^9,^ ^94,^ ^96^ | | I: 5146 | | I: 7, 1.4
| | | | J: Death from musculoskeletal disease ^9,^ ^94,^ ^96^ | | J: 5146 | | J: 3, 0.6
| | | | K: Death from mental, nervous, or sensory organ disease ^9,^ ^94,^ ^96^ | | K: 5146 | | K: 1, 0.2**
| | | | L: Death from endocrine, nutritional, and metabolic disease ^9,^ ^94,^ ^96^ | | L: 5146 | | L: 3, 0.6
| | | | M. Death from suicide ^9,^ ^94,^ ^96^ | | M: NR | | M: NR
| | | | N: Death from lymphohematopoetic cancer ^9,^ ^94,^ ^96^ | | N: 5138 | | N: 8, 1.6#
| | | | | | 11-year F/U: | | 11-year F/U:
| | | | | | A: 5138 | | A: 353, 68.7
| | | | | | B: 5138 | | B: 44, 8.6#
| | | | | | C: 5138 | | C: 5, 3.3#
| | | | | | D: 2791 | | D: 14, 5.0
| | | | | | E: 2791 | | E: 1, 0.4
| | | | | | F: 2347 | | F: 0, 0.0
| | | | | | G: 5138 | | G: 13, 2.5
| | | | | | H: 5138 | | H: 92, 17.9
| | | | | | I: 5138 | | I: 10, 2.0
| | | | | | J: 5138 | | J: 4, 0.8
| | | | | | K: 5138 | | K: 3, 0.6
| | | | | | L: 5138 | | L: 5, 1.0
| | | | | | M: 5138 | | M: 18, 3.5#
| | | | | | N: 5138 | | N: 15, 2.9#
| | | | | | 16-year F/U: | | 16-year F/U:
| | | | | | A: 5138 | | A: 585, 113.9^‡‡^
| | | | | | B: 5138 | | B: 77, 15.0^††^
| | | | | | C: 55 | | C: 12, 2.3#
| | | | | | D: 2791 | | D: 21, 4.1
| | | | | | E: 2791 | | E: 5, 1.0
| | | | | | F: 2347 | | F: 1, 0.2
| | | | | | G: 5138 | | G: 24, 4.7
| | | | | | H: 5138 | | H: 155, 30.2
| | | | | | I: 5138 | | I: 19, 3.9
| | | | | | J: 5138 | | J: 4, 0.8
| | | | | | K: 5138 | | K: 7, 1.6
| | | | | | L: 5138 | | L: 9, 1.9
| | | | | | M: 5138 | | M: 25, 4.9#
| | | | | | N: 5138 | | N: 22, 4.3#
| Control group: California Kaiser Health Plan members aged 35–54 received usual care | | | | | 7-year F/U: | | 7-year F/U:
| | | | | | A: 5540 | | A: 217, 39.2
| | | | | | B: 5540 | | B: 41, 7.4#
| | | | | | C: 5540 | | C: 10, 1.8#
| | | | | | D: 2908 | | D: 9, 3.1
| | | | | | E: 2908 | | E: 2, 0.7
| | | | | | F: 2631 | | F: 1, 0.4
| | | | | | G: 5540 | | G: 16, 2.9
| | | | | | H: 5540 | | H: 46, 8.3
| | | | | | I: 5540 | | I: 11, 2.0
| | | | | | J: 5540 | | J: 3, 0.5
| | | | | | K: 5540 | | K: 2, 0.4**
| | | | | | L: 5540 | | L: 3, 0.5
| | | | | | M: NR | | M:NR
| | | | | | N: 5540 | | N: 3, 0.5#
| | | | | | 11-year F/U: | | 11-year F/U:
| | | | | | A: 5536 | | A: 393
| | | | | | B: 5536 | | B: 73, 13.2#
| | | | | | C: 5536 | | C: 18, 3.3#
| | | | | | D: 2914 | | D: 14, 4.8
| | | | | | E: 2914 | | E: 4, 1.4
| | | | | | F: 2622 | | F: 2, 0.8
| | | | | | G: 5536 | | G: 26, 4.7
| | | | | | H: 5536 | | H: 98, 17.7
| | | | | | I: 5536 | | I: 18, 3.3
| | | | | | J: 5536 | | J: 3, 0.5
| | | | | | K: 5536 | | K: 5, 0.9
| | | | | | L: 5536 | | L: 5, 0.9
| | | | | | M: 5536 | | M: 7, 1.3#
| | | | | | N: 5536 | | N:5, 0.9#
| | | | | | 16 -year F/U: | | 16- year F/U:
| | | | | | A: 5536 | | A: 643, 116.1^‡‡^
| | | | | | B: 5536 | | B: 119, 21.5^††^
| | | | | | C: 5536 | | C: 29, 5.2#
| | | | | | D: 2914 | | D: 24, 4.3
| | | | | | E: 2914 | | E: 5, 0.9
| | | | | | F: 2622 | | F: 5, 0.9
| | | | | | G: 5536 | | G: 40, 7.2
| | | | | | H: 5536 | | H: 151, 27.3
| | | | | | I: 5536 | | I: 30, 5.4
| | | | | | J: 5536 | | J: 4, 0.7
| | | | | | K: 5536 | | K: 9, 1.6
| | | | | | L: 5536 | | L: 9, 1.6
| | | | | | M: 5536 | | M: 11, 2.0#
| | | | | | N: 5536 | | N: 10, 1.8#
Theobald, 1998 | Intervention group: Stockholm residents aged 18‐65 offered a general health examination | NR | 22 years | A: All cause mortality | Not self-reported | A: 3064 | NR | A: RR 1.03, 95% CI (0.94–1.14) | NR | Yes*** | 63
| | | | B: Cardiovascular disease mortality | | B: 3064 | | B: OR 1.06, 95% CI (0.91–1.23) | | | Low
| | | | C: Cancer mortality | | C: 3064 | | C: OR 1.06, 95% CI (0.88–1.23)
| | | | D: Accidents and intoxication mortality | | D: 3064 | | D: OR 0.97, 95% CI (0.73–1.30)
| Control group: Stockholm residents aged 18–65 received usual care | | | | | | | Reference group

* Overall, p = 0.006; <75 years old, p = 0.267; ≥75 years old, p = 0.005.

† Overall, p = 0.062; <75 years old, p = 0.528; ≥75 years old, p = 0.05.

‡ p = 0.003.

§ Age, sex, smoking, lipids, blood pressure, diabetes, social class, general practice office.

∥ Authors reported there were no statistically significant differences, but formal significance testing was not reported.

¶ Colon/rectum, breast, cervix/uterine, prostate, and kidney cancer, hypertension, hypertensive cardiovascular disease, hemorrhagic cerebrovascular disease.

# p < 0.05, chi-square.

** 7-year follow-up includes nervous system and sensory organs only.

†† p=0.012.

‡‡ p=0.710.

*** Age, sex, need for service.

F/U = follow-up; NR = not reported; RR = risk ratio; OR = odds ratio; CI = confidence interval.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 17b. Distal Clinical Outcome, Mortality: Prospective Cohort Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. score
| | | | | | | | | tertile
Chiou, 2002 | Exposed group: Taiwanese adults aged 65 years and older reporting receiving a physical examination in past year | Patients | 6 years | Relative risk of mortality | Not self-reported | 1193 in exposed and un-exposed groups combined | RR 0.50, 95% CI (0.36–0.69) for those receiving check-up in past year | Yes* | 59
| Unexposed group: Taiwanese adults aged 65 and older not receiving physical examination in past year | | | | | | Reference group | No | Med.

* Age, sex, race, education, comorbities, living arrangements.

F/U = follow-up; RR = relative risk; CI = confidence interval.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 17c. Distal Clinical Outcome, Mortality: Prospective Cohort Study with Historical Control

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | F/U | Adjusted | Qual. Score
| | | | | | | | | tertile
Robert, 1969 | Exposed group: U.S. employed men receiving employer-sponsored periodic health examination | Patients | 15 years | Actual/expected deaths | Not self-reported | 20,648 | 0.56 | Yes* | 38
| Unexposed group: historical comparison of U.S. white men | | | | | NA | Reference group | No | Low

* Age, race, sex.

F/U = follow-up; NA = not applicable.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 18a. Receipt of the Periodic Health Exam: Non-randomized Controlled Trials

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Change | Adjusted | Qual. score
| | | | | | | | | | | tertile
Christensen, 1995 | Intervention group: Denmark patients of general practitioners received mailing that a preventive health examination was free | Patient | Not specified | Attendance at PHE | No | 1259 | NR | 829 (66%)* | NR | No | 77
| Control group: Denmark patients of general practitioners received mailing that a preventive health examination was 40 Danish Krone | | | | | 1193 | | 443 (37%) | | | High

* p <0.05

F/U = follow-up; PHE = periodic health evaluation; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 18a-1. Receipt of the Periodic Health Exam: Randomized Controlled Trials. (continued)

Author, year | Description of intervention | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | F/U | Qual. score
| | | | | | | | tertile
Norman, 1992 | Patients who received an invitation letter with an appointment to health check | Patients | NR | Attendance at PHE (%) | Patients | 399 | 69.7^†^ | 68
| Patients who received an open invitation letter to health check | | | | | 419 | 37.1 | Med.

† p <0.05.

F/U = follow-up; SD = standard deviation.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 18b. Receipt of the Periodic Health Exam: Cross-sectional Studies

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | Adjusted | Qual. score
| | | | | | | | | tertile
Faulkner, 1997 | Behavioral Risk Factor Surveillance Survey 1991: All preventive services covered by health plan | NA | NA | Odds of receiving checkup according to level of health insurance compared to no health insurance coverage | | Total = 9432 | A: OR 2.5, 95% CI (2.0–3.0) | Yes* | 64
| | | | A: Men, aged 18–39 years | | A: 2925 | B: OR 2.0, 95% CI (1.5–2.6) | | Med.
| | | | B: Men, aged 40–64 years | | B: 1980 | C: OR 1.4, 95% CI (1.1–1.8)
| | | | C: Women, aged 18–39 years | | C: 2820 | D: OR 1.7, 95% CI (1.2–2.4)
| | | | D: Women, aged 40–64 years | | D: 1707
| Most preventive services covered by health plan | | | | | Total = 17157 | A: OR 1.4, 95% CI (1.2–1.7)
| | | | | | A: 4974 | B: 1.7, 95% CI (1.4–2.1)
| | | | | | B: 3916 | C: 1.5
| | | | | | C: 4565 | D: 1.7
| | | | | | D: 3702
| Some preventive services covered by health plan | | | | | Total = 7647 | A: OR 1.4, 95% CI (1.1–1.7) B: OR 1.2, 95% CI (0.9–1.5)
| | | | | | A: 2114 | C: OR 1.2, 95% CI (1.0–1.5)
| | | | | | B: 1750 | D: OR 1.2, 95% CI (1.0–1.4)
| | | | | | C: 2040
| | | | | | D: 1743
Slesinger, 1976 | Employees who chose prepaid group insurance plan | | | | | 506 | 48%^†^ | No | 47
| Random sampling of employees who chose the traditional BC/BS plan | | | | | 483 | 45% | | Med.

* Race, education, insurance status, marital status, employment, income.

† Not significant.

F/U = follow-up; OR = odds ratio; CI = confidence interval; BC/BS = Blue Cross/Blue Shield; NA = not applicable.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category)

Evidence Table 18c. Receipt of the Periodic Health Exam: Pre-post Study

Author, year | Description of study groups | Target of intervention | Length of F/U | Outcome | Outcome self-reported by patients or providers | N | Baseline | F/U | Adjusted | Qual. Score
| | | | | | | | | | tertile
Schneider, 2003 | Patients: written material, reminder, phone call | Patients and providers | After 1-year intervention. | Health maintenance exam performed | Not self-reported | 321 pre-intervention (baseline) | 11.9% | 19.4%* | No | 69
| Providers: education on prevention measures | | | | | 356 post-intervention (F/U) | | | | Med.

* p < 0.005.

F/U = follow-up; NR = not reported.

Qual. Score = quality score (for assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms, scores were calculated by adding quality scores and dividing them by the maximum score for any given category).