# Appendix F: Study Nomenclature

## Nomenclature used by studies

Study, year | Used Nomenclature
Lin, 2004 | Health maintenance visit
Somkin, 2004 | Check-up
Flocke, 2004; Eaton, 2002 | Health care maintenance visit
Schneider, 2003 | Health maintenance examination
Finkelstein, 2002 | Health examination or Periodic health examination
Hahn, 1999 | Physical examination or Preventive services
Chiou, 2002 | Physical examination or Health examination
Burton, 2002 | Periodic health examination or Periodic health evaluation
Tao, 2001 | General medical examination or Periodic health examination
Parchman, 2001 | Check-up
Shannon, 2001 | Physical examination or Periodic health examination
Nutting, 2001 | Annual examination or Health maintenance visit
Hama, 2001 | Preassignment medical examination
Patrick, 1999 | Health risk assessment or preventive services
Stange, 2000 | Screening service or Preventive services
Freedman, 2000 | Periodic health examination
Williams, 1998 | Health maintenance examination
Faulkner, 1997 | Periodic health exam
Kottke, 1997 | Physical examination or check-up
Sox, 1997 | Periodic health examination
Elder, 1995; Cacciatore, 1994 | Health risk appraisal
Christensen, 1995 | Preventive health examination
Morrisey, 1995 | Preventive care visit or Health promotion service package
Holl, 1995; German, 1995; Burton, 1997; Burton, 1995 | Physical examination
Giger, 1993 | Health check or Physical examination
Norman, 1992 | Health check
Belcher, 1990 | Physical examination
Bernacki, 1988 | Periodic physical examination
Stone, 1981; Stone, 1978; no author, 1977; no author, 2001;Tevelyan, 1973; Stone, 1978 | Multiphasic screening
Fletcher, 1977 | Multiphasic screening
Collen, 1977 | Health examination or Multiphasic health check
Slesinger, 1976 | General physical check-up Physical examination
Cutler, 1973; Collen, 1973; Dales, 1973; Ramcharan, 1973; Friedman, 1986; Dales, 1979; Norinder, 2002 | Periodic health examination or Multiphasic health check-up
Robert, 1969 | Periodic health examination
Grimaldi, 1965 | Periodic physical examination or Periodic health examination
Theobald, 1998 | General health examination
OXCHECK, 1995 | Health check
Belcher, 1990 | Physical examination or Preventive services
Nakanishi, 1996 | Health check-up Periodic health examination